# APPENDIX C FRAMEWORK FOR ATSDR’S SYSTEMATIC REVIEW OF HEALTH EFFECTS DATA FOR BROMODICHLOROMETHANE

To increase the transparency of ATSDR’s process of identifying, evaluating, synthesizing, and interpreting the scientific evidence on the health effects associated with exposure to bromodichloromethane, ATSDR utilized a slight modification of NTP’s Office of Health Assessment and Translation (OHAT) systematic review methodology (NTP 2013, 2015; Rooney et al. 2014). ATSDR’s framework is an eight-step process for systematic review with the goal of identifying the potential health hazards of exposure to bromodichloromethane:

- Step 1. Problem Formulation
- Step 2. Literature Search and Screen for Health Effects Studies
- Step 3. Extract Data from Health Effects Studies
- Step 4. Identify Potential Health Effect Outcomes of Concern
- Step 5. Assess the Risk of Bias for Individual Studies
- Step 6. Rate the Confidence in the Body of Evidence for Each Relevant Outcome
- Step 7. Translate Confidence Rating into Level of Evidence of Health Effects
- Step 8. Integrate Evidence to Develop Hazard Identification Conclusions

## C.1 PROBLEM FORMULATION

The objective of the toxicological profile and this systematic review was to identify the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to bromodichloromethane. The inclusion criteria used to identify relevant studies examining the health effects of bromodichloromethane are presented in Table C-1.

Data from human and laboratory animal studies were considered relevant for addressing this objective. Human studies were divided into two broad categories: observational epidemiology studies and controlled exposure studies. The observational epidemiology studies were further divided: cohort studies (retrospective and prospective studies), population studies (with individual data or aggregate data), and case-control studies.

Table C-1 Inclusion Criteria for Identifying Health Effects Studies

- Species; - Human; - Laboratory mammals
- Route of exposure; - Inhalation; - Oral; - Dermal (or ocular); - Parenteral (these studies will be considered supporting data)
- Health outcome; - Death; - Systemic effects; - Body weight effects; - Respiratory effects; - Cardiovascular effects; - Gastrointestinal effects; - Hematological effects; - Musculoskeletal effects; - Hepatic effects; - Renal effects; - Dermal effects; - Ocular effects; - Endocrine effects; - Immunological effects; - Neurological effects; - Reproductive effects; - Developmental effects; - Other noncancer effects; - Cancer

## C.2 LITERATURE SEARCH AND SCREEN FOR HEALTH EFFECTS STUDIES

A literature search and screen was conducted to identify studies examining the health effects of bromodichloromethane. The literature search framework for the toxicological profile is discussed in detail in Appendix B.

### C.2.1 Literature Search

As noted in Appendix B, the current literature search was intended to update the draft toxicological profile for bromodichloromethane released for public comment in 2018. See Appendix B for the databases searched and the search strategy.

A total of 209 records relevant to all sections of the toxicological profile were identified (after duplicate removal).

### C.2.2 Literature Screening

As described in Appendix B, a two-step process was used to screen the literature search to identify relevant studies examining the health effects of bromodichloromethane.

Title and Abstract Screen. In the Title and Abstract Screen step, 236 records were reviewed; 12 documents were considered to meet the health effects inclusion criteria in Table C-1 and were moved to the next step in the process.

Full Text Screen. In the second step in the literature screening process for the systematic review, a full text review of the 12 health effects documents identified in the update literature was performed. From those 12 documents, 8 studies were included in the qualitative review. Additionally, 77 studies cited in the LSE tables for the existing profile were included in the full study screen bringing the total number of studies for the qualitative review to 85.

## C.3 EXTRACT DATA FROM HEALTH EFFECTS STUDIES

Relevant data extracted from the individual studies selected for inclusion in the systematic review were collected in customized data forms. A summary of the type of data extracted from each study is presented in Table C-2. For references that included more than one experiment or species, data extraction records were created for each experiment or species.

Table C-2 Data Extracted From Individual Studies

- Citation; - Chemical form; - Route of exposure (e.g., inhalation, oral, dermal); - Specific route (e.g., gavage in oil, drinking water); - Species; - Strain; - Exposure duration category (e.g., acute, intermediate, chronic); - Exposure duration; - Frequency of exposure (e.g., 6 hours/day, 5 days/week); - Exposure length; - Number of animals or subjects per sex per group; - Dose/exposure levels; - Parameters monitored; - Description of the study design and method; - Summary of calculations used to estimate doses (if applicable); - Summary of the study results; - Reviewer’s comments on the study; - Outcome summary (one entry for each examined outcome); - No-observed-adverse-effect level (NOAEL) value; - Lowest-observed-adverse-effect level (LOAEL) value; - Effect observed at the LOAEL value

A summary of the extracted data for each study is presented in the Supplemental Document for Bromodichloromethane and overviews of the results of the inhalation and oral exposure studies (no dermal exposure studies were identified) are presented in Sections 2.2–2.18 of the profile and in the Levels Significant Exposures tables in Section 2.1 of the profile (Tables 2-2 and 2-3, respectively).

## C.4 IDENTIFY POTENTIAL HEALTH EFFECT OUTCOMES OF CONCERN

Overviews of the potential health effect outcomes for bromodichloromethane identified in human and animal studies are presented in Tables C-3 and C-4, respectively. The available human studies examined a limited number of endpoints (hepatic, immunological, reproductive, and developmental effects) and reported immunological, reproductive, and developmental effects. Animal studies examined a number of endpoints following inhalation or oral exposure. These studies examined most endpoints and reported body weight, gastrointestinal, hematological, hepatic, renal, ocular, endocrine, immunological, reproductive, developmental, and other noncancer (alterations in blood glucose) effects. Hepatic, renal, immunological, reproductive, and developmental effects were considered sensitive outcomes (i.e., effects were observed at low concentrations or doses). Studies examining these potential outcomes were carried through to Steps 4–8 of the systematic review. Eighty-five studies (published in 54 documents) examining these potential outcomes were carried through to Steps 4–8 of the systematic review.

Table C-3 Overview of the Health Outcomes for Bromodichloromethane Evaluated In Human Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological | Neurological | Reproductive | Developmental | Other Noncancer | Caner
Inhalation studies
Cohort
Cohort
Case control
Case control
Population
Population
Case series
Case series
Oral studies
Cohort | | | | | | | | | | | | | | 2 | 9 | | 1
Cohort | | | | | | | | | | | | | | 2 | 8 | | 1
Case control | | | | | | | | | | | | | | | 4 | | 1
Case control | | | | | | | | | | | | | | | 2 | | 1
Population | | | | | | | 1 | | | | | 1 | | 1 | | | 1
Population | | | | | | | 0 | | | | | 1 | | 0 | | | 0
Case series
Case series
Dermal studies
Cohort
Cohort
Case control
Case control
Population
Population
Case series
Case series
Number of studies examining endpoint | | | | 0 | 1 | 2 | 3 | 4 | 5-9 | ≥10
Number of studies reporting outcome | | | | 0 | 1 | 2 | 3 | 4 | 5-9 | ≥10

Table C-4 Overview of the Health Outcomes for Bromodichloromethane Evaluated in Experimental Animal Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological^a^ | Neurological^a^ | Reproductive^a^ | Developmental | Other Noncancer | Caner
Inhalation studies
Acute-duration | 2 | | | | | | 2 | 2 | | 2 | | | | | | 2
Acute-duration | 2 | | | | | | 2 | 2 | | 2 | | | | | | 0
Intermediate-duration | 3 | | | | | | 2 | 2 | | | | | | | | 3
Intermediate-duration | 0 | | | | | | 0 | 2 | | | | | | | | 0
Chronic-duration
Chronic-duration
Oral studies
Acute-duration | 16 | 1 | 1 | 1 | 3 | 1 | 9 | 8 | | | 1 | 3 | 3 | 4 | 7 | 5
Acute-duration | 12 | 0 | 0 | 0 | 2 | 0 | 7 | 6 | | | 0 | 2 | 2 | 3 | 7 | 1
Intermediate-duration | 11 | 7 | 7 | 9 | 6 | | 9 | 11 | | | 7 | 2 | 8 | 6 | 3 | 2
Intermediate-duration | 5 | 0 | 0 | 1 | 0 | | 6 | 2 | | | 0 | 1 | 1 | 2 | 1 | 1
Chronic-duration | 8 | 7 | 7 | 7 | 1 | | 8 | 7 | | | 7 | | 1 | 6 | | 1 | 8
Chronic-duration | 4 | 0 | 0 | 0 | 0 | | 4 | 3 | | | 1 | | 0 | 1 | | 1 | 3
Dermal studies
Acute-duration
Acute-duration
Intermediate-duration
Intermediate-duration
Chronic-duration
Chronic-duration
Number of studies examining endpoint | | | | 0 | 1 | 2 | 3 | 4 | 5-9 | ≥10
Number of studies reporting outcome | | | | 0 | 1 | 2 | 3 | 4 | 5-9 | ≥10

a Number of studies examining endpoint includes study evaluating histopathology, but not evaluating function

## C.5 ASSESS THE RISK OF BIAS FOR INDIVIDUAL STUDIES

### C.5.1 Risk of Bias Assessment

The risk of bias of individual studies was assessed using OHAT’s Risk of Bias Tool (NTP 2015). The risk of bias questions for observational epidemiology studies, human-controlled exposure studies, and animal experimental studies are presented in Tables C-5, C-6, and C-7, respectively. Each risk of bias question was answered on a four-point scale:

- Definitely low risk of bias (++)
- Probably low risk of bias (+)
- Probably high risk of bias (−)
- Definitely high risk of bias (− −)

In general, “definitely low risk of bias” or “definitely high risk of bias” was used if the question could be answered with information explicitly stated in the study report. If the response to the question could be inferred, then “probably low risk of bias” or “probably high risk of bias” response was typically used.

Table C-5 Risk of Bias Questionnaire for Observational Epidemiology Studies

Selection bias; - Were the comparison groups appropriate?
Confounding bias; - Did the study design or analysis account for important confounding and modifying variables?
Attrition/exclusion bias; - Were outcome data complete without attrition or exclusion from analysis?
Detection bias; - Is there confidence in the exposure characterization?; - Is there confidence in outcome assessment?
Selective reporting bias; - Were all measured outcomes reported?

Table C-6 Risk of Bias Questionnaire for Human-Controlled Exposure Studies

Selection bias; - Was administered dose or exposure level adequately randomized?; - Was the allocation to study groups adequately concealed?
Performance bias; - Were the research personnel and human subjects blinded to the study group during the study?
Attrition/exclusion bias; - Were outcome data complete without attrition or exclusion from analysis?
Detection bias; - Is there confidence in the exposure characterization?; - Is there confidence in outcome assessment?
Selective reporting bias; - Were all measured outcomes reported?

Table C-7 Risk of Bias Questionnaire for Experimental Animal Studies

Selection bias; - Was administered dose or exposure level adequately randomized?; - Was the allocation to study groups adequately concealed?
Performance bias; - Were experimental conditions identical across study groups?; - Were the research personnel blinded to the study group during the study?
Attrition/exclusion bias; - Were outcome data complete without attrition or exclusion from analysis?
Detection bias; - Is there confidence in the exposure characterization?; - Is there confidence in outcome assessment?
Selective reporting bias; - Were all measured outcomes reported?

After the risk of bias questionnaires were completed for the health effects studies, the studies were assigned to one of three risk of bias tiers based on the responses to the key questions listed below and the responses to the remaining questions.

- Is there confidence in the exposure characterization? (only relevant for observational studies)
- Is there confidence in the outcome assessment?
- Does the study design or analysis account for important confounding and modifying variables? (only relevant for observational studies)

First Tier. Studies placed in the first tier received ratings of “definitely low” or “probably low” risk of bias on the key questions AND received a rating of “definitely low” or “probably low” risk of bias on the responses to at least 50% of the other applicable questions.

Second Tier. A study was placed in the second tier if it did not meet the criteria for the first or third tiers.

Third Tier. Studies placed in the third tier received ratings of “definitely high” or “probably high” risk of bias for the key questions AND received a rating of “definitely high” or “probably high” risk of bias on the response to at least 50% of the other applicable questions.

The results of the risk of bias assessment for the different types of bromodichloromethane health effects studies (observational epidemiology and animal experimental studies) are presented in Tables C-8 and C-9, respectively.

Table C-8 Summary of Risk of Bias Assessment for Bromodichloromethane—Observational Epidemiology Studies

Reference | Risk of bias criteria and ratings | | | | | | Risk of bias tier
Reference | Selection bias | Confounding bias | Attrition / exclusion bias | Detection bias | | Selective reporting bias | Risk of bias tier
Reference | Comparison groups appropriate? | Study design or analysis account for important confounding and modifying variables?^*^ | Outcome data complete without attrition or exclusion from analysis? | Confidence in exposure characterization?^*^ | Confidence in outcome assessment?^*^ | All measured outcomes reported? | Risk of bias tier
Outcome: Hepatic Effects
Cross-sectional studies
Burch et al. 2015 | ++ | − | + | + | + | + | Third
Outcome: Immunological Effects
Cohort studies
Vlaanderen et al. 2017 | ++ | − | + | + | + | + | Third
Outcome: Reproductive Effects
Cohort studies
MacLehose et al. 2008 | ++ | − | + | − | + | + | Third
Windham et al. 2003 | ++ | − | + | − | + | + | Third
Cross-sectional studies
Zeng et al. 2013 | ++ | − | + | + | + | + | Third
Outcome: Developmental Effects
Cohort studies
Cao et al. 2016 | ++ | − | + | + | + | + | Third
Chen et al. 2019 | ++ | − | + | + | + | + | Third
Dodds and King 2001 | ++ | − | + | − | + | + | Third
Grazuleviciene et al. 2013 | ++ | − | + | − | + | + | Third
King et al. 2000 | ++ | − | + | − | + | + | Third
Rivera-Núñez and Wright 2013 | ++ | − | + | − | + | + | Third
Summerhayes et al. 2012 | ++ | − | + | − | + | + | Third
Waller et al. 1998 | ++ | − | + | − | + | + | Third
Wright et al. 2004 | ++ | − | + | − | + | + | Third
Case-control Studies
Danileviciute et al. 2012 | ++ | − | + | − | + | + | Third
Iszatt et al. 2011 | ++ | − | + | − | + | + | Third
Rivera-Núñez et al. 2018 | ++ | − | + | − | + | + | Third
Wright et al. 2017 | ++ | − | + | − | + | + | Third

++ = definitely low risk of bias; + = probably low risk of bias; − = probably high risk of bias; − − = definitely high risk of bias; na = not applicable

* Key question used to assign risk of bias tier

Table C-9 Summary of Risk of Bias Assessment for Bromodichloromethane—Experimental Animal Studies

Reference | Risk of bias criteria and ratings | | | | | | | | Risk of bias tier
Reference | Selection bias | | Performance bias | | Attrition/exclusion bias | Detection bias | | Selective reporting bias | Risk of bias tier
Reference | Administered dose or exposure level adequately randomized? | Allocation to study groups adequately concealed? | Experimental conditions identical across study groups? | Research personnel blinded to the study group during the study? | Outcome data complete without attrition or exclusion from analysis? | Confidence in exposure characterization? | Confidence in outcome assessment?^*^ | All measured outcomes reported? | Risk of bias tier
Outcome: Hepatic Effects
Inhalation acute exposure
Torti et al. 2001 (C57BL/6 mouse) | ++ | + | ++ | + | + | + | + | + | First
Torti et al. 2001 (FVN mouse) | ++ | + | ++ | + | + | + | + | + | First
Inhalation intermediate exposure
Torti et al. 2001 (C57BL/6 mouse) | ++ | + | ++ | + | + | + | + | + | First
Torti et al. 2001 (FVN mouse | ++ | + | ++ | + | + | + | + | + | First
Oral acute exposure
Condie et al. 1983 (mouse) | − | + | + | + | + | − | + | + | First
Keegan et al. 1998 (rat) | − | + | + | + | + | + | + | + | First
Lilly et al. 1994 (rat, GW) | + | + | + | + | + | + | + | + | First
Lilly et al. 1994 (rat, GO) | + | + | + | + | + | + | + | + | First
Lilly et al. 1996 (rat) | + | + | + | + | + | + | + | + | First
Munson et al. 1982 (mouse) | − | + | + | + | + | + | + | + | First
Ruddick et al. 1983 (rat) | + | + | + | + | + | + | + | + | First
Thornton-Manning et al. 1994 (rat) | + | + | + | + | + | + | + | + | First
Thornton-Manning et al. 1994 (mouse) | + | + | + | + | + | + | + | + | First
Oral intermediate exposure
Aida et al. 1989 (rat, F) | − | + | + | + | + | + | + | + | First
Aida et al. 1989 (rat, W) | − | + | + | + | + | + | + | + | First
Aida et al. 1992 (rat) | + | + | + | + | + | + | + | + | First
Chu et al. 1982 (rat) | − | + | + | + | + | − | + | + | First
Hooth et al. 2002 (rat) | + | + | + | + | + | + | + | + | First
NTP 1987 (rat) | ++ | + | + | + | + | ++ | + | + | First
NTP 1987 (mouse) | ++ | + | + | + | + | ++ | + | + | First
NTP 2006 (rat) | ++ | + | + | + | + | ++ | + | ++ | First
NTP 2006 (mouse) | ++ | + | + | + | + | ++ | + | ++ | First
Oral chronic exposure
Aida et al. 1992 (rat) | + | + | + | + | + | + | + | + | First
George et al. 2002 (rat) | + | + | + | + | + | + | + | + | First
George et al. 2002 (mouse) | + | + | + | + | + | + | + | + | First
NTP 1987 (rat) | ++ | + | + | + | + | ++ | + | ++ | First
NTP 1987 (mouse) | ++ | + | + | + | + | ++ | + | ++ | First
NTP 2006 (rat) | ++ | + | + | + | + | ++ | + | ++ | First
NTP 2006 (mouse) | ++ | + | + | + | + | ++ | + | ++ | First
Tumasonis et al. 1985 (rat) | − | + | + | + | + | + | + | + | First
Outcome: Renal Effects
Inhalation acute exposure
Torti et al. 2001 (C57BL/6 mouse) | ++ | + | ++ | + | + | + | + | + | First
Torti et al. 2001 (FVN mouse) | ++ | + | ++ | + | + | + | + | + | First
Inhalation intermediate exposure
Torti et al. 2001 (C57BL/6 mouse) | ++ | + | ++ | + | + | + | + | + | First
Torti et al. 2001 (FVN mouse) | ++ | + | ++ | + | + | + | + | + | First
Oral acute exposure
Condie et al. 1983 (mouse) | − | + | + | + | + | − | + | + | First
Lilly et al. 1994 (rat, GW) | + | + | + | + | + | + | + | + | First
Lilly et al. 1994 (rat, GO) | + | + | + | + | + | + | + | + | First
Lilly et al. 1996 (rat) | + | + | + | + | + | + | + | + | First
Munson et al. 1982 (mouse) | − | + | + | + | + | + | + | + | First
Ruddick et al. 1983 (rat) | + | + | + | + | + | + | + | + | First
Thornton-Manning et al. 1994 (rat) | + | + | + | + | + | + | + | + | First
Thornton-Manning et al. 1994 (mouse) | + | + | + | + | + | + | + | + | First
Oral intermediate exposure
Aida et al. 1989 (rat, F) | − | + | + | + | + | + | + | + | First
Aida et al. 1989 (rat, W) | − | + | + | + | + | + | + | + | First
Aida et al. 1992 (rat) | + | + | + | + | + | + | + | + | First
Chu et al. 1982 (rat) | − | + | + | + | + | − | + | + | First
Lipsky et al. 1993 (rat) | − | + | + | + | + | − | + | + | First
Lock et al. 2004 (rat) | − | + | + | + | + | + | + | + | First
Lock et al. 2004 (mouse) | − | + | + | + | + | + | + | + | First
NTP 1987 (rat) | ++ | + | + | + | + | ++ | + | ++ | First
NTP 1987 (mouse) | ++ | + | + | + | + | ++ | + | ++ | First
NTP 2006 (rat) | ++ | + | + | + | + | ++ | + | ++ | First
NTP 2006 (mouse) | ++ | + | + | + | + | ++ | + | ++ | First
Oral chronic exposure
Aida et al. 1992 (rat) | + | + | + | + | + | + | + | + | First
George et al. 2002 (rat) | + | + | + | + | + | + | + | + | First
George et al. 2002 (mouse) | + | + | + | + | + | + | + | + | First
NTP 1987 (rat) | ++ | + | + | + | + | ++ | + | ++ | First
NTP 1987 (mouse) | ++ | + | + | + | + | ++ | + | ++ | First
NTP 2006 (rat) | ++ | + | + | + | + | ++ | + | ++ | First
NTP 2006 (mouse) | ++ | + | + | + | + | ++ | + | ++ | First
Outcome: Immunological Effects
Oral acute exposure
French et al. 1999 (rat, 5 days) | − | + | + | + | + | + | + | + | First
French et al. 1999 (rat, 14 days) | − | + | + | + | + | + | + | + | First
Munson et al. 1982 | − | + | + | + | + | + | + | + | First
Oral intermediate exposure
French et al. 1999 (mouse, 16 days; GW) | − | + | + | + | + | + | + | + | First
French et al. 1999 (rat, 26 weeks; W) | − | + | + | + | + | + | + | + | First
Outcome: Reproductive Effects
Oral acute exposure
Bielmeier et al. 2001 (rat, GDs 8–9) | − | + | + | + | + | + | + | ++ | First
Bielmeier et al. 2004 (rat) | − | + | + | + | + | + | + | ++ | First
Bielmeier et al. 2007 (rat) | − | + | + | + | + | + | + | ++ | First
Ruddick et al. 1983 (rat) | + | + | + | + | + | + | + | + | First
Oral intermediate exposure
Aida et al. 1992 (rat) | + | + | + | + | + | + | + | + | First
Christian et al. 2001b | ++ | + | + | + | + | + | + | + | First
NTP 1987 (rat) | ++ | + | + | + | + | ++ | + | ++ | First
NTP 1987 (mouse) | ++ | + | + | + | + | ++ | + | ++ | First
NTP 2006 (rat) | ++ | + | + | + | + | ++ | + | ++ | First
NTP 2006 (mouse) | ++ | + | + | + | + | ++ | + | ++ | First
Oral chronic exposure
Aida et al. 1992 (rat) | + | + | + | + | + | + | + | + | First
Klinefelter et al. 1995 (rat) | − | + | + | + | + | + | + | + | First
NTP 1987 (rat) | ++ | + | + | + | + | ++ | + | ++ | First
NTP 1987 (mouse) | ++ | + | + | + | + | ++ | + | ++ | First
NTP 2006 (rat) | ++ | + | + | + | + | ++ | + | ++ | First
NTP 2006 (mouse) | ++ | + | + | + | + | ++ | + | ++ | First
Outcome: Developmental Effects
Oral Acute Exposure
Bielmeier et al. 2001 (rat, GDs 6–10) | − | + | + | + | + | + | + | ++ | First
Bielmeier et al. 2001 (Sprague-Dawley rat, GDs 6–10) | − | + | + | + | + | + | + | ++ | First
Bielmeier et al. 2001 (rat, GDs 8–9) | − | + | + | + | + | + | + | ++ | First
Bielmeier et al. 2001 (rat, GDs 6–10 or 6–15) | − | + | + | + | + | + | + | ++ | First
Bielmeier et al. 2004 (rat) | − | + | + | + | + | + | + | ++ | First
Narotsky et al. 1997 (rat) | ++ | + | + | + | + | + | + | ++ | First
Ruddick et al. 1983 (rat) | + | + | + | + | + | + | + | + | First
Oral intermediate exposure
Christian et al. 2001a (rat) | ++ | + | + | + | + | + | + | + | First
Christian et al. 2001a (rabbit) | ++ | + | + | + | + | + | + | + | First
Christian et al. 2001b (rat) | ++ | + | + | + | + | + | + | + | First

++ = definitely low risk of bias; + = probably low risk of bias; − = probably high risk of bias; − − = definitely high risk of bias; na = not applicable

* Key question used to assign risk of bias tier

## C.6 RATE THE CONFIDENCE IN THE BODY OF EVIDENCE FOR EACH RELEVANT OUTCOME

Confidences in the bodies of human and animal evidence were evaluated independently for each potential outcome. ATSDR did not evaluate the confidence in the body of evidence for carcinogenicity; rather, the Agency defaulted to the cancer weight-of-evidence assessment of other agencies including DHHS, EPA, and IARC. The confidence in the body of evidence for an association or no association between exposure to bromodichloromethane and a particular outcome was based on the strengths and weaknesses of individual studies. Four descriptors were used to describe the confidence in the body of evidence for effects or when no effect was found:

- High confidence: the true effect is highly likely to be reflected in the apparent relationship
- Moderate confidence: the true effect may be reflected in the apparent relationship
- Low confidence: the true effect may be different from the apparent relationship
- Very low confidence: the true effect is highly likely to be different from the apparent relationship

Confidence in the body of evidence for a particular outcome was rated for each type of study: case-control, case series, cohort, population, human-controlled exposure, and experimental animal. In the absence of data to the contrary, data for a particular outcome were collapsed across animal species, routes of exposure, and exposure durations. If species (or strain), route, or exposure duration differences were noted, then the data were treated as separate outcomes.

### C.6.1 Initial Confidence Rating

In ATSDR’s modification to the OHAT approach, the body of evidence for an association (or no association) between exposure to bromodichloromethane and a particular outcome was given an initial confidence rating based on the key features of the individual studies examining that outcome. The presence of these key features of study design was determined for individual studies using four “yes or no” questions, which were customized for epidemiology, human controlled exposure, or experimental animal study designs. Separate questionnaires were completed for each outcome assessed in a study. The key features for observational epidemiology (cohort, population, and case-control) studies, human controlled exposure, and experimental animal studies are presented in Tables C-10, C-11, and C-12, respectively. The initial confidence in the study was determined based on the number of key features present in the study design:

- High Initial Confidence: Studies in which the responses to the four questions were “yes”.
- Moderate Initial Confidence: Studies in which the responses to only three of the questions were “yes”.
- Low Initial Confidence: Studies in which the responses to only two of the questions were “yes”.
- Very Low Initial Confidence: Studies in which the response to one or none of the questions was “yes”.

Table C-10 Key Features of Study Design for Observational Epidemiology Studies

Exposure was experimentally controlled
Exposure occurred prior to the outcome
Outcome was assessed on individual level rather than at the population level
A comparison group was used

Table C-11 Key Features of Study Design for Human-Controlled Exposure Studies

A comparison group was used or the subjects served as their own control
A sufficient number of subjects were tested
Appropriate methods were used to measure outcomes (i.e., clinically-confirmed outcome versus self-reported)
Appropriate statistical analyses were performed and reported or the data were reported in such a way to allow independent statistical analysis

Table C-12 Key Features of Study Design for Experimental Animal Studies

A concurrent control group was used
A sufficient number of animals per group were tested
Appropriate parameters were used to assess a potential adverse effect
Appropriate statistical analyses were performed and reported or the data were reported in such a way to allow independent statistical analysis

The presence or absence of the key features and the initial confidence levels for studies examining hepatic, renal, immunological, reproductive, and developmental effects observed in the observational epidemiology and animal experimental studies are presented in Tables C-13 and C-14, respectively.

Table C-13 Presence of Key Features of Study Design for Bromodichloromethane—Observational Epidemiology Studies

Reference | Key features | | | | Initial study confidence
Reference | Controlled exposure | Exposure prior to outcome | Outcomes assessed on an individual level | Comparison group | Initial study confidence
Outcome: Hepatic effects
Cross-sectional studies
Burch et al. 2015 | No | No | Yes | Yes | Low
Outcome: Immunological effects
Cohort studies
Vlaanderen et al. 2017 | No | Yes | Yes | Yes | Moderate
Outcome: Reproductive effects
Cohort studies
MacLehose et al. 2008 | No | No | Yes | Yes | Low
Windham et al. 2003 | No | No | Yes | Yes | Low
Cross-sectional studies
Zeng et al. 2013 | No | No | Yes | Yes | Low
Outcome: Developmental effects
Cohort studies
Cao et al. 2016 | No | No | Yes | Yes | Low
Chen et al. 2019 | No | No | Yes | Yes | Low
Dodds and King 2001 | No | No | Yes | Yes | Low
Grazuleviciene et al. 2013 | No | No | Yes | Yes | Low
King et al. 2000 | No | No | Yes | Yes | Low
Rivera-Núñez and Wright 2013 | No | No | Yes | Yes | Low
Summerhayes et al. 2012 | No | No | Yes | Yes | Low
Waller et al. 1998 | No | No | Yes | Yes | Low
Wright et al. 2004 | No | No | Yes | Yes | Low
Case-control studies
Danileviciute et al. 2012 | No | No | Yes | Yes | Low
Iszatt et al. 2011 | No | No | Yes | Yes | Low
Rivera-Núñez et al. 2018 | No | No | Yes | Yes | Low
Wright et al. 2017 | No | No | Yes | Yes | Low

Table C-14 Presence of Key Features of Study Design for Bromodichloromethane—Experimental Animal Studies

Reference | Key features | | | | Initial study confidence
Reference | Concurrent control group | Sufficient number of animals per group | Appropriate parameters to assess potential effect | Adequate data for statistical analysis | Initial study confidence
Outcome: Hepatic Effects
Inhalation acute exposure
Torti et al. 2001 (C57BL/6 mouse) | Yes | No | Yes | Yes | Moderate
Torti et al. 2001 (FVN mouse) | Yes | No | Yes | Yes | Moderate
Inhalation intermediate exposure
Torti et al. 2001 (C57BL/6 mouse) | Yes | No | Yes | Yes | Moderate
Torti et al. 2001 (FVN mouse) | Yes | No | Yes | Yes | Moderate
Oral acute exposure
Condie et al. 1983 (mouse) | Yes | No | Yes | Yes | Moderate
Keegan et al. 1998 (rat) | Yes | No | No | Yes | Low
Lilly et al. 1994 (rat, GW) | Yes | No | Yes | Yes | Moderate
Lilly et al. 1994 (rat, GO) | Yes | No | Yes | Yes | Moderate
Lilly et al. 1996 (rat) | Yes | No | Yes | Yes | Moderate
Munson et al. 1982 (mouse) | Yes | No | No | Yes | Low
Ruddick et al. 1983 (rat) | Yes | No | Yes | Yes | Moderate
Thornton-Manning et al. 1994 (rat) | Yes | No | Yes | Yes | Moderate
Thornton-Manning et al. 1994 (mouse) | Yes | No | Yes | Yes | Moderate
Oral intermediate exposure
Aida et al. 1989 (rat, F) | Yes | No | Yes | Yes | Moderate
Aida et al. 1989 (rat, W) | Yes | No | Yes | Yes | Moderate
Aida et al. 1992 (rat) | Yes | Yes | Yes | Yes | High
Chu et al. 1982 (rat) | Yes | No | Yes | Yes | Moderate
Hooth et al. 2002 (rat) | Yes | No | Yes | Yes | Moderate
NTP 1987 (rat) | Yes | Yes | Yes | Yes | High
NTP 1987 (mouse) | Yes | Yes | Yes | Yes | High
NTP 2006 (rat) | Yes | No | Yes | Yes | Moderate
NTP 2006 (mouse) | Yes | No | Yes | Yes | Moderate
Oral chronic exposure
Aida et al. 1992 (rat) | Yes | Yes | Yes | Yes | High
George et al. 2002 (rat) | Yes | No | Yes | Yes | Moderate
George et al. 2002 (mouse) | Yes | No | Yes | Yes | Moderate
NTP 1987 (rat) | Yes | Yes | Yes | Yes | High
NTP 1987 (mouse) | Yes | Yes | Yes | Yes | High
NTP 2006 (rat) | Yes | No | Yes | Yes | Moderate
NTP 2006 (mouse) | Yes | No | Yes | Yes | Moderate
Tumasonis et al. 1985 (rat) | Yes | Yes | Yes | Yes | High
Outcome: Renal Effects
Inhalation acute exposure
Torti et al. 2001 (C57BL/6 mouse) | Yes | No | Yes | Yes | Moderate
Torti et al. 2001 (FVN mouse) | Yes | No | Yes | Yes | Moderate
Inhalation intermediate exposure
Torti et al. 2001 (C57BL/6 mouse) | Yes | No | Yes | Yes | Moderate
Torti et al. 2001 (FVN mouse) | Yes | No | Yes | Yes | Moderate
Oral acute exposure
Condie et al. 1983 (mouse) | Yes | No | Yes | Yes | Moderate
Lilly et al. 1994 (rat, GW) | Yes | No | Yes | Yes | Moderate
Lilly et al. 1994 (rat, GO) | Yes | No | Yes | Yes | Moderate
Lilly et al. 1996 (rat) | Yes | No | Yes | Yes | Moderate
Munson et al. 1982 (mouse) | Yes | No | No | Yes | Low
Ruddick et al. 1983 (rat) | Yes | No | Yes | Yes | Moderate
Thornton-Manning et al. 1994 (rat) | Yes | No | Yes | Yes | Moderate
Thornton-Manning et al. 1994 (mouse) | Yes | No | Yes | Yes | Moderate
Oral intermediate exposure
Aida et al. 1989 (rat, F) | Yes | No | Yes | Yes | Moderate
Aida et al. 1989 (rat, W) | Yes | No | Yes | Yes | Moderate
Aida et al. 1992 (rat) | Yes | Yes | Yes | Yes | High
Chu et al. 1982 (rat) | Yes | No | Yes | Yes | Moderate
Lipsky et al. 1993 (rat) | Yes | No | Yes | Yes | Moderate
Lock et al. 2004 (rat) | Yes | No | Yes | Yes | Moderate
Lock et al. 2004 (mouse) | Yes | No | Yes | Yes | Moderate
NTP 1987 (rat) | Yes | Yes | Yes | Yes | High
NTP 1987 (mouse) | Yes | Yes | Yes | Yes | High
NTP 2006 (rat) | Yes | No | Yes | Yes | Moderate
NTP 2006 (mouse) | Yes | No | Yes | Yes | Moderate
Oral chronic exposure
Aida et al. 1992 (rat) | Yes | Yes | Yes | Yes | High
George et al. 2002 (rat) | Yes | No | Yes | Yes | Moderate
George et al. 2002 (mouse) | Yes | No | Yes | Yes | Moderate
NTP 1987 (rat) | Yes | Yes | Yes | Yes | High
NTP 1987 (mouse) | Yes | Yes | Yes | Yes | High
NTP 2006 (rat) | Yes | No | Yes | Yes | Moderate
NTP 2006 (mouse) | Yes | No | Yes | Yes | Moderate
Outcome: Immunological Effects
Oral acute exposure
French et al. 1999 (rat, 5 days) | Yes | No | Yes | Yes | Moderate
French et al. 1999 (rat, 14 days) | Yes | No | Yes | Yes | Moderate
Munson et al. 1982 (mouse) | Yes | No | No | Yes | Low
Oral intermediate exposure
French et al. 1999 (mouse, 16 days; GW) | Yes | No | Yes | Yes | Moderate
French et al. 1999 (rat, 26 weeks, W) | Yes | No | Yes | Yes | Moderate
Outcome: Reproductive Effects
Oral acute exposure
Bielmeier et al. 2001 (rat, GDs 8–9) | Yes | Yes | No | Yes | Moderate
Bielmeier et al. 2004 (rat) | Yes | Yes | No | Yes | Moderate
Bielmeier et al. 2007 (rat) | Yes | No | No | Yes | Low
Ruddick et al. 1983 (rat) | Yes | Yes | No | Yes | Moderate
Oral intermediate exposure
Aida et al. 1992 (rat) | Yes | Yes | No | Yes | Moderate
Christian et al. 2001b | Yes | Yes | Yes | Yes | High
NTP 1987 (rat) | Yes | Yes | No | Yes | Moderate
NTP 1987 (mouse) | Yes | Yes | No | Yes | Moderate
NTP 2006 (rat) | Yes | Yes | No | Yes | Moderate
NTP 2006 (mouse) | Yes | Yes | No | Yes | Moderate
Oral chronic exposure
Aida et al. 1992 (rat) | Yes | Yes | No | Yes | Moderate
Klinefelter et al. 1995 (rat) | Yes | Yes | Yes | Yes | High
NTP 1987 (rat) | Yes | Yes | No | Yes | Moderate
NTP 1987 (mouse) | Yes | Yes | No | Yes | Moderate
NTP 2006 (rat) | Yes | Yes | No | Yes | Moderate
NTP 2006 (mouse) | Yes | Yes | No | Yes | Moderate
Outcome: Developmental Effects
Oral Acute Exposure
Bielmeier et al. 2001 (rat, GDs 6–10) | Yes | Yes | No | Yes | Moderate
Bielmeier et al. 2001 (Sprague-Dawley rat, GDs 6–10) | Yes | Yes | No | Yes | Moderate
Bielmeier et al. 2001 (rat, GDs 8–9) | Yes | Yes | No | Yes | Moderate
Bielmeier et al. 2001 (rat, GDs 6–10 or 6–15) | Yes | Yes | No | Yes | Moderate
Bielmeier et al. 2004 (rat) | Yes | Yes | No | Yes | Moderate
Narotsky et al. 1997 (rat) | Yes | Yes | No | Yes | Moderate
Ruddick et al. 1983 (rat) | Yes | Yes | Yes | No | Moderate
Oral intermediate exposure
Christian et al. 2001a (rat) | Yes | Yes | Yes | Yes | High
Christian et al. 2001a (rabbit) | Yes | Yes | Yes | Yes | High
Christian et al. 2001b (rat) | Yes | Yes | No | Yes | Moderate

A summary of the initial confidence ratings for each outcome is presented in Table C-15. If individual studies for a particular outcome and study type had different study quality ratings, then the highest confidence rating for the group of studies was used to determine the initial confidence rating for the body of evidence; any exceptions were noted in Table C-15.

Table C-15 Initial Confidence Rating for Bromodichloromethane Health Effects Studies

| Initial study confidence | Initial confidence rating
Outcome: Hepatic Effects
Inhalation acute exposure
Animal studies
Torti et al. 2001 (C57BL/6 mouse) | Moderate | Moderate
Torti et al. 2001 (FVN mouse) | Moderate | Moderate
Inhalation intermediate exposure
Animal studies
Torti et al. 2001 (C57BL/6 mouse) | Moderate | Moderate
Torti et al. 2001 (FVN mouse) | Moderate | Moderate
Oral acute exposure
Animal studies
Condie et al. 1983 (mouse) | Moderate | Moderate
Keegan et al. 1998 (rat) | Low | Moderate
Lilly et al. 1994 (rat, GW) | Moderate | Moderate
Lilly et al. 1994 (rat, GO) | Moderate | Moderate
Lilly et al. 1996 (rat) | Moderate | Moderate
Munson et al. 1982 (mouse) | Low | Moderate
Ruddick et al. 1983 (rat) | Moderate | Moderate
Thornton-Manning et al. 1994 (rat) | Moderate | Moderate
Thornton-Manning et al. 1994 (mouse) | Moderate | Moderate
Oral intermediate exposure
Animal studies
Aida et al. 1989 (rat, F) | Moderate | High
Aida et al. 1989 (rat, W) | Moderate | High
Aida et al. 1992 (rat) | High | High
Chu et al. 1982 (rat) | Moderate | High
Hooth et al. 2002 (rat) | Moderate | High
NTP 1987 (rat) | High | High
NTP 1987 (mouse) | High | High
NTP 2006 (rat) | Moderate | High
NTP 2006 (mouse) | Moderate | High
Oral chronic exposure
Human studies
Burch et al. 2015 | Low | Low
Animal studies
Aida et al. 1992 (rat) | High | High
George et al. 2002 (rat) | Moderate | High
George et al. 2002 (mouse) | Moderate | High
NTP 1987 (rat) | High | High
NTP 1987 (mouse) | High | High
NTP 2006 (rat) | Moderate | High
NTP 2006 (mouse) | Moderate | High
Tumasonis et al. 1985 (rat) | High | High
Outcome: Renal Effects
Inhalation acute exposure
Animal studies
Torti et al. 2001 (C57BL/6 mouse) | Moderate | Moderate
Torti et al. 2001 (FVN mouse) | Moderate | Moderate
Inhalation intermediate exposure
Animal studies
Torti et al. 2001 (C57BL/6 mouse) | Moderate | Moderate
Torti et al. 2001 (FVN mouse) | Moderate | Moderate
Oral acute exposure
Animal studies
Condie et al. 1983 (mouse) | Moderate | Moderate
Lilly et al. 1994 (rat, GW) | Moderate | Moderate
Lilly et al. 1994 (rat, GO) | Moderate | Moderate
Lilly et al. 1996 (rat) | Moderate | Moderate
Munson et al. 1982 (mouse) | Low | Moderate
Ruddick et al. 1983 (rat) | Moderate | Moderate
Thornton-Manning et al. 1994 (rat) | Moderate | Moderate
Thornton-Manning et al. 1994 (mouse) | Moderate | Moderate
Oral intermediate exposure
Animal studies
Aida et al. 1989 (rat, F) | Moderate | High
Aida et al. 1989 (rat, W) | Moderate | High
Aida et al. 1992 (rat) | High | High
Chu et al. 1982 (rat) | Moderate | High
Lipsky et al. 1993 (rat) | Moderate | High
Lock et al. 2004 (rat) | Moderate | High
Lock et al. 2004 (mouse) | Moderate | High
NTP 1987 (rat) | High | High
NTP 1987 (mouse) | High | High
NTP 2006 (rat) | Moderate | High
NTP 2006 (mouse) | Moderate | High
Oral chronic exposure
Animal studies
Aida et al. 1992 (rat) | High | High
George et al. 2002 (rat) | Moderate | High
George et al. 2002 (mouse) | Moderate | High
NTP 1987 (rat) | High | High
NTP 1987 (mouse) | High | High
NTP 2006 (rat) | Moderate | High
NTP 2006 (mouse) | Moderate | High
Outcome: Immunological Effects
Oral acute exposure
Animal studies
French et al. 1999 (rat, 5 days) | Moderate | Moderate
French et al. 1999 (rat, 14 days) | Moderate | Moderate
Munson et al. 1982 (mouse) | Low | Moderate
Oral intermediate exposure
Animal studies
French et al. 1999 (mouse, 16 days; GW) | Moderate | Moderate
French et al. 1999 (rat, 26 weeks; W) | Moderate | Moderate
Acute dermal exposure
Human studies
Vlaanderen et al. 2017 | Moderate | Moderate
Outcome: Reproductive Effects
Oral acute exposure
Animal studies
Bielmeier et al. 2001 (rat, GDs 8–9) | Moderate | Moderate
Bielmeier et al. 2004 (rat) | Moderate | Moderate
Bielmeier et al. 2007 (rat) | Low | Moderate
Ruddick et al. 1983 (rat) | Moderate | Moderate
Oral intermediate exposure
Animal studies
Aida et al. 1992 (rat) | Moderate | High
Christian et al. 2001b | High | High
NTP 1987 (rat) | Moderate | High
NTP 1987 (mouse) | Moderate | High
NTP 2006 (rat) | Moderate | High
NTP 2006 (mouse) | Moderate | High
Oral chronic exposure
Human studies
MacLehose et al. 2008 | Low | Low
Windham et al. 2003 | Low | Low
Zeng et al. 2013 | Low | Low
Animal studies
Aida et al. 1992 (rat) | Moderate | High
Klinefelter et al. 1995 (rat) | High | High
NTP 1987 (rat) | Moderate | High
NTP 1987 (mouse) | Moderate | High
NTP 2006 (rat) | Moderate | High
NTP 2006 (mouse) | Moderate | High
Outcome: Developmental Effects
Oral acute exposure
Animal studies
Bielmeier et al. 2001 (F344 rat, GDs 6–10) | Moderate | Moderate
Bielmeier et al. 2001 (Sprague-Dawley rat, GDs 6–10) | Moderate | Moderate
Bielmeier et al. 2001 (rat, GDs 8–9) | Moderate | Moderate
Bielmeier et al. 2001 (rat, GDs 6–10 or 6–15) | Moderate | Moderate
Bielmeier et al. 2004 (rat) | Moderate | Moderate
Narotsky et al. 1997 (rat) | Moderate | Moderate
Ruddick et al. 1983 (rat) | Moderate | Moderate
Oral intermediate exposure
Animal studies
Christian et al. 2001a (rat) | High | High
Christian et al. 2001b (rat) | Moderate | High
Christian et al. 2001a (rabbit) | High | High
Oral chronic exposure
Human studies
Cao et al. 2016 | Low | Low
Chen et al. 2019 | Low | Low
Danileviciute et al. 2012 | Low | Low
Dodds and King 2001 | Low | Low
Grazuleviciene et al. 2013 | Low | Low
Iszatt et al. 2011 | Low | Low
King et al. 2000 | Low | Low
Rivera-Núñez et al. 2018 | Low | Low
Rivera-Núñez and Wright 2013 | Low | Low
Summerhayes et al. 2012 | Low | Low
Waller et al. 1998 | Low | Low
Wright et al. 2004 | Low | Low
Wright et al. 2017 | Low | Low

### C.6.2 Adjustment of the Confidence Rating

The initial confidence rating was then downgraded or upgraded depending on whether there were substantial issues that would decrease or increase confidence in the body of evidence. The nine properties of the body of evidence that were considered are listed below. The summaries of the assessment of the confidence in the body of evidence for hepatic, renal, immunological, reproductive, and developmental effects are presented in Table C-16. If the confidence ratings for a particular outcome were based on more than one type of human study, then the highest confidence rating was used for subsequent analyses. An overview of the confidence in the body of evidence for all health effects associated with bromodichloromethane exposure is presented in Table C-17.

Five properties of the body of evidence were considered to determine whether the confidence rating should be downgraded:

- Risk of bias. Evaluation of whether there is substantial risk of bias across most of the studies examining the outcome. This evaluation used the risk of bias tier groupings for individual studies examining a particular outcome (Tables C-8 and C-9). Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for risk of bias:
  ○ No downgrade if most studies are in the risk of bias first tier
  ○ Downgrade one confidence level if most studies are in the risk of bias second tier
  ○ Downgrade two confidence levels if most studies are in the risk of bias third tier
- Unexplained inconsistency. Evaluation of whether there is inconsistency or large variability in the magnitude or direction of estimates of effect across studies that cannot be explained. Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for unexplained inconsistency:
  ○ No downgrade if there is little inconsistency across studies or if only one study evaluated the outcome
  ○ Downgrade one confidence level if there is variability across studies in the magnitude or direction of the effect
  ○ Downgrade two confidence levels if there is substantial variability across studies in the magnitude or direct of the effect
- Indirectness. Evaluation of four factors that can affect the applicability, generalizability, and relevance of the studies:
  ○ Relevance of the animal model to human health—unless otherwise indicated, studies in rats, mice, and other mammalian species are considered relevant to humans
  ○ Directness of the endpoints to the primary health outcome—examples of secondary outcomes or nonspecific outcomes include organ weight in the absence of histopathology or clinical chemistry findings in the absence of target tissue effects
  ○ Nature of the exposure in human studies and route of administration in animal studies—inhalation, oral, and dermal exposure routes are considered relevant unless there are compelling data to the contrary
  ○ Duration of treatment in animal studies and length of time between exposure and outcome assessment in animal and prospective human studies—this should be considered on an outcome-specific basis
  Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for indirectness:
  ○ No downgrade if none of the factors are considered indirect
  ○ Downgrade one confidence level if one of the factors is considered indirect
  ○ Downgrade two confidence levels if two or more of the factors are considered indirect
- Imprecision. Evaluation of the narrowness of the effect size estimates and whether the studies have adequate statistical power. Data are considered imprecise when the ratio of the upper to lower 95% CIs for most studies is ≥10 for tests of ratio measures (e.g., odds ratios) and ≥100 for absolute measures (e.g., percent control response). Adequate statistical power is determined if the study can detect a potentially biologically meaningful difference between groups (20% change from control response for categorical data or risk ratio of 1.5 for continuous data). Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for imprecision:
  ○ No downgrade if there are no serious imprecisions
  ○ Downgrade one confidence level for serious imprecisions
  ○ Downgrade two confidence levels for very serious imprecisions
- Publication bias. Evaluation of the concern that studies with statistically significant results are more likely to be published than studies without statistically significant results.
  ○ Downgrade one level of confidence for cases where there is serious concern with publication bias

Table C-16 Adjustments to the Initial Confidence in the Body of Evidence

| Initial confidence | Adjustments to the initial confidence rating | Final confidence
Outcome: Hepatic Effects
Human studies | Low | −2 risk of bias | Very Low
Animal studies | High | +1 large magnitude of effect | High
Outcome: Renal Effects
Animal studies | High | −1 inconsistency | Moderate
Outcome: Immunological Effects
Human studies | Moderate | −2 risk of bias, −1 imprecision | Very Low
Animal studies | Moderate | None | Moderate
Outcome: Reproductive Effects
Human studies | Low | −2 risk of bias | Very Low
Animal studies | High | −1 inconsistency. −1 imprecision | Low
Outcome: Developmental Effects
Human studies | Low | −2 risk of bias | Very Low
Animal studies | High | +1 large magnitude of effect | High

Table C-17 Confidence in the Body of Evidence for Bromodichloromethane

Outcome | Confidence in body of evidence
Outcome | Human studies | Animal studies
Hepatic effects | Very Low | High
Renal effects | No data | Moderate
Immunological effects | Very Low | Moderate
Reproductive effects | Very Low | Low
Developmental effects | Very Low | High

Four properties of the body of evidence were considered to determine whether the confidence rating should be upgraded:

- Large magnitude of effect. Evaluation of whether the magnitude of effect is sufficiently large so that it is unlikely to have occurred as a result of bias from potential confounding factors.
  ○ Upgrade one confidence level if there is evidence of a large magnitude of effect in a few studies, provided that the studies have an overall low risk of bias and there is no serious unexplained inconsistency among the studies of similar dose or exposure levels; confidence can also be upgraded if there is one study examining the outcome, provided that the study has an overall low risk of bias
- Dose response. Evaluation of the dose-response relationships measured within a study and across studies. Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level for evidence of a monotonic dose-response gradient
  ○ Upgrade one confidence level for evidence of a non-monotonic dose-response gradient where there is prior knowledge that supports a non-monotonic dose-response and a non-monotonic dose-response gradient is observed across studies
- Plausible confounding or other residual biases. This factor primarily applies to human studies and is an evaluation of unmeasured determinants of an outcome such as residual bias towards the null (e.g., “healthy worker” effect) or residual bias suggesting a spurious effect (e.g., recall bias). Below is the criterion used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level for evidence that residual confounding or bias would underestimate an apparent association or treatment effect (i.e., bias toward the null) or suggest a spurious effect when results suggest no effect
- Consistency in the body of evidence. Evaluation of consistency across animal models and species, consistency across independent studies of different human populations and exposure scenarios, and consistency across human study types. Below is the criterion used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level if there is a high degree of consistency in the database

## C.7 TRANSLATE CONFIDENCE RATING INTO LEVEL OF EVIDENCE OF HEALTH EFFECTS

In the seventh step of the systematic review of the health effects data for bromodichloromethane, the confidence in the body of evidence for specific outcomes was translated to a level of evidence rating. The level of evidence rating reflected the confidence in the body of evidence and the direction of the effect (i.e., toxicity or no toxicity); route-specific differences were noted. The level of evidence for health effects was rated on a five-point scale:

- High level of evidence: High confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Moderate level of evidence: Moderate confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Low level of evidence: Low confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Evidence of no health effect: High confidence in the body of evidence that exposure to the substance is not associated with the health outcome
- Inadequate evidence: Low or moderate confidence in the body of evidence that exposure to the substance is not associated with the health outcome OR very low confidence in the body of evidence for an association between exposure to the substance and the health outcome

A summary of the level of evidence of health effects for bromodichloromethane is presented in Table C-18.

Table C-18 Level of Evidence of Health Effects for Bromodichloromethane

Outcome | Confidence in body of evidence | Direction of health effect | Level of evidence for health effect
Human studies
Hepatic effects | Very Low | Health effect | Inadequate
Renal effects | No data | | No data
Immunological effects | Very Low | Health effect | Inadequate
Reproductive effects | Very Low | Health effect | Inadequate
Developmental effect | Very Low | Health effect | Inadequate
Animal studies
Hepatic effects | High | Health effect | High
Renal effects | Moderate | Health effect | Moderate
Immunological effects | Moderate | Health effect | Moderate
Reproductive effects | Low | Health effect | Low
Developmental effect | High | Health effect | High

## C.8 INTEGRATE EVIDENCE TO DEVELOP HAZARD IDENTIFICATION CONCLUSIONS

The final step involved the integration of the evidence streams for the human studies and animal studies to allow for a determination of hazard identification conclusions. For health effects, there were four hazard identification conclusion categories:

- Known to be a hazard to humans
- Presumed to be a hazard to humans
- Suspected to be a hazard to humans
- Not classifiable as to the hazard to humans

The initial hazard identification was based on the highest level of evidence in the human studies and the level of evidence in the animal studies; if there were no data for one evidence stream (human or animal), then the hazard identification was based on the one data stream (equivalent to treating the missing evidence stream as having low level of evidence). The hazard identification scheme is presented in Figure C-1 and described below:

- Known: A health effect in this category would have:
  ○ High level of evidence for health effects in human studies AND a high, moderate, or low level of evidence in animal studies.
- Presumed: A health effect in this category would have:
  ○ Moderate level of evidence in human studies AND high or moderate level of evidence in animal studies OR
  ○ Low level of evidence in human studies AND high level of evidence in animal studies
- Suspected: A health effect in this category would have:
  ○ Moderate level of evidence in human studies AND low level of evidence in animal studies OR
  ○ Low level of evidence in human studies AND moderate level of evidence in animal studies
- Not classifiable: A health effect in this category would have:
  ○ Low level of evidence in human studies AND low level of evidence in animal studies

Other relevant data such as mechanistic or mode-of-action data were considered to raise or lower the level of the hazard identification conclusion by providing information that supported or opposed biological plausibility.

Two hazard identification conclusion categories were used when the data indicated that there may be no health effect in humans:

- Not identified to be a hazard in humans
- Inadequate to determine hazard to humans

If the human level of evidence conclusion of no health effect was supported by the animal evidence of no health effect, then the hazard identification conclusion category of “not identified” was used. If the human or animal level of evidence was considered inadequate, then a hazard identification conclusion category of “inadequate” was used. As with the hazard identification for health effects, the impact of other relevant data was also considered for no health effect data.

Figure C-1 Hazard Identification Scheme

Figure C-1 description

The hazard identification conclusions for bromodichloromethane are listed below and summarized in Table C-19.

Presumed Health Effects

- Hepatic effects
  ○ Inadequate evidence from a cross-sectional study (Burch et al. 2015) examining the association between serum bromodichloromethane levels and alanine aminotransferase levels.
  ○ High level of evidence in mice following acute inhalation exposure (Torti et al. 2001) and in rats and mice following acute (Condie et al. 1983; Keegan et al. 1998; Lilly et al. 1994, 1996; Munson et al. 1982; Thornton-Manning et al. 1994), intermediate (Aida et al. 1992; Hooth et al. 2002; NTP 1987), and chronic (Aida et al. 1992; NTP 1987) oral exposure.
- Developmental effects
  ○ Although a number of epidemiology studies found associations between exposure to bromodichloromethane and developmental effects, the human data were considered inadequate for evaluating the potential hazard due to the low initial confidence in these studies and the high risk of bias.
  ○ High level of evidence from acute (Bielmeier et al. 2001, 2004; Narotsky et al. 1997) and intermediate (Christian et al. 2001a) oral exposure in rats. The most sensitive developmental endpoint was full-litter resorption in F344 rats, but not in Sprague-Dawley rats (Bielmeier et al. 2001, 2004; Narotsky et al. 1997).

Suspected Health Effects

- Renal effects
  ○ No human data are available on the potential renal toxicity of bromodichloromethane.
  ○ Moderate evidence of renal toxicity in mice following acute or intermediate inhalation exposure and in rats and mice following acute (Condie et al. 1983; Lilly et al. 1994, 1996; Munson et al. 1982; Thornton-Manning et al. (1994), intermediate (NTP 1987), and chronic (George et al. 2002; NTP 1987) oral exposure.
- Immunological effects
  ○ Very low evidence in an epidemiological study that evaluated immune markers in subjects swimming in chlorinated water for 40 minutes (Vlaanderen et al. 2017). No data are available on whether inhalation, oral, or dermal exposure to bromodichloromethane impairs immune function.
  ○ Moderate evidence in animal studies based on two studies that found altered responses to immune stimulants after acute gavage administration (French et al. 1999; Munson et al. 1982) or intermediate oral exposure in rats (French et al. 1999).

Not Classifiable Effects

- Reproductive effects
  ○ Inadequate evidence in cohort and cross-sectional studies that examined sperm parameters (Zeng et al. 2013), menstrual cycle (Windham et al. 2003), and time to pregnancy (MacLehose et al. 2008).
  ○ Low evidence in animal studies (Aida et al. 1992; Bielmeier et al. 2001, 2004, 2007; Christian et al. 2001b; Klinefelter et al. 1995; NTP 1987, 2006; Ruddick et al. 1983). Studies evaluating the histopathology of the reproductive system have not found alterations at nonlethal doses (Aida et al. 1992; NTP 1987, 2006). Bielmeier et al. (2001, 2004, 2007) reported significant alterations in reproductive hormone levels in pregnant rats, and Klinefelter et al. (1995) reported decreases in sperm velocity, but no changes in sperm motility. No alterations in reproductive function were observed in a 2-generation study in rats (Christian et al. 2001b). The lack of consistency across studies and the indirectness of the observed effects decreased the initial confidence in these studies.

Table C-19 Hazard Identification Conclusions for Bromodichloromethane

Outcome | Hazard identification
Hepatic effects | Presumed health effect
Renal effects | Suspected health effect
Immunological effects | Suspected health effect
Reproductive effects | Not classifiable
Developmental effects | Presumed health effect