# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Human Health Sciences, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Division of Toxicology and Human Health Sciences, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S102-1, Atlanta, Georgia 30329-4027.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Bromodichloromethane
CAS Numbers: | 75-27-4
Date: | March 2020
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL.

Rationale for Not Deriving an MRL: The acute-duration inhalation database was not considered suitable for derivation of an MRL due to several data gaps: lack of examination of the respiratory tract, lack of incidence data in the only available inhalation study, and lack of developmental toxicity studies.

There are limited data on the acute inhalation toxicity of bromodichloromethane. Torti et al. (2001) reported hepatic, renal, body weight, and ocular effects in two strains of mice exposed to bromodichloromethane vapor 6 hours/day, 7 days/week for 1 week. The kidney was the most sensitive target, with tubular degeneration and nephrosis observed at ≥10 ppm; the NOAEL was 1 ppm. At 30 ppm, hepatocellular centrilobular degeneration and decreases in body weight gain were observed. Increases in mortality were observed at ≥30 ppm; the cause of death was not reported, but the investigators noted that animals exposed to 100 and 150 ppm were lethargic with labored breathing. There are several methodological and reporting deficiencies in the Torti et al. (2001) study that limit its usefulness for deriving an MRL. One limitation is the lack of examination of the respiratory tract, which could be a sensitive target of toxicity. Mild eye irritation was noted at 30 ppm, so it is possible that bromodichloromethane also resulted in respiratory tract irritation. Another limitation is the lack of reporting of incidence data for the liver and kidney lesions; only a description of the lesions was provided. Thus, there is some uncertainty in identifying NOAEL and LOAEL values for the study.

Acute-duration oral studies have found developmental toxicity to be a more sensitive target of toxicity than the kidney or liver. For example, increases in the incidence of full-litter resorptions were observed in rats administered ≥50 mg/kg/day during gestation (Narotsky et al. 1997); the lowest LOAEL for kidney effects in rats was 150 mg/kg/day with a NOAEL of 75 mg/kg/day (Thornton-Manning et al. 1994) and the lowest LOAEL for liver effects was 74 mg/kg/day with a NOAEL of 37 mg/kg/day (Condie et al. 1983). Although the causative agent (bromodichloromethane or a metabolite) of the litter resorptions is not known, there are no data to suggest that developmental effects will not be a sensitive endpoint following inhalation exposure.

Agency Contacts (Chemical Managers): Susan Ingber

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Bromodichloromethane
CAS Numbers: | 75-27-4
Date: | March 2020
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL.

Rationale for Not Deriving an MRL: The intermediate-duration inhalation database was not considered suitable for derivation of an MRL due to several data gaps: lack of incidence data for histological alterations, lack of examination of the respiratory tract, and relatively short duration of the only available intermediate-duration study (Torti et al. 2001), as well as the lack of developmental toxicity studies.

The intermediate-duration inhalation database for bromodichloromethane is limited to several mouse studies conducted by Torti et al. (2001). In two strains of mice, renal tubular degeneration was observed following exposure to 10 or 30 ppm 6 hours/day, 7 days/week for 3 weeks; the NOAEL was 3 ppm. No hepatic, body weight, or urinary bladder effects were observed in these studies at the highest concentration of 30 ppm. Minimal centrilobular hepatocellular degeneration was observed at 10 and 30 ppm in p53 heterogenous mouse strains (Torti et al. 2001). The kidney and liver lesions observed in the mice were described; however, no incidence data were provided Torti et al. (2001). Thus, there is some uncertainty in identifying NOAEL and LOAEL values for the study. Torti et al. (2001) also exposed the heterogenous mouse strains to ≤15 ppm bromodichloromethane for 13 weeks. The investigators noted minimal cortical scarring and tubular karyocytomegaly in the kidneys, but did not provide any additional information that would allow for identification of a LOAEL; no other effects were noted. This study in transgenic mice was not considered a suitable basis for an MRL. The Torti et al. (2001) studies did not include an examination of the respiratory tract; results from the acute-duration inhalation study by these investigators provide suggestive evidence (labored breathing at lethal concentrations and eye irritation at 30 ppm) that bromodichloromethane exposure may affect the respiratory tract. Intermediate and chronic oral studies (NTP 1987) also provide suggestive evidence that the renal toxicity of bromodichloromethane increases with exposure duration. Thus, a 3-week study may not be suitable for establishing an MRL for continuous exposure for up to 1 year.

Liver, kidney, immunological, neurological, and developmental effects have been observed in intermediate-duration oral studies (Aida et al. 1989, 1992; Balster and Borzelleca 1982; Christian et al. 2001a; French et al. 1999; NTP 1987). The available data suggest that the liver may be the most sensitive effect for oral exposure; however, based on the Torti et al. (2001) inhalation study, the kidney may be more sensitive than the liver following inhalation exposure. The LOAELs for kidney (71 mg/kg/day), immunological (49 mg/kg/day), and developmental (82 mg/kg/day) effects identified in intermediate-duration oral studies are similar. However, immunological and developmental toxicity have not been assessed in inhalation studies. Given these data gaps, there is considerable uncertainty in establishing an intermediate-duration inhalation MRL for bromodichloromethane at this time.

Agency Contacts (Chemical Managers): Susan Ingber

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Bromodichloromethane
CAS Numbers: | 75-27-4
Date: | March 2020
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL.

Rationale for Not Deriving an MRL: No chronic-duration inhalation studies were identified.

Agency Contacts (Chemical Managers): Susan Ingber

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Bromodichloromethane
CAS Numbers: | 75-27-4
Date: | March 2020
Profile Status: | Final
Route: | Oral
Duration: | Acute
MRL | 0.0_7_ mg/kg/day
Critical Effect: | Full-litter resorption
Reference: | Narotsky et al. 1997
Point of Departure: | BMDL_05_ of 7.15 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 15
Species: | Rat

MRL Summary: An acute-duration oral MRL of 0.0_7_ mg/kg/day was derived for bromodichloromethane based on an increased incidence of full-litter resorptions in rats administered bromodichloromethane via gavage on GDs 6–15 (Narotsky et al. 1997). The MRL is based on a BMDL_05_ of 7.15 mg/kg/day and a total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

Selection of the Critical Effect: A number of studies have evaluated the toxicity of bromodichloromethane following acute, oral exposure; these studies examine a wide range of potential endpoints including liver and kidney effects (Condie et al. 1983; Keegan et al. 1998; Lilly et al. 1994, 1996; Munson et al. 1982; Ruddick et al. 1983; Thornton-Manning et al. 1994), immunotoxicity (French et al. 1999), reproductive toxicity (Bielmeier et al. 2001), and developmental toxicity (Bielmeier et al. 2001, 2004; Narotsky et al. 1997; Ruddick et al. 1983). The LOAELs for these studies range from 50 to 400 mg/kg/day; a summary of select LOAELs is presented in Table A-1 (studies identifying LOAELs for body weight effects were not included since this is not considered a primary effect of bromodichloromethane).

The available data suggest that developmental toxicity, particularly full-litter resorption, is the most sensitive endpoint following acute-duration oral exposure. In multiple studies conducted by Bielmeier et al. (2001) and Narotsky et al. (1997), full-litter resorptions have been observed at 50 mg/kg/day (8–17% resorptions) and ≥75 mg/kg/day (17–100% resorptions). Similar LOAELs (≥74–75 mg/kg/day) were identified for liver and immunological effects. The liver effects consisted of centrilobular pallor, vacuolar degeneration and necrosis, and increases in liver enzymes (Condie et al. 1983; Keegan et al. 1998; Lilly et al. 1994, 1996; Munson et al. 1982; Thornton-Manning et al. 1994). Two studies demonstrated impaired immune responses in rats and mice administered ≥75 mg/kg/day (French et al. 1999; Munson et al. 1982). The kidney appears to be slightly less sensitive than other targets, with LOAEL values ranging from 148 to 400 mg/kg/day. The effects included tubular degeneration, hyperplasia, and necrosis, and increases in blood urea nitrogen levels (Condie et al. 1983; Lilly et al. 1994, 1996; Munson et al. 1982; Thornton-Manning et al. 1994).

Table A-1 Summary of Relevant LOAEL Values Following Acute Oral Exposure to Bromodichloromethane

Species | Duration/route | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Developmental effects
F344 rat | GDs 6–15 (GW) | 25 | 50 | 17% full-litter resorption | Narotsky et al. 1997
F344 rat | GDs 6–15 (GO) | 25 | 50 | 8% full-litter resorption | Narotsky et al. 1997
F344 rat | GDs 6–10 (GW) | – | 75^a^ | 62% full-litter resorption | Bielmeier et al. 2001
F344 rat | GDs 8–9, or GD 0 (GW) | – | 75^a^ | 64% full-litter resorption | Bielmeier et al. 2001
F344 rat | GDs 6–10 or GDs 6–15 (GW) | – | 75^a^ | 75 or 50% full-litter resorption | Bielmeier et al. 2001
F344 rat | GDs 6–10 (GW) | – | 75^a^ | 80% full-litter resorption | Bielmeier et al. 2004
Sprague-Dawley rat | GDs 6–10 (GW) | 100 | | 0% full-litter resorption | Bielmeier et al. 2001
Sprague-Dawley rat | GDs 6–15 (GO) | 100 | 200 | Delayed ossification of sternebrae | Ruddick et al. 1983
Kidney effects
CD-1 mouse | 14 days (GO) | 74 | 148 | Intratubular mineralization, epithelial hyperplasia, and cytomegaly | Condie et al. 1983
Fischer 344 rat | 5 days (GW) | 75 | 150 | Tubular vacuolar degeneration | Thornton-Manning et al. 1994
Fischer 344 rat | Once (GW) | | 200 | Proximal tubule necrosis | Lilly et al. 1996
CD-1 mouse | 14 days (GW) | 125 | 250 | Increased blood urea nitrogen levels | Munson et al. 1982
Fischer 344 rat | Once (GW) or (GO) | 200 | 400 | Renal tubule degeneration and necrosis | Lilly et al. 1994
Liver effects
CD-1 mouse | 14 days (GO) | 37 | 74 | Centrilobular pallor | Condie et al. 1983
Fischer 344 rat | 5 days (GW) | 75 | 150 | Hepatocellular vacuolar degeneration | Thornton-Manning et al. 1994
Fisher 344 rat | Once (G) | 163.8 | 245.7 | Increases in alanine aminotransferase, aspartate aminotransferase, and sorbitol dehydrogenase | Keegan et al. 1998
CD-1 mouse | 14 days (GW) | 125 | 250 | Aspartate aminotransferase and alanine aminotransferase levels | Munson et al. 1982
Fischer 344 rat | Once (GW) or (GO) | 200 | 400 | Vacuolar degeneration and necrosis | Lilly et al. 1994
Fischer 344 rat | Once (GW) | 200 | 400 | Centrilobular necrosis and vacuolar degeneration | Lilly et al. 1996
Immunological effects
F344 rat | 5 days (GW) | – | 75 | Impaired response to T-lymphocyte stimulants | French et al. 1999
CD-1 mouse | 14 days (GW) | 125 | 250 | Altered response to sheep red blood cells | Munson et al. 1982

a Considered a serious LOAEL.

G = gavage; GD = gestation day; GO = gavage in oil vehicle; GW = gavage in water vehicle; LOAEL = lowest observed adverse effect level; NOAEL = no-observed-adverse-effect level

The lowest LOAEL for an acute-duration study was 50 mg/kg/day for full-litter resorptions in rats (Narotsky et al. 1997) and this was selected as the critical effect for the MRL. Although the Narotsky et al. (1997) and Bielmeier et al. (2001) studies have consistently shown an increase in pregnancy loss in F344 rats administered bromodichloromethane via gavage on GDs 6–10, other studies have not found this effect in Sprague-Dawley rats or in rabbits. No pregnancy losses were observed in Sprague-Dawley rats administered gavage doses as high as 100 mg/kg/day on GDs 6–10 (Bielmeier et al. 2001) or 200 mg/kg/day on GDs 6–15 (Ruddick et al. 1983), exposed via drinking water to 82.0 mg/kg/day on GDs 6–21 (Christian et al. 2001a), or exposed in drinking water to 29.5–109 mg/kg/day in a 2-generation study (Christian et al. 2001b). Additionally, no pregnancy losses were observed in New Zealand white rabbits exposed to doses as high as 55.3 mg/kg/day on GDs 6–29 (Christian et al. 2001a). Support for the applicability of the pregnancy loss effect for derivation of an MRL comes from human studies that found significant associations between bromodichloromethane in tap water and an increased risk of spontaneous abortion (Waller et al. 1998) or stillbirths (King et al. 2000); it is noted that these studies involved exposure to multiple disinfection byproducts, including other trihalomethanes.

Selection of the Principal Study: As summarized in Table A-1, Bielmeier et al. (2001) and Narotsky et al. (1997) conducted several studies evaluating full-litter resorptions in rats. Together, the studies demonstrate a dose-response relationship between bromodichloromethane exposure and full-litter resorption. The incidence of full-litter resorptions in selected studies conducted by these investigators are presented in Table A-2. Since the Narotsky et al. (1997) studies tested lower concentrations and identified a NOAEL, it was selected as the principal study for the MRL.

Table A-2 Incidence of Full-Litter Resorptions in F344 Rats Administered Bromodichloromethane via Gavage

| Dose (mg/kg/day)
| 0 | 25 | 50 | 75 | 100
Narotsky et al. 1997 (GW) | 0/14 (0%) | 0/12 (0%) | 2/12 (17%) | 3/14 (21%)
Narotsky et al. 1997 (GO) | 0/12 (0%) | 0/14 (0%) | 1/13 (8%) | 10/12 (83%)
Bielmeier et al. 2001 (GDs 6–15) | 0% | | | 50%
Bielmeier et al. 2001 (GDs 9) | 0% | | | 64% | 100%

G = gavage; GD = gestation day; GO = gavage in oil vehicle; GW = gavage in water vehicle

Summary of the Principal Study:

Narotsky MG, Pegram RA, Kavlock RJ. 1997. Effect of dosing vehicle on the developmental toxicity of bromodichloromethane and carbon tetrachloride in rats. Fundam Appl Toxicol 40:30–36.

Groups of pregnant F344 rats (12–14/group) were administered 0, 25, 50, or 75 mg /kg/day bromodichloromethane by gavage in corn oil or an aqueous vehicle on GDs 6–15. Endpoints monitored included maternal weight and clinical signs. Pups were examined and weighed individually on PNDs 1 and 6. Dams were killed on PND 6, and the number of uterine implantations were recorded. The uteri of rats that did not deliver were stained to detect cases of full-litter resorptions.

Clinical signs seen only in the corn oil vehicle rats included hunched back (75 mg/kg/day) and chromodacryorrhea/lacrimation (≥50 mg/kg/day). Piloerection occurred at 75 mg/kg/day with both vehicles and at 50 mg/kg/day with the aqueous vehicle. Body weight gain on GDs 6–8 was reduced about 83% in rats dosed with 25 mg/kg/day in aqueous vehicle and about 61% with the oil vehicle (statistically significant only in aqueous vehicle group). Rats in the higher dose groups lost weight (both vehicles). Body weight gains were not reported at other time periods. Full-litter resorptions occurred in 50 and 75 mg/kg/day groups for both vehicles, but were not observed in controls or 25 mg/kg/day groups. The incidences of full-litter resorption are presented in Table A-2. In surviving litters, there was no significant effect on gestation length, postnatal viability, or pup weight on PND 1 or 6. In a toxicokinetic study also conducted, bromodichloromethane levels in the blood declined faster in aqueous vehicle groups than in corn oil vehicle groups; the blood half-times were 2.7 and 3.6 hours, respectively.

Selection of the Point of Departure: The BMDL_05_ of 7.15 mg/kg/day for full-litter resorption was selected as the basis of the MRL.

Benchmark dose (BMD) modeling was conducted to identify a point of departure using the incidence data for full-litter resorptions in rats administered bromodichloromethane in an aqueous vehicle. The oil vehicle data were not modeled since administration in an aqueous vehicle is most likely to mimic human exposure to bromodichloromethane in water. The data were fit to all available dichotomous models in EPA’s Benchmark Dose Software (BMDS, version 3.1.1) using the extra risk option. Adequate model fit was judged by three criteria: goodness-of-fit statistics (p-value >0.1), visual inspection of the dose-response curve, and scaled residual at the data point (except the control) closest to the predefined benchmark response (BMR). Among all of the models providing adequate fit to the data, the lowest BMDL (95% lower confidence limit on the benchmark concentration) was selected as the point of departure when the difference between the BMDLs estimated from these models was >3-fold; otherwise, the BMDL from the model with the lowest Akaike’s Information Criterion (AIC) was chosen. Since the endpoint was developmental toxicity, a BMR of 5% was used. The model predictions for the gavage in aqueous solution are presented in Table A-3 and the fit of the selected model is presented in Figure A-1.

A BMDL_05_ value of 7.15 mg/kg/day was calculated using the incidence data for rats administered bromodichloromethane via gavage in aqueous solution. Although the BMDL_05_ of 7.15 mg/kg/day was lower than the empirical NOAEL of 25 mg/kg/day identified in the study, it was selected as the point of departure because it provides a better indicator of the dose-response relationship than the NOAEL, which is a single data point.

Table A-3 Model Predictions for Full-Litter Resorptions in Rats Orally Administered Bromodichloromethane in an Aqueous Vehicle (Narotsky et al. 1997)

Model | DF | χ^2^ | χ2 Goodness-of-fit p-value^a^ | Scaled residuals^b^ | | | AIC | BMD_05_ (mg/kg/day) | BMDL_05_ (mg/kg/day)
Model | DF | χ^2^ | χ2 Goodness-of-fit p-value^a^ | Dose below BMD | Dose above BMD | Overall largest | AIC | BMD_05_ (mg/kg/day) | BMDL_05_ (mg/kg/day)
Gamma^c^ | 2 | 0.77 | 0.68 | −0.48 | 0.67 | 0.67 | 32.30 | 36.34 | 10.61
Logistic | 2 | 1.49 | 0.47 | −0.57 | 0.98 | 0.98 | 31.10 | 41.00 | 25.03
LogLogistic^d^ | 2 | 0.77 | 0.68 | −0.52 | 0.66 | 0.66 | 30.34 | 35.59 | 9.60
LogProbit^d^ | 1 | 5.70 | 0.02 | −1.22 | −1.13 | 1.50 | 38.92 | ND | ND
Multistage (1-degree)^e^ | 2 | 1.06 | 0.59 | 0.00 | −0.93 | −0.93 | 31.22 | 18.28 | 9.48
Multistage (2-degree) ^e^ | 3 | 0.75 | 0.86 | -0.60 | 0.60 | 0.60 | 28.43 | 32.80 | 10.43
Multistage (3-degree)^e^ | 2 | 0.77 | 0.68 | −0.59 | 0.61 | 0.61 | 32.43 | 33.22 | 10.43
Probit | 2 | 1.27 | 0.53 | −0.53 | 0.90 | 0.90 | 30.81 | 39.58 | 23.38
Dichotomous Hill ^f^ | 1 | 0.00 | 0.99 | -0.00 | 0.00 | 0.00 | 31.36 | 43.66 | 7.15
Weibull^c^ | 2 | 0.82 | 0.67 | −0.54 | 0.68 | 0.68 | 30.40 | 35.31 | 10.47

a Values <0.1 fail to meet conventional goodness-of-fit criteria.

b Scaled residuals at doses immediately below and above the BMD; also the largest residual at any dose.

c Power restricted to ≥1.

d Slope restricted to ≥1.

e Betas restricted to ≥0.

f Selected model. BMDLs for models providing adequate fit were sufficiently close (differed by <3-fold), so the model with the lowest AIC was selected (Dichotomous Hill).

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure concentration associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _050_ = exposure concentration associated with 5% extra risk); DF = degrees of freedom; ND = not determined, goodness-of-fit p-value <0.1

Figure A-1 Fit of Dichotomous Hill Model to Data on Incidence of Full-Litter Resorption in Rats Administered Bromodichloromethane in Aqueous Vehicle

Figure A-1 description

Adjustment for Intermittent Exposure: Not applicable.

Uncertainty Factor: The BMDL_05_ is divided by a total uncertainty factor of 100

- 10 for extrapolation from animals to humans
- 10 for human variability

- MRL = BMDL_05_ ÷ UFs
  - 7.15 mg/kg/day ÷ (10 × 10) = 0.07 mg/kg/day

Other Additional Studies or Pertinent Information: EPA (2005b) estimated that the average exposure of the general population to bromodichloromethane is 20 μg/person/day (0.0003 mg/kg/day assuming a reference body weight of 70 kg) from surface water systems and 8.1 μg/person/day (0.0001 mg/kg/day) from groundwater systems. These average intakes are approximately 1,000-fold lower than the MRL.

Agency Contacts (Chemical Managers): Susan Ingber

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Bromodichloromethane
CAS Numbers: | 75-27-4
Date: | March 2020
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: The available intermediate oral data were not considered adequate for derivation of an intermediate-duration oral MRL. However, the chronic MRL of 0.008 mg/kg/day was considered protective for intermediate-duration exposure.

Rationale for Not Deriving an MRL: Intermediate-duration studies have evaluated a wide range of possible targets of bromodichloromethane toxicity. Studies conducted by Aida et al. (1989, 1992) and NTP (1987, 2006) have included histopathological examination of most major tissues; the Aida et al. (1989, 1992) studies also included examination of hematological and serum clinical chemistry parameters. In addition, other studies have evaluated potential targets in the immune system (French et al. 1999), neurological system (Balster and Borzelleca 1982; Moser et al. 2007), reproductive system (Christian et al. 2001b), and developmental toxicity (Christian et al. 2001a, 2001b). These studies have identified LOAEL values for liver, kidney, immune, neurobehavioral, and developmental effects; the LOAELs for these effects are summarized in Table A-4. Based on these LOAELs, the liver appears to be the most sensitive target of toxicity. The observed effects include alterations in serum enzymes (alanine aminotransferase and aspartate aminotransferase), hepatocellular vacuolization, swelling, fatty degeneration, and necrosis in rats (Aida et al. 1989, 1992; Hooth et al. 2002; NTP 1987) and mice (NTP 1987) administered bromodichloromethane via gavage, drinking water, or feed for 1–6 months. The lowest LOAEL was 6.1 mg/kg/day in rats exposed for 6 months (Aida et al. 1992).

The lowest LOAEL for other effects range from 49 mg/kg/day for immunological effects to 100 mg/kg/day for neurobehavioral effects. The data supporting these other endpoints are not as strong as for liver effects, and there are some inconsistencies in the results depending on the endpoint examined. The immunological effect observed at 49 mg/kg/day is a decreased response by splenic lymphocytes to concanavalin A in rats exposed to bromodichloromethane in drinking water for 26 weeks (French et al. 1999). The study did not find an altered response to another T-cell mitogen (phytohemagglutinin-p) or a significant response to Salmonella stimulation to B-lymphocytes. Acute exposure studies at higher doses (≥75 mg/kg/day) have found more consistent responses to T-lymphocyte mitogens (French et al. 1999) and sheep red blood cells (Munson et al. 1982). The renal effects observed in 13-week gavage studies (NTP 1987) included proximal tubule epithelial cell degeneration in rats at 214 mg/kg/day and proximal tubular necrosis in mice at ≥71 mg/kg/day. Other intermediate-duration studies in rats have not reported renal effects; however, the doses tested were lower than the NTP (1987) study (Aida et al. 1989, 1992; Chu et al. 1982; Lipsky et al. 1993; Lock et al. 2004; NTP 2006). The results of acute (Lilly et al. 1994, 1996; Thornton-Mannin et al. 1994) and chronic (George et al. 2002; NTP 1987) studies support the identification of the kidney as a sensitive target of toxicity. Christian et al. (2001a) reported minor delays in skeletal ossification in the offspring of rats exposed to 82 mg/kg/day in drinking water on GDs 6–21. This was not found in a 2-generation study utilizing similar dose levels (Christian et al. 2001b). The last effect that has been observed following intermediate exposure is impaired learning in an operant behavior test in mice receiving gavage administration of 100 mg/kg/day for 60 days (Balster and Borzelleca 1982). Balster and Borzelleca (1982) conducted several neurobehavioral studies and found negative results in the passive avoidance learning test at 100 mg/kg/day (30-day exposure) and in tests of motor performance and exploratory behavior at 11.6 mg/kg/day (90-day exposure). Moser et al. (2007) also found no alterations in performance on functional battery tests in rats exposed to 71.7 mg/kg/day for 6 months.

Table A-4 Summary of Relevant LOAEL Values Following Intermediate-Duration Oral to Bromodichloromethane

Species | Duration (route) | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Liver effects
Wistar rats | 6 months (F) | − | 6.1 | Hepatocellular fatty degeneration (males only) | Aida et al. 1992
Eker rats | 4 or 10 months (W) | 3.5 | 35 | Centrilobular swelling | Hooth et al. 2002
Wistar rats | 1 month (GO) | 20 | 60 | Hepatocellular vacuolization | Aida et al. 1989
Wistar rats | 1 month (F) | 60 | 180 | Hepatocellular vacuolization, swelling, and necrosis | Aida et al. 1989
B6C3F1 mice | 13 weeks (GO) | 71^a^ | 142^a^ | Enlarged centrilobular hepatocytes and vacuolization (females only) | NTP 1987
F344 rats | 13 weeks (GO) | 107^a^ | 214^a^ | Centrilobular degeneration, mild bile duct hyperplasia | NTP 1987
Immunological effects
F344 rats | 26 weeks (GW) | 5 | 49 | Decreased response to mitogen in splenic lymphocytes | French et al. 1999
Kidney effects
B6C3F1 mice | 13 weeks (GO) | 36^a^ | 71^a^ | Proximal tubular epithelial cell focal necrosis (males only) | NTP 1987
F344 rats | 13 weeks (GO) | 107^a^ | 214^a^ | Proximal tubular epithelial cell degeneration | NTP 1987
Developmental effects
Sprague-Dawley rats | GDs 6–21 (W) | 45 | 82 | Minor delays in ossification | Christian et al. 2001a
Neurobehavioral effects
ICR mice | 60 days (GW) | | 100 | Alterations in operant behavior | Balster and Borzelleca 1982

a Adjusted for intermittent exposure (5 days/7 days).

F = feed; GD = gestation day; GO = gavage in oil; GW = gavage in water; LOAEL = lowest observed adverse effect level; NOAEL = no observed-adverse-effect level; W = water

Based on the available data, the liver appears to be the most sensitive target of bromodichloromethane intermediate-duration toxicity.

Nine studies have investigated the potential of bromodichloromethane to induce liver effects in laboratory animals (Aida et al. 1989, 1992; Chu et al. 1982; Hooth et al. 2002; NTP 1987, 2006); the results of these studies are summarized in Table A-5. Comparisons of NOAEL/LOAEL values across studies show a considerable amount of overlap, which likely results from differences in exposure routes and vehicles that could influence absorption, metabolism, and delivery of the compound to target organs; strain differences and exposure duration may have also influenced the results. A 1-month study by Aida et al. (1989) allows for a comparison of the effect levels between gavage with oil vehicle and feed exposure. The NOAEL and LOAEL values were 20 and 60 mg/kg/day, respectively, for hepatocellular vacuolization in rats administered bromodichloromethane via gavage in olive oil. In contrast, the NOAEL and LOAEL values for feed administration were 60 and 180 mg/kg/day for hepatocellular vacuolization, swelling, and necrosis. These results suggest that gavage administration is a more toxic exposure route than feed. In a PBPK modeling study conducted by NTP (2006), the plasma AUCs were lower for drinking water exposure than gavage in oil exposure. The study also found that a higher percentage of bromodichloromethane was metabolized by cytochrome P450 than by glutathione transferase.

A comparison between the results of the Aida et al. (1989) gavage study and the NTP (1987) 3-month gavage studies suggest that Wistar rats may be more sensitive than F344 rats based on the NOAEL of 197 mg/kg/day for F344 rats, which is higher than the LOAEL of 60 mg/kg/day in Wistar rats; a toxicokinetic basis for this difference has not been established. Studies conducted by Aida and associates also demonstrate an increasing toxicity with exposure duration. After 6 months of exposure to bromodichloromethane in the feed, hepatocellular degeneration was observed at 6.1 mg/kg/day; in contrast, the NOAEL for the 1-month feed study was 60 mg/kg/day.

Although gavage administration may be a more toxic route of exposure, continuous exposure laboratory animal studies (administration in feed or drinking water) are likely more representative of general population exposure to bromodichloromethane in tap water. Of the drinking water and feed studies, Aida et al. (1992) identified the lowest LOAEL of 6.1 mg/kg/day. Derivation of an intermediate-duration oral MRL based on the Aida et al. (1992) study was considered using the NOAEL/LOAEL approach; the fatty degeneration incidence data were not suitable for BMD modeling because the maximal response (100%) was observed at all non-control dose levels in the males. Using the LOAEL as the point of departure for the MRL and an uncertainty factor of 1,000 (10 for extrapolation from a LOAEL, 10 for extrapolation from animal studies, and 10 for human variability) would result in an MRL of 0.006 mg/kg/day. This MRL is lower than the chronic-duration MRL also based on hepatic fatty degeneration in rats exposed to bromodichloromethane for 2 years (Aida et al. 1992). The intermediate and chronic studies identified the same LOAEL values; however, there was greater confidence in the chronic MRL because a larger number of animals were examined at 24 months (13–19/exposure group compared to 5/exposure group in the 6-month study) and the chronic data allowed for use of BMD modeling.

Table A-5 Summary of Hepatic Effects Following Intermediate-Duration Oral to Bromodichloromethane

Species | Duration | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Feed administration
Wistar rats | 6 months | – | 6.1 | Hepatocellular fatty degeneration (males only) | Aida et al. 1992
Wistar rats | 1 month | 60 | 180 | Hepatocellular vacuolization, swelling, and necrosis | Aida et al. 1989
Gavage (oil vehicle) administration
Wistar rats | 1 month | 20 | 60 | Hepatocellular vacuolization | Aida et al. 1989
B6C3F1 mice | 13 weeks | 71^a^ | 142^a^ | Enlarged centrilobular hepatocytes and vacuolization (females only) | NTP 1987
F344 rats | 13 weeks | 107^a^ | 214^a^ | Centrilobular degeneration, mild bile duct hyperplasia | NTP 1987
Drinking water administration
Eker rats | 4 or 10 months | 3.5 | 35 | Centrilobular swelling | Hooth et al. 2002
F344/N rats | 22 days | 71 | – | | NTP 2006
B6C3F1 mice | 22 days | 51 | – | | NTP 2006
Sprague-Dawley rats | 28 days | 45 | – | | Chu et al. 1982

a Adjusted for intermittent exposure (5 days/7 days).

LOAEL = lowest observed adverse effect level; NOAEL = no observed-adverse-effect level

Agency Contacts (Chemical Managers): Susan Ingber

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Bromodichloromethane
CAS Numbers: | 75-27-4
Date: | March 2020
Profile Status: | Final
Route: | Oral
Duration: | Chronic
MRL | 0.008 mg/kg/day
Critical Effect: | Hepatocellular fatty degeneration
Reference: | Aida et al. 1992
Point of Departure: | BMDL_10_ of 0.78 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 51
Species: | Rat

MRL Summary: A chronic-duration oral MRL of 0.008 mg/kg/day was derived for bromodichloromethane based on an increased incidence of hepatocellular fatty degeneration in male rats exposed to bromodichloromethane in the diet for 24 months (Aida et al. 1992). The MRL is based on a BMDL_10_ of 0.78 mg/kg/day and a total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

Selection of the Critical Effect: A number of studies have evaluated the possible association between exposure to bromodichloromethane and adverse health effects in humans; in particular, these studies evaluate potential hepatic, developmental, and reproductive endpoints. No significant associations between blood bromodichloromethane levels and aspartate aminotransferase levels were found in a study utilizing the NHANES database (Burch et al. 2015). Nine studies have examined whether bromodichloromethane in drinking water was associated with alterations in birth weight, congenital anomalies, or stillbirths. One study found a significant association for stillbirths (King et al. 2000). Mixed results were found for birth weight, birth length, or small for gestational age (SGA) (Cao et al. 2016; Danileviciute et al. 2012; Rivera-Núñez and Wright 2013; Summerhayes et al. 2012; Wright et al. 2004) and for the malformations, in particular neural tube defects, heart anomalies, and hypospadias (Dodds and King 2001; Grazuleviciene et al. 2013; Iszatt et al. 2011) with some studies finding significant associations. Of the three studies examining possible associations between bromodichloromethane and reproductive parameters, significant associations between bromodichloromethane in water and a shorter time to pregnancy (MacLehose et al. 2008) and a decreased menstrual cycle length (Windham et al. 2003) were found; no association was found between blood bromodichloromethane levels and sperm parameters (Zeng et al. 2013). Although some studies have found significant associations, the studies do not establish causality and bromodichloromethane levels in drinking water only accounted for a small portion of the risk of these effects.

Nine studies have evaluated the chronic toxicity of bromodichloromethane in rats and mice (Aida et al. 1992; George et al. 2002; Klinefelter et al. 1995; NTP 1987, 2006; Tumasonis et al. 1985). These studies have identified three sensitive targets of non-neoplastic toxicity: liver, kidney, and sperm; the LOAELs for these effects are presented in Table A-6. In the liver, the accumulation of fat resulted in hepatocellular degeneration in rats exposed to ≥ 6.1 mg/kg/day in the diet for 1–2 years (Aida et al. 1992) and fatty metamorphosis in rats and mice administered via gavage ≥36 mg/kg/day for 2 years (NTP 1987). A fourth study reported hepatic adenofibrosis in rats following a lifetime exposure to 190 mg/kg/day in drinking water (Tumasonis et al. 1985). Renal and sperm effects have also been observed at dose levels of 36–39 mg/kg/day (George et al. 2002; Klinefelter et al. 1995; NTP 1987). Although the results of the NTP (1987) rat and mice studies suggest that the liver and kidneys are equally sensitive to bromodichloromethane toxicity, the Aida et al. (1992) studies did not find kidney effects at doses as high as 138.0 mg/kg/day in males and 168.4 mg/kg/day in females. Bolus administration versus continuous exposure may have accounted for the differences between the studies. PBPK modeling conducted by NTP (2006) found an approximately 10-fold difference in maximal bromodichloromethane blood levels following administration of 50 mg/kg via gavage and 33 mg/kg via drinking water; likewise, the 24-hour AUC was 1.5 times higher following gavage. Given these possible differences, gavage administration may not be a relevant route of exposure for estimating an MRL for humans since the general population is primarily exposed to bromodichloromethane in tap water. Among the drinking water and feed studies, the lowest LOAEL was 6.1 mg/kg/day for liver effects; thus, fatty degeneration of the liver was selected as the critical effect for the chronic-duration oral MRL.

Table A-6 Summary of Relevant LOAEL Values Following Chronic-Duration Oral to Bromodichloromethane

Species | Duration | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Liver effects
Wistar rats | 1–2 years | – | 6.1 | Hepatocellular fatty degeneration and granulomas (males only) | Aida et al. 1992
F344 rats | 2 years | – | 36^a^ | Fatty metamorphosis | NTP 1987
B6C3F1 mice | 2 years | 18^a^ | 36^a^ | Fatty metamorphosis (males only) | NTP 1987
Wistar rats | Lifetime | – | 190 | Hepatic adenofibrosis (females only) | Tumasonis et al. 1985
Kidney effects
F344 rats | 2 years | 20 | 36.3 | Renal tubular cell hyperplasia | George et al. 2002
F344 rats | 2 years | | 36^a^ | Tubular epithelial cell cytomegaly (males only) | NTP 1987
B6C3F1 mice | | 18^a^ | 36^a^ | Tubular epithelial cell cytomegaly (males only) | NTP 1987
Reproductive effects
F344 rats | 1 year | 22 | 39 | Decreased sperm velocity | Klinefelter et al. 1995

a Adjusted for intermittent exposure (5 days/7 days).

LOAEL = lowest observed adverse effect level; NOAEL = no observed-adverse-effect level

Selection of the Principal Study: The hepatotoxicity of bromodichloromethane has been investigated in eight studies of rats or mice administered the compound via gavage (NTP 1987), feed (Aida et al. 1992), or drinking water (George et al. 2002; NTP 2006; Tumasonis et al. 1985); the results of these studies are presented in Table A-7. Four studies have identified LOAEL values in rats or mice for damage associated with fat accumulation (Aida et al. 1992; NTP 1987) or for adenofibrosis (Tumasonis et al. 1985). The lowest LOAEL was 6.1 mg/kg/day identified by Aida et al. (1992); this study was selected as the principal study for the MRL.

Table A-7 Summary of Hepatic Effects Following Chronic-Duration Oral to Bromodichloromethane

Species | Duration | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Feed administration
Wistar rats | 1–2 years | – | 6.1 | Fatty degeneration | Aida et al. 1992
Gavage (oil vehicle) administration
F344 rats | | – | 36^a^ | Fatty metamorphosis | NTP 1987
B6C3F1 mice | 2 years | 18^a^ | 36^a^ | Fatty metamorphosis | NTP 1987
Drinking water administration
Wistar rats | Lifetime | – | 190 | Hepatic adenofibrosis | Tumasonis et al. 1985
B6C3F1 mice | 2 years | 43.3 | | | George et al. 2002
F344 rats | 2 years | 36.3 | | | George et al. 2002
B6C3F1 mice | 2 years | 36 | – | | NTP 2006
F344/N rats | 2 years | 25 | – | | NTP 2006

a Adjusted for intermittent exposure (5 days/7 days).

LOAEL = lowest observed adverse effect level; NOAEL = no observed-adverse-effect level

Summary of the Principal Study:

Aida Y, Yasuhara K, Takada K, . 1992. Chronic toxicity of microencapsulated bromodichloromethane administered in the diet to Wistar rats. J Toxicol Sci 17:51–68.1507274

Groups of 40 male and 40 female Wistar rats were exposed to 0.014, 0.055, or 0.22% bromodichloromethane microencapsulated in the diet for up to 2 years; a control group of 70 male and 70 female rats was exposed to placebo granules added to the diet at the same concentration as the high-dose group. The investigators estimated the doses to be 6.1, 25.5, and 138.0 mg/kg/day for males and 8.0, 31.7, and 168.4 mg/kg/day for females. The following parameters were used to assess toxicity: daily observations, body weights (measured weekly for 6 months, biweekly during months 6–12, and monthly for the last year of the study), food intake (measured at the same frequency as body weight), hematology indices (erythrocyte count, hemoglobin, hematocrit, mean corpuscular volume, mean corpuscular hemoglobin, mean corpuscular hemoglobin concentration, and platelet and leukocyte counts), clinical chemistry indices (urea nitrogen, creatinine, glucose, triglycerides, cholinesterase, alanine aminotransferase, aspartate aminotransferase, gamma-glutamyl transpeptidase), liver and kidney weights, histopathological examination of major tissues and organs, and staining of liver sections for the detection of mucous substances in the bile ducts. Histopathological examination was also conducted in animals sacrificed after 12 (9/sex for controls and 5/sex/bromodichloromethane group) and 18 (9/sex for controls and 5/sex/bromodichloromethane group) months of exposure.

No dose-related alterations in mortality were observed. Mild piloerection and emaciation were observed in the 138.0/168.4 mg/kg/day group; the symptoms were first observed after 1 month of exposure and persisted throughout the study. No significant alterations in food intake were observed. Significant decreases in body weights were observed in the 138.0/168.4 mg/kg/day group after 12 and 18 months of exposure; males weighed 25 and 23% less than controls and females weighed 31 and 39% of controls. Increases in absolute and relative liver weights were observed in all exposed groups at 12 months and in the two highest groups after 18 months of exposure. Increases in relative kidney weights were observed in the 138.0/168.4 mg/kg/day group. No hematological alterations were observed. The following significant alterations in clinical chemistry parameters were observed after 12 months of exposure: increases in blood glucose levels in males only at 6.1 and 25.5 mg/kg/day; increased creatinine in females only at 168.4 mg/kg/day; increased gamma glutamyl transpeptidase at 138.0/168.4 mg/kg/day; decreased triglycerides in males at 6.1, 25.5, and 138.0 mg/kg/day and females at 168.4 mg/kg/day; decreased aspartate aminotransferase in males at 25.5 and 138.0 mg/kg/day and females at 168.4 mg/kg/day; decreased alanine aminotransferase at 8.0 (females only) and 138.0/168.4 mg/kg/day; and decreased cholinesterase in females at 31.7 and 168.4 mg/kg/day. After 18 months of exposure, the following alterations were observed: decreased blood glucose in females only at 168.4 mg/kg/day; decreased triglycerides at 25.5/31.7 and 138.0/168.4 mg/kg/day; decreased cholinesterase in males at 138.0 mg/kg/day and in females at 8.0, 31.7, and 168.4 mg/kg/day; slightly increased alanine aminotransferase in females 168.4 mg/kg/day; increased gamma-glutamyl transpeptidase at 31.7 mg/kg/days (females only) and 138.0/168.4 mg/kg/day; and increased blood urea nitrogen in females at 168.4 mg/kg/day. After 12 months of exposure, the following effects were observed in the liver: fatty degeneration in males at ≥6.1 mg/kg/day and in females at ≥31.7 mg/kg/day; bile duct proliferation in males at 138.0 mg/kg/day and in females at ≥31.7 mg/kg/day; cholangiofibrosis at 138.0/168.4 mg/kg/day; and granulomas in females at ≥31.7 mg/kg/day. After 18 months of exposure, the liver effects included: fatty degeneration in males at ≥6.1 mg/kg/day and in females at ≥31.7 mg/kg/day; cholangiofibrosis at 138.0/168.4 mg/kg/day; and granulomas at 31.7 (females only) and 138.9/168.4 mg/kg/day. After 24 months of exposure, liver effects included: fatty degeneration at ≥6.1 mg/kg/day; granulomas in males at ≥6.1 mg/kg/day and in females ≥31.7 mg/kg/day; and cholangiofibrosis at 138.0/168.4 mg/kg/day. The incidences of these lesions are presented in Table A-8. No other exposure-related increases in non-neoplastic lesions were observed. No increases in neoplastic lesions were observed; however, cholangiocarcinomas were observed in 3/40 females in the 168.4 mg/kg/day group, compared to 0/70 controls.

Table A-8 Incidences of Liver Lesions in Male and Female Rats Exposed to Bromodichloromethane in the Diet for 12, 18, or 24 Months (Aida et al. 1992)

| 12 months | | | | 18 months | | | | 24 months
| Doses (mg/kg/day) | | | | Doses (mg/kg/day) | | | | Doses (mg/kg/day)
Males | 0 | 6.1 | 25.5 | 138.0 | 0 | 6.1 | 25.5 | 138.0 | 0 | 6.1 | 25.5 | 138.0
Fatty degeneration | 0/9 | 5/5 | 5/5 | 5/5 | 1/9 | 3/5 | 5/5 | 5/5 | 0/24 | 5/14 | 12/13 | 19/19
Granuloma | 0/9 | 0/5 | 0/5 | 1/5 | 0/9 | 0/5 | 2/5 | 4/5 | 0/24 | 4/14 | 9/13 | 19/19
Bile duct proliferation | 1/9 | 1/5 | 0/5 | 5/5 | 9/9 | 5/5 | 5/5 | 5/5 | 24/24 | 13/14 | 13/13 | 19/19
Cholangiofibrosis | 0/9 | 0/5 | 0/5 | 5/5 | 0/9 | 0/5 | 0/5 | 3/5 | 0/24 | 0/14 | 0/13 | 4/19
Females | 0 | 8.0 | 31.7 | 168.4 | 0 | 8.0 | 31.7 | 168.4 | 0 | 8.0 | 31.7 | 168.4
Fatty degeneration | 0/9 | 0/5 | 5/5 | 4/5 | 0/9 | 1/5 | 5/5 | 5/5 | 2/32 | 8/19 | 18/18 | 18/18
Granuloma | 0/9 | 0/5 | 5/5 | 5/5 | 0/9 | 0/5 | 5/5 | 5/5 | 0/32 | 0/19 | 17/18 | 18/18
Bile duct proliferation | 0/9 | 0/5 | 3/5 | 5/5 | 6/9 | 2/5 | 4/5 | 5/5 | 28/32 | 16/19 | 17/18 | 18/18
Cholangiofibrosis | 0/9 | 0/5 | 0/5 | 5/5 | 0/9 | 0/5 | 0/5 | 4/5 | 0/32 | 0/19 | 0/18 | 12/18

Selection of the Point of Departure: The BMDL_10_ of 1.57 mg/kg/day for hepatocellular fatty degeneration in male rats was selected as the POD.

The Aida et al. (1992) study identifies a LOAEL of 6.1 mg/kg/day for fatty degeneration in male rats exposed to bromodichloromethane for 12, 18, or 24 months; a significant increase in the incidence of granulomas was also observed in males exposed to ≤6.1 mg/kg/day for 24 months. The lowest LOAELs in female rats were 31.7 mg/kg/day for fatty degeneration following exposure for 12 or 18 months and 8.0 mg/kg/day for fatty degeneration following exposure for 24 months. BMD modeling was conducted to identify a point of departure using the incidence data for fatty degeneration at 24 months; the 24-month data were selected over the 12- and 18-month data due to the large number of animals examined (13–19/sex at 25 months versus 5/sex at 12 and 18 months). The data were fit to some of the available dichotomous models in EPA’s BMDS (version 3.1.1) using the extra risk option. Adequate model fit was judged by three criteria: goodness-of-fit statistics (p-value >0.1), visual inspection of the dose-response curve, and scaled residual at the data point (except the control) closest to the predefined BMR. Among all of the models providing adequate fit to the data, the lowest BMDL was selected as the point of departure when the difference between the BMDLs estimated from these models was >3-fold; otherwise, the BMDL from the model with the lowest AIC was chosen. A BMR of 10% over the control incidence was used. The model predictions for males and females are presented in Table A-9 and the fit of the selected models are presented in Figures A-2 and A-3. The lowest BMDL_10_ values in the male and female rats were 0.78 for the first-degree Multistage model and 2.57 mg/kg/day for the Probit model; the BMDL_10_ for the males was selected as the point of departure for the MRL since it was lower than the female BMDL_10_.

Intermittent Exposure: Not applicable.

The BMDL_10_ is divided by a total uncertainty factor of 100

- 10 for extrapolation from animals to humans
- 10 for human variability

- MRL = BMDL_10_ ÷ UFs
  - 0.78 mg/kg/day ÷ (10 × 10) = 0.008 mg/kg/day

Other Additional Studies or Pertinent Information: EPA (2005b) estimated that the average exposure of the general population to bromodichloromethane is 20 μg/person/day (0.0003 mg/kg/day assuming a reference body weight of 70 kg) from surface water systems and 8.1 μg/person/day (0.0001 mg/kg/day) from groundwater systems. These average intakes are approximately 25-fold lower than the MRL.

Agency Contacts (Chemical Managers): Susan Ingber

Table A-9 Model Predictions for Hepatocellular Fatty Degeneration in Rats Exposed to Bromodichloromethane in the Diet for 24 Months (Aida et al. 1992)

Model | DF | χ^2^ | χ2 Goodness-of-fit p-value^a^ | Scaled residuals^b^ | | | AIC | BMD_10_ (mg/kg/day) | BMDL_10_ (mg/kg/day)
Model | DF | χ^2^ | χ2 Goodness-of-fit p-value^a^ | Dose below BMD | Dose above BMD | Overall largest | AIC | BMD_10_ (mg/kg/day) | BMDL_10_ (mg/kg/day)
Male Rats
Gamma^c^ | 2 | 0.00 | 1.00 | −0.00 | 0.00 | 0.00 | 29.30 | 2.08 | 0.80
Logistic | 3 | 5.63 | 0.13 | −1.88 | 0.96 | −1.88 | 36.20 | 4.77 | 3.25
LogLogistic^d^ | 2 | 0.04 | 0.98 | −0.00 | 0.02 | 0.19 | 29.38 | 2.97 | 0.94
LogProbit^d^ | 1 | 0.00 | 0.95 | −0.00 | 0.01 | 0.06 | 31.31 | 2.95 | 0.86
Multistage (1-degree) ^e^ ^,^ ^f^ | 2 | 0.31 | 0.86 | -0.00 | -0.42 | -0.42 | 29.63 | 1.21 | 0.78
Multistage (2-degree)^e^ | 2 | 0.00 | 1.00 | −0.00 | −0.00 | 0.00 | 29.30 | 1.60 | 0.80
Multistage (3-degree)^e^ | 1 | 0.00 | 1.00 | −0.00 | −0.00 | 0.00 | 31.30 | 1.60 | 0.80
Dichotomous Hill | 0 | 0.04 | NA | −0.00 | 0.02 | 0.19 | 33.38 | ND-1 | ND-1
Probit | 2 | 3.59 | 0.17 | −1.17 | 1.39 | 1.39 | 33.90 | 4.37 | 2.87
Female Rats
Gamma^c^ | 2 | 1.09 | 0.58 | 0.05 | −0.44 | 0.94 | 46.76 | ND-2 | ND-2
Logistic | 3 | 6.31 | 0.09 | −1.76 | 0.71 | 1.76 | 52.31 | ND-3 | ND-3
LogLogistic^d^ | 2 | 0.01 | 1.00 | 0.00 | −0.00 | 0.08 | 44.84 | 6.03 | 2.84
LogProbit^d^ | 1 | 0.00 | 1.00 | 0.00 | 0.00 | 0.00 | 46.83 | 6.56 | 2.67
Multistage (1-degree) ^e^ | 2 | 2.14 | 0.34 | 0.14 | -1.03 | 1.03 | 47.95 | ND-1 | ND-1
Multistage (2-degree)^e^ | 2 | 0.09 | 1.00 | 0.01 | −0.03 | 0.09 | 44.84 | 3.72 | 1.10
Multistage (3-degree)^e^ | 1 | 0.00 | 1.00 | 0.00 | −0.00 | −0.00 | 46.83 | 4.32 | 1.01
Dichotomous Hill | 1 | 0.00 | 0.94 | 0.00 | −0.00 | 0.08 | 46.84 | 6.02 | 2.84
Probit ^f^ | 3 | 1.38 | 0.71 | -0.84 | 0.63 | -0.84 | 44.59 | 3.60 | 2.57
Weibull^c^ | 2 | 1.44 | 0.49 | 0.07 | −0.61 | 1.03 | 47.27 | ND-2 | ND-2

a Values <0.1 fail to meet conventional goodness-of-fit criteria.

b Scaled residuals at doses immediately below and above the BMD; also the largest residual at any dose.

c Power restricted to ≥1.

d Slope restricted to ≥1.

e Betas restricted to ≥0.

f Selected model. BMDLs for models providing adequate fit were not sufficiently close (differed by >3-fold). Therefore, the model with lowest BMDL (1^st^ degree multistage) was selected.

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure concentration associated with the selected benchmark response; BMDL_10_ = 95% lower confidence limit on the BMD for a benchmark response of 10% extra risk; DF = degrees of freedom; ND-1 = not determined, BMDL was 10 times lower than the lowest non-zero dose; ND-2 = not determined, lower limit includes zero; ND-3 = not determined, goodness-of-fit p-value <0.1

Figure A-2 Fit of 1^st^ Degree Multistage Model for Hepatocellular Fatty Degeneration in Male Rats Exposed to Bromodichloromethane (mg/kg/day)

Figure A-2 description

Figure A-3 Fit of Probit Model for Hepatocellular Fatty Degeneration in Female Rats Exposed to Bromodichloromethane (mg/kg/day)

Figure A-3 description