# 9 REFERENCES

* Cited in text

*Abrahamsson K, Klick S. 1989. Distribution and fate of halogenated organic substances in an anoxic marine environment. Chemosphere 18:2247–2256.
ACGIH. 1986. Documentation of the threshold limit values and biological exposure indices. 5th ed. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
ACGIH. 2001. Threshold limit values for chemical substances and physical agents & biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
*ACGIH. 2003. Bromoform. Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
*Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27:532–537.4029526
*Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
*Agarwal AK, Mehendale HM. 1983. Absence of potentiation of bromoform hepatotoxicity and lethality by chlordecone. Toxicol Lett 15:251–257.6187108
Agency for Toxic Substances and Disease Registry. 1989a. Toxicological profile for chloroform. Atlanta, GA: ATSDR, January 1989.
Agency for Toxic Substances and Disease Registry. 1989b. Toxicological profile for carbon tetrachloride. Atlanta, GA: Agency for Toxic Substances and Disease Registry. December 1989.
*Agency for Toxic Substances and Disease Registry. 1989c. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Fed Regist 54(174):37618–37634.
Agency for Toxic Substances and Disease Registry. 1990a. Biomarkers of organ damage or dysfunction for the renal, hepatobiliary, and immune systems. Subcommittee on Biomarkers of Organ Damage and Dysfunction. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
Agency for Toxic Substances and Disease Registry. 1990b. Toxicological profile for bromoform and chlorodibromomethane. PB91180323. http://www.atsdr.cdc.gov/toxprofiles/tp130.pdf.
*Agency for Toxic Substances and Disease Registry. 1997. Toxicological profile for chloroform. Atlanta, GA: U.S. Department of Health and Human Services, Agency for Toxic Substances and Disease Registry.
*Agency for Toxic Substances and Disease Registry. 1994. Toxicological profile for chlorodibenzofurans. U.S. Department of Health and Human Services, Public Health Service. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
*Aggazzotti G, Fantuzzi G, Righi E, 1998. Blood and breath analyses as biological indicators of exposure to trihalomethanes in indoor swimming pools. Sci Total Environ 30(1–2):155–163.
*Ahmed AE, Kubic VL, Anders MW. 1977. Metabolism of haloforms to carbon monoxide: I. In vitro studies. Drug Metab Dispos 5:198–204.15814
Ahmed AE, Kubic VL, Stevens JL, 1980. Halogenated methanes: Metabolism and toxicity. Fed Proc 39:3150–3155.6775982
Aida Y, Takada K, Momma J, 1987. Acute and subacute toxicities of three trihalomethanes in rats I. J Toxicol Sci 12:585.
*Aida Y, Takada K, Uchida O, 1992. Toxicities of microencapsulated tribromomethane, dibromochloromethane and bromodichloromethane administered in the diet to Wister rats for one month. J Toxicol Sci 17(3):119–133.1453497
Air Resources Board. 1993. Toxic air contaminant identification list. December 1999. California Air Resources Board. State of California. http://www.arb.ca.gov/toxics/cattable.htm.
Aizawa T, Magara Y, Musashi M. 1989. Effect of bromide ions on trihalomethane (THM) formation in water. Aqua 38:165–175.
Akland GG, Schwab M, Zenick H, 1997. An interagency partnership applied to the study of environmental health in the Lower Rio Grande Valley of Texas. Environ Int 23(5):595–609.
Aldrich TE, Peoples AJ. 1982. Malignant melanoma and drinking water contamination. Bull Environ Contam Toxicol 28:519–523.7093549
Allis JW, Zhao G. 2002. Quantification evaluation of bromodichloromethane metabolism by recombinant rat and human cytochrome P450s. Chem Biol Interact 140:137–153.12076521
Allis JW, Anderson BP, Ross TM, 2002. Evidence for the involvement of CYP1A2 in the metabolism of bromodichloromethane. Toxicology 176:25–37.12062927
*Allis JW, Brown BL, Zhao G, 2001. The effects of inhalation exposure to bromodichloromethane on specific rat CYP isoenzymes. Toxicology 161(1–2):67–77.11295256
*Altman PL, Dittmer DS. 1974. Biological handbooks: Biology data book. Vol. III. 2nd ed. Bethesda, MD: Federation of American Societies for Experimental Biology, 1987–2008, 2041.
Alvanja M, Goldstein I, Susser M. 1978. A case-control study of gastrointestinal and urinary tract cancer mortality and drinking water chlorination. In: Jolley RL, Bull RJ, Cotruvo JA, ,eds. Water chlorination: Environmental impact and health effects. Ann Arbor, MI: Ann Arbor Science Publishers, 395–409.
*Amagai T, Olansandan, Matsushita H, 1999. A survey of indoor pollution by volatile organohalogen compounds in Katsushika, Tokyo, Japan. Indoor Built Environ 8:255–268.
*Amoore JE, Hautala E. 1983. Odor as an aid to chemical safety: Odor thresholds compared with threshold limit values and volatilities for 214 industrial chemicals in air and water dilution. J Appl Toxico1 3:272–290.
*Anders MW, Stevens JL, Sprague RW, 1978. Metabolism of haloforms to carbon monoxide: II. In vivo studies. Drug Metab Dispos 6:556–560.30605
*Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York: Marcel Dekker, Inc., 9–25.
*Andersen ME, Clewell HJ III, Gargas ML, 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87:185–205.3824380
Anderson BE, Zeiger E, Shelby MD, 1990. Chromosome aberration and sister chromatid exchange test results with 42 chemicals. Environ Mol Mutagen 16(Suppl 18):55–137.2091924
Anonymous. 1985. Chlorodibromomethane. Dangerous Properties of Industrial Materials Reports 5:61–63.
*Antoine SR, DeLeon IR, O'Dell-Smith RM. 1986. Environmentally significant volatile organic pollutants in human blood. Bull Environ Contam Toxicol 36:364–371.3955247
*APHA. 1985a. Halogenated methanes and ethanes by purge and trap-method 514. In: Greenberg AF, Trussell RR, Clesceri LS, eds. Standard methods for the examination of water and wastewater. 16th ed. Washington, DC: American Public Health Association, 591–602.
*APHA. 1985b. Organic contaminants, gas chromatographic/mass spectrometric method - method 516. In: Greenberg AF, Trussell RR, Clesceri LS, eds. Standard methods for the examination of water and wastewater, 16th ed. Washington, DC: American Public Health Association, 612–619.
Aremu DA, Olawuyi JF, Meshitsuka S, 2002. Heavy metal analysis of groundwater from Warri, Nigeria. Int J Environ Health Res 12:261–267.12396526
Arena JM, Drew RH, eds. 1986. Poisoning: Toxicology-symptoms treatments. 5th ed. Springfield, IL: Charles C. Thomas, 522, 652.
*Arguello MD, Chriswell CD, Fritz JS, 1979. Trihalomethanes in water: A report on the occurrence, seasonal variation in concentrations, and precursors of trihalomethanes. JAWWA 71:504–508.
Ariyoshi T, Yamaguchi M, Miyazaki Y, 1993. Trihalomethane induced alterations in the content of metallothionein and in the activities of heme metabolizing enzymes in rats. Bull Environ Contam Toxicol 50(5):772–778.8490284
Arlett CF, Cole J. 1988. The role of mammalian cell mutation assays in mutagenicity and carcinogenicity testing. Mutagenesis 3(6):455–458.3070282
*Arthur CL, 1992. Environmental analysis of organic compounds in water using solid phase micro extraction. J High Resolut Chromatogr 15:741–744.
Aschengrau A, Zierler S, Cohen A. 1993. Quality of community drinking water and the occurrence of late adverse pregnancy outcomes. Arch Environ Health 48(2):105–113.8476301
Ashby J, Tennant RW. 1988. Chemical structure, Salmonella mutagenicity, and extent of carcinogenicity as indicators of genotoxic carcinogenesis among 222 chemicals tested in rodents by the U.S. NCI/NTP. Mutat Res 204:17–115.3277047
*Ashley DL, Bonin MA, Cardinali FL, 1992. Determining volatile organic compounds in human blood from a large sample population by using purge and trap gas chromatography/mass spectrometry. Anal Chem 64:1021–1029.1590585
*Ashley DL, Bonin MA, Cardinali FL, 1996. Measurement of volatile organic compounds in human blood. Environ Health Perspect Suppl 104(5):871–877.
Asoh M, Tateishi T, Kumai T, 1999. Induction of CYP2B in fetal and postnatal rats after maternal administration of phenobarbitol. Pharmacol Toxicol 84:18–23.9974185
*ASTM. 1988. Low molecular weight halogenated hydrocarbons in water method D 3978–85. In: 1988 Annual book of ASTM standards: Water and environmental technology. Vol. 11.02. Water (II). Philadelphia, PA: American Society for Testing and Materials, 141–145.
*Atlas E, Pollock W, Greenburg J, 1993. Alkyl nitrates, nonmethane hydrocarbons, and halocarbon gases over the equatorial Pacific Ocean during saga 3. J Geophys Res 98(D9):16933–16947.
Axelson O. 1985. Halogenated alkanes and alkenes and cancer: Epidemiological aspects. In: Fishbein L O'Neill IK, eds. Environmental carcinogens selected methods of analysis. Vol. 7. Some volatile halogenated hydrocarbons. Lyon, France: International Agency for Research on Cancer, 5–20.
Backer LC, Ashley DL, Bonin MA, 2000. Household exposures to drinking water disinfection byproducts: Whole blood trihalomethane level. J Expo Anal Environ Epidemiol 10(4):321–326.10981726
*Balster RL, Borzelleca JF. 1982. Behavioral toxicity of trihalomethane contaminants of drinking water in mice. Environ Health Perspect 46:127–136.7151753
Baltussen E, Sandra P, David F, 1999. Stir bar sorptive extraction (SBSE), a novel extraction technique for aqueous sample: Theory and principles. J Microcolumn Sep 11(10):737–747.
Banerji AP, Fernandes AO. 1996. Field bean protease inhibitor mitigates the sister-chromatid exchanges induced by bromoform and depresses the spontaneous sister-chromatid exchanges frequency of human lymphocytes in vitro. Mutat Res 360(1):29–35.8657207
Barbante C, Boutron C, Moreau A-L, 2002. Seasonal variations in nickel and vanadium in Mont Blanc snow and ice dated from the 1960's and 1990's. J Environ Monitor 4:960–966.
Barkley J, Bunch J, Bursey JT, 1980. Gas chromatography/mass spectrometry computer analysis of volatile halogenated hydrocarbons in man and his environment - A multimedia environmental study. Biomed Mass Spectrom 7:139–147.7448328
Barnes D, Bellin J, DeRosa C, 1987. Reference dose (RfD): Description and use in health risk assessments. Vol. I, Appendix A: Integrated risk information system supportive documentation. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA600886032a.
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
Bartnicki EW, Castro CE. 1994. Biodehalogenation: Rapid oxidative metabolism of mono-and polyhalomethanes by Methylosinus trichosporium OB-3b. Environ Toxicol Chem 13(2):241–245.
Bassford MR, Simmonds PG, Nickless G. 1998. An automated system for near-real-time monitoring of trace atmospheric halocarbons. Anal Chem 70(5):958–965.21644625
Bathija AT. 2003. Health risk to fetuses, infants and children from stage 1 disinfectants and disinfectant by-products (D/DBPs). Toxicologist 72(S-1):28.
Batjer K, Gabel B, Koschorrek M, 1980. Drinking water in Bremen: Trihalomethanes and social costs: A case study of bromoform formation during chlorination of river water highly contaminated with bromide ions. Sci Total Environ 14:287–291.7394511
*Batterman S, Zhang L, Wang S, 2002. Partition coefficients for the trihalomethanes among blood, urine, water, milk and air. Sci Total Environ 284(1–3):237–247.11846168
Bedding ND, McIntyre AE, Perry R, 1982. Organic contaminants in the aquatic environment: I. Sources and occurrence. Sci Total Environ 25:143–167.
*Beech JA. 1980. Estimated worst case trihalomethane body burden of a child using a swimming pool. Med Hypothesis 6:303–307.
*Beech JA, Diaz R, Ordaz CO, 1980. Nitrates, chlorates and trihalomethanes in swimming pool water. Am J Public Health 70:79–82.7350831
Beissner RS, Guilford WJ, Coates RM, 1981. Synthesis of brominated heptanones and bromoform by a bromoperoxidase of marine origin. Biochemistry 20:3724–3731.7272274
Beliveau M, Krishnan K. 2000a. Concentration dependency of rat blood: Air partition coefficients of some volatile organic chemicals. J Toxicol Environ Health A 60(6):377–389.10933755
*Beliveau M, Krishnan K. 2000b. Estimation of rat blood:air partition coefficients of volatile chemicals using reconstructed mixtures of blood components. Toxicol Lett 116(3):183–188.10996479
Beliveau M, Charest-Tardif G, Krishnan K. 2001. Blood:air partition coefficients of individual and mixtures of trihalomethanes. Chemosphere 44(3):377–381.11459142
Belkin S, Smulski DR, Dadon S, 1997. A panel of stress-positive luminous bacteria for the detection of selected classes of toxicants. Water Res 31(12):3009–3016.
*Bellar TA, Lichtenberg JJ, Kroner RC. 1974. The occurrence of organohalides in chlorinated drinking waters. JAWWA 66:703–706.
Benfenati E, Facchini G, Pierucci P, 1996. Identification of organic contaminants in leachates from industrial waste landfills. TrAC Trends Anal Chem 15(8):305–310.
Benigni R. 1989. A bootstrap analysis of four in vitro short-term test performances. Mutat Res 216(2):127–136.2927414
*Benigni R, Andeoli C, Conti L 1993. Quantitative structure activity relationship models correctly predict the toxic and aneuplodizing properties of six halogenated methanes in Aspergillus nidulans. Mutagenesis 8:301–305.8377647
*Benson M, Brux MD. 1907. Poisoning by bromoform. Br Med J July 27:204.
*Berg WW, Heidt LE, Pollock W, 1984. Brominated organic species in the Arctic atmosphere. Geophysical Research Letters 11:429–432.
*Berger GS. 1994. Epidemiology of endometriosis. In: Berger GS, ed. Endometriosis: Advanced management and surgical techniques. New York, NY: Springer-Verlag.
*Berry MR, Johnson LS, Brenner KP, 1997. Dietary characterizations in a study of human exposures in the lower Rio Grande Valley: II. Household waters. Environ Int 23(5):693–703.
Betterton EA, Arnold RG, Kuhler RJ, 1995. Reductive dehalogenation of bromoform in aqueous solution. Environ Health Perspect Suppl (103):89–91.
*Bianchi AP, Varney MS, Phillips J. 1991. Analysis of volatile organic compounds in estuarine sediments using dynamic headspace and gas chromatography-mass spectrometry. J Chromatogr 542:413–450.
Bielmeier SR, Best DS, Guidici DL, 2002. Pregnancy loss in the rat caused by bromodichloromethane. Toxicol Sci 59:309–315.
Binz C. 1891. [The conversion of bromoform in warm-blooded animals.] Archiv F Experiment Path u Pharmakol 28:201–205. (German)
Biziuk M, Namiesnik J, Czerwinski J, 1996. Occurrence and determination of organic pollutants in tap and surface waters of the Gdansk district. J Chromatogr A 733(1–2):171–183.8814789
Blair A, Burg J, Foran J, 1995. Guidelines for application of meta-analysis in environmental epidemiology. Regul Toxicol Pharmacol 22:189–197.8577954
Board AS, Fuelberg HE, Gregory GL, 1999. Chemical characteristics of air from differing source regions during the Pacific Exploratory Mission-Tropics A. J Meteorol 104(D13):16181–16196.
*Bocchini P, Pozzi R, Andalo C, 1999. Membrane inlet mass spectrometry of volatile organohalogen compounds in drinking water. Rapid Commun Mass Spectrom 13(20):2049–2053.10510419
Bonanno LJ, Freeman NC G, Greenburg M, 2001. Multivariate analysis on levels of selected metals, particulate matter, VOC, and household characteristics and activities from the Midwestern states NHEXAS. Appl Occup Envrion Hyg 16(9):859–874.
Bonome M. 1884. Uber die physiologische wirkung des bromoform, des bromathyl und des bromathylen. Centralblatt fur Chirugie 36:593–594.
Boorman GA, Dellarco V, Dunnick JK, 1999. Drinking water disinfection byproducts: Reivew and approach to toxicity evaluation. Environ Health Perspect Suppl 107(1):207–217.
Borzelleca JF. 1983. A review of volatile organic contaminant data. Proceedings - American Water Works Association Water Quality Technology Conference.
*Borzelleca JF, Carchman RA. 1982. Effects of selected organic drinking water contaminants on male reproduction. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Research and Development. EPA600182009. PB82259847.
Bourquin AW, Gibson DT. 1980. Microbial degradation of halogenated hydrocarbons. In: Jolley RL, Gorchev H, Hamilton DH Jr., eds. Water chlorination: Environmental impact and health effects. Vol. 2. Ann Arbor, MI: Ann Arbor Science Publishers, Inc., 253–264.
*Bouwer EJ, McCarty PL. 1983a. Transformation of l- and 2-carbon halogenated aliphatic organic compounds under methanogenic conditions. Appl Environ Microbial 45:1286–1294.
*Bouwer EJ, McCarty PL. 1983b. Transformation of halogenated organic compounds under dentrification conditions. Appl Environ Microbial 45:1295–1299.
*Bouwer EJ, McCarty PL. 1984. Modeling of trace organics biotransformation in the subsurface. Ground Water 22:433–440.
*Bouwer EJ, Wright JP. 1986. Anoxic transformations of trace halogenated aliphatics [Abstract]. American Chemical Society: Environmental Chemistry Section 26:42–45.
*Bouwer EJ, Rittman BE, McCarty PL. 1981. Anaerobic degradation of halogenated 1- and 2-carbon organic compounds. Environ Sci Technol 15:596–599.22283955
*Bove F, Shim Y, Zeitz P. 2002. Drinking water contaminants and adverse pregnancy outcomes: A review. Environ Health Perspect 110(Suppl 1):61–74.
*Bove FJ, Fulcomer M, Klotz JB, 1992. Population-based surveillance and etiological research of adverse reproductive outcomes and toxic wastes. Report on phase 1V-B: Public drinking water contamination and birthweight, and selected birth defects. A case control study. New Jersey: New Jersey Department of Health.
*Bove FJ, Fulcomer MC, Klotz JB, 1995. Public drinking water contamination and birth outcomes. Am J Epidemiol 141(9):850–862.7717362
*Bowman FJ, Borzelleca JF, Munson AE. 1978. The toxicity of some halomethanes in mice. Toxicol Appl Pharmacol 44:213–215.675691
*Brass HF, Feige MA, Halloran T, 1977. The national organic monitoring survey: Samplings and analyses for purgeable organic compounds. In: Pojasek RB, ed. Drinking water quality enhancement through source protection. Ann Arbor, MI: Ann Arbor Science Publishers, 393–416.
Brenniman GR, Vasilomanolakis-Lagos J, Amsel J, 1980. Case-control study of cancer deaths in Illinois communities served by chlorinated or non-chlorinated water. In: Jolley RL, Brungs WA, Cummings RB, , eds. Water chlorination: Environmental impact and health effects. Ann Arbor, MI: Ann Arbor Science Publishers, 1043–1057.
Brett RW, Calverley RA. 1979. A one-year survey of trihalomethane concentration changes within a distribution system. JAWWA 71:515–520.
*Brodzinsky R, Singh HB. 1983. Volatile organic chemicals in the atmosphere: An assessment of available data. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Research and Development. EPA600383027(A).
Brooks BO, Aldrich FD, Utter GM, 1990. Immune responses to pollutant mixtures from indoor sources. Ann N Y Acad Sci 641:199–214.
*Brown BR, Sipes IG, Sagalyn MA. 1974. Mechanisms of acute hepatic toxicity: Chloroform, haloform and glutathione. Anesthesiology 41:554–561.4433055
Brzezinski MR, Boutelet-Bochan H, Person RE, 1999. Catalytic activity and quantitation cytochrome P-450 2E1 in prenatal human brain. J Pharmacol Exp Ther 289:1648–1653.10336564
*Buckley TJ, Liddle J, Ashley DL, 1997. Environmental and biomarker measurements in nine homes in the lower Rio Grande valley: Multimedia results for pesticides, metals, PAHs, and VOCs. Environ Int 23(5):705–732.
Bull RJ, Birnbaum LS, Cantor KP, 1995. Water chlorination: Essential process or cancer hazard? Fundam Appl Toxicol 28(2):155–166.8835225
*Burton-Fanning FW. 1901. Poisoning by bromoform. Br Med J May 18:1202–1203.
Butterworth BE, Conolly RB, Morgan KT. 1995. A strategy for establishing mode of action of chemical carcinogenesis as a guide for approaches to risk assessments. Cancer Lett 93:129–146.7600540
Cailleux A, Subra JF, Riberi P, 1989. Uptake of trihalomethanes by patients during hemodialysis. Clin Chim Acta 181(1):75–80.2721007
*Callahan MA, Slimak MW, Gabel NW, 1979. Water-related environmental fate of 129 priority pollutants: Vol. I: Introduction and technical background, metals and inorganics, pesticides and PCB. Washington, DC: U.S. Environmental Protection Agency, Office of Water Planning and Standards. EPA440479029a. PB80204373.
Callahan MA, Slimak MW, Gabel NW, 1980. Epidemiologic studies of chlorination by-products in drinking water: An overview. In: Jolley RL, Brungs WA, Cotruvo JA, , eds. Water chlorination: Environmental impact and health effects. Environment, health, and risk. Ann Arbor, MI: Ann Arbor Science Publishers.
Cammann K, Hubner K. 1995. Trihalomethane concentrations in swimmers' and bath attendants' blood and urine after swimming or working in indoor swimming pools. Arch Environ Health 50(1):61–65.7717770
*Campillo N, Viñas P, López-Garcia N, 2004. Purge-and-trap capillary gas chromatography with atomic emission detection for volatile halogenated organic compounds determination in waters and beverages. J Chromatogr A 1035(1):1–8.15117067
Cantor KP. 1983. Epidemiologic studies of chlorination by-products in drinking water: An overview. In: Jolley RL, Brungs WA, Cotruvo JA, , eds. Water chlorination: Environmental impact and health effects. Vol. 4, Book 2. Environment, health, and risk. Ann Arbor, MI: Ann Arbor Science Publishers, 1381–1398.
Cantor KP, Hoover R, Hartge P, 1985. Drinking water source and risk of bladder cancer: A case-control study. In: Jolley RL, Bull RJ, Cotruvo JA, eds. Water chlorination. Environmental impact and health effects. Ann Arbor, MI: Ann Arbor Science Publishers, 143–150.
*Cantor KP, Hoover R, Hartge P, 1987. Bladder cancer, drinking water source, and tap water consumption: A case-control study. J Natl Cancer Inst 79:1269–1279.3480378
Cantor KP, Hoover R, Mason TJ, 1978. Associations of cancer mortality with halomethanes in drinking water. J Natl Cancer Inst 61:979–985.702538
*Carpenter LJ, Liss PS. 2000. On template sources of bromoform and other reactive bromine gases. J Geophys Res 105(D16):20539–20547.
Carpenter LJ, Liss PS, Penkett SA. 2003. Marine organohalogens in the atmosphere over the Atlantic and Southern Oceans. J Geophys Res 108 (D9):ACH 1–1–ACH1–13.
Carpenter LJ, Malin G, Liss PS, 2000. Novel biogenic iodine-containing trihalomethanes and other short-lived halocarbons in the coastal East Atlantic. Global Biogeochem Cycles 14(4):1191–1204.
*Carpenter LJ, Sturges WT, Penkett SA, 1999. Short-lived alkyl iodines and bromides at Mace Head, Ireland: Links to biogenic sources and halogen oxide production. J Geophys Res 104(D1):1679–1689.
Carpenter SP, Lasker JM, Raucy JL. 1996. Expression, induction, and catalytic activity of the ethanol-inducible cytochrome P450 (CYP2E1) in human fetal liver and hepatocytes. Mol Pharmacol 49(2):260–268.8632758
CCTTE. 1988. Computerized listing of chemicals being tested for toxic effects. United Nations Environment Programme, International Programme on Chemical Safety, International Register of Potentially Toxic Chemicals. Geneva, Switzerland. June 1988.
*CDC/ATSDR. 1990. Biomarkers of organ damage or dysfunction for the renal, hepatobiliary and immuna systems. Atlanta, GA: Centers for Disease Control and Prevention/Agency for Toxic Substances and Disease Registry (CDC/ATSDR). August 1990.
*Cech I, Smith V, Henry J. 1981. Spatial and seasonal variations in concentration of trihalomethanes in drinking water. In: Albaiges J, ed. Analytical techniques in environmental chemistry II. New York, NY: Pergamon Press Ltd., 19–38.
Chapin R, Gulati D, Hope E, 1997. Bromoform. Environ Health Perspect Suppl 105(1):277–278.
*Chen WJ, Weisel CP. 1998. Halogenated DBP concentrations in a distribution system. J Am Water Works Assoc 90(4):151–163.
Chenoweth MB, Hake CL. 1962. The smaller halogenated aliphatic hydrocarbons. Annual Review of Pharmacology 2:363–398.
*Christof O, Seifert R, Michaelis W. 2002. Volatile halogenated organic compound in European estuaries. Biogeochem 59(1–2):143–160.
*Chu I, Secours V, Marino I, 1980. The acute toxicity of four trihalomethanes in male and female rats. Toxicol Appl Pharmacol 52:351–353.7361328
*Chu I, Villeneuve DC, Secours VE, 1982a. Toxicity of trihalomethanes: I. The acute and subacute toxicity of chloroform, bromodichloromethane, chlorodibromomethane and bromoform in rats. J Environ Sci Health [B] 17:205–224.
*Chu I, Villeneuve DC, Secours VE, 1982b. Trihalomethanes: II. Reversibility of toxicological changes produced by chloroform, bromodichloromethane, chlorodibromomethane and bromoform in rats. J Environ Sci Health [B] 17:225–240.
*CITI. 1992. Biodegradation and bioaccumulation data of existing chemicals based on the CSCL Japan. Japan: Japan Chemical Industry Ecology-Toxicology and Information Center. Chemicals Inspection and Testing Institute.
Clansky KB, ed. 1986. Chemical guide to the OSHA hazard communication standard. Burlingame, CA: Roytech Publications Inc., 653–655.
*Clark RM, Pourmoghaddas H, Wymer LJ, 1996. Modelling the kinetics of chlorination byproduct formation: The effects of bromide. Aqua (Oxford) 45(3):112–119.
*Clark RM, Smalley G, Goodrich JA, 1994. Managing water quality in distribution systems: Simulating TTHM and chlorine residual propagation. Aqua (Oxford) 43(4):182–191.
*Class T, Kohnle R, Ballschmiter K. 1986. Chemistry of organic traces in air VII: Bromo- and bromochloromethanes in air over the Atlantic Ocean. Chemosphere 15:429–436.
Clayton GD, Clayton FE, eds. 1981. Patty's industrial hygiene and toxicology. 3rd ed. New York, NY: John Wiley and Sons, 3469–3470.
*Clewell HJ III, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
CLC. 1988. Coordinated list of chemicals. Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development.
*CLPSD. 1988. Contract Laboratory Program Statistical Database. Alexandria, VA: Viar and Company, Management Services Division. December, 1988.
*Cobb GD, Bouwer EJ. 1991. Effects of electron acceptors on halogenated organic compound biotransformations in a biofilm column. Environ Sci Technol 25:1068–1074.
*Cocchioni M, Pellegrini MG, Nacciarriti L, 1996. Presenza di organo-alogenati alifatici nelle bevande del commercio. Ig Mod 106:287–293.
*Coffin JC, Ge R, Yang S, 2000. Effect of trihalomethanes on cell proliferation and demethylaytion in female B6C3F1 mouse liver. Toxicol Sci 58:243–252.11099637
*Colborn T, Clement C. 1992. Chemically induced alterations in sexual and functional development. The wildlife/human connection. In: Advances in modern environmental toxicology. Volume XXI. Princeton, NJ: Princeton Scientific Publishing Co.
Cole RH, Frederick RE, Healy RP, 1984. Preliminary findings of the priority pollutant monitoring project of the nationwide urban runoffprogram. J Water Pollut Control Fed 56:898–908.
*Coleman WE, Lingg RD, Melton RG, 1975. The occurrence of volatile organics in five drinking water supplies using gas chromatography/mass spectrometry. In: Keith IH, ed. Identification and analysis of organic pollutants in water. Ann Arbor Science Publishers, Inc., 305–327.
*Condie LW, Smallwood CL, Laurie RD. 1983. Comparative renal and hepatotoxicity of halomethanes: Bromodichloromethane, bromoform, chloroform, dibromochloromethane and methylene chloride. Drug Chem Toxicol 6:563–578.6653442
*Constan AA, Sprankle CS, Peters JM, 1999. Metabolism of chloroform by cytochrome P450 2E1 is required for induction of toxicity in the liver, kidney, and nose of male mice. Toxicol Appl Pharmacol 160(2):120–126.10527910
Cragle DL, Shy CM, Struba RJ, 1985. A case-control study of colon cancer and water chlorination in North Carolina. Water chlorination: environmental impact and health effects. Ann Arbor, Michigan: Ann Arbor Science Publishers, 153–159.
Crebelli R, Andreoli C, Carere A, 1995. Toxicology of halogenated aliphatic hydrocarbons: Structural and molecular determinants for the disturbance of chromosome segregation and the induction of lipid peroxidation. Chem Bio Interact 98(2):113–129.8548852
Cresteil T, Beaune C, Celier C, 1986. Cytochrome P450 isoenzyme content and monooxygenase activities in rat liver: Effect of ontogenesis and pretreatment by phenobarbital and 3-methylcholanthrene. J Pharmacol Exp Ther 236:269–276.3941398
Cresteil T, Beaune P, Kremers P, 1985. Immnuoquantitation in of epoxide hydroxylase and cytochrome P450 isozymes in fetal and adult liver microsomes. Eur J Biochem 151:345–350.2411555
*CRIS. 2003. CRIS database. Current Research Information System. http://cristel.csrees.usda.gov/star/system.html.
*Crump KS. 1983. Chlorinated drinking water and cancer: The strength of the epidemiologic evidence. In: Jolley RL, Brungs WA, Cotruvo JA, , eds. Water chlorination: Environmental impact and health effects. Vol. 4, Book 2. Environment, health, and risk. Ann Arbor, MI: Ann Arbor Science Publishers, 1481–1491.
*Curtis GP, Robert PV, Reinhard M. 1986. A natural gradient experiment on solute transport in a sand aquifer. 4. Sorption of organic solutes and its influence on mobility. Water Resour Res 22:2059–2067.
*Czerwinski M, McLemore T, Gelboin H, 1994. Quantification of CYP2B7, CY4B1, and CYPOR messenger RNAs in normal lung and lung tumors. Cancer Res 54:1085–1091.8313365
*Daniel FB, Robinson M, Condie LW, 1990. Ninety-day oral toxicity study of chloral hydrate in Sprague-Dawley rats. Drug Chem Toxicol 13(2&3):135–154.2276338
Daniel FB, Robinson M, Condie LW, 1992. Ninety-day oral toxicity study of dibromochloromethane in Sprague-Dawley rats. Drug Chem Toxicol 15(3):217–232.1425361
*Da Silva ML, Charest-Tardif G, Krishnan K, 1999. Influence of oral administration of a quaternary mixture of trihalomethanes on their blood kinetics in the rat. Toxicol Lett 106(1):49–57.10378450
Da Silva ML, Charest-Tardif G, Krishnan K, 2000. Evaluation of the pharmacokinetic interactions between orally administered trihalomethanes in the rat. J Toxicol Environ Health A 60:343–353.10912587
DeAngelo AB, Geter DR, Rosenberg OW, 2002. The induction of aberrant crypt foci (ACF) in the colons of rats by trihalomethanes administered in the drinking water. Cancer Lett 187(1–2):25–31.12359347
DeCarlo VJ. 1979. Studies on brominated chemicals in the environment. Ann NY Acad Sci 320:678–681.287406
DeGreef E, Morris JC, Van Kreijl CF, 1980. Health effects in the chemical oxidation of polluted waters. In: Jolley RL, Brungs WA, Cumming RB, , eds. Water chlorination: Environmental impact and health effects. Vol. 3. Ann Arbor, MI: Ann Arbor Science Publishers, Inc., 913–924.
Delaney JC, Wolfe GW, Kaiser L, 1997. Short term reproductive development effects of chlorodibromomethane in S-D rats when administered in the drinking water. Toxicologist 36(1Pt2):257.
*Delzer GC, Ivahnenko T. Occurrence and temporal variability of methyl tert-butyl ether (MTBE) and other volatile organic compounds in select sources of drinking water: Results of the focused survey. United States Geological Survey. Oregon Health & Science Univeristy and the American Water Works Association Research Foundation, 1–65.
*DeMarini DM, Shelton ML, Warren SH, 1997. Glutathione S-transferase-mediated induction of GC→AT transitions by halomethanes in Salmonella. Environ Mol Mutagen 30(4):440–447.9435885
Department of Health Services. 2000. Monitoring B unregulated contaminants. California code of regulations. 22 CCR 64450.1. Sacramento, CA: California Department of Health Services.
Department of Health Services. 2002. Drinking water standards. Primary maximum contaminant levels (MCLs) and lead and copper action levels. California code of regulations. 22 CCR 64439. Sacramento, CA: California Department of Health Services.
*Dey A, Gareth T, Arun K, 2001. The effect of SFR on the removal of THMs from municipal water by GAC filter. Ultrapure Water 18(3):40–42, 44, 46, 48–50, 53–54.
Dilling WL. 1977. Interphase transfer processes. II. Evaporation rates of chloro methanes, ethanes, ethylenes, propanes, and propylenes from dilute aqueous solutions. Comparisons with theoretical predictions. Environ Sci Technol 11:405–409.
*Djozan D, Assadi Y. 1995. Optimization of the gas chromatographic analysis of traces of volatile halogenated compounds in drinking water. J Chromatogr A 697(1–2):525–532.
Docks EL, Krishna G. 1976. The role of glutathione in chloroform induced hepatotoxicity. Exp Mol Pathol 24:13–22.1253933
Dodds L, King WD. 2001. Relations between trichloromethane compounds and birth defects. Occup Environ Med 58(7):443–446.11404448
*Dodds L, King W, Woolcott C, 1999. Trihalomethanes in public water supplies and adverse birth outcomes. Epidemiology 10(3):233–237.10230830
Dowty B, Carlisle D, Laseter JL. 1975. Halogenated hydrocarbons in New Orleans drinking water and blood plasma. Science 187:75–77.1109227
Doyle TJ, Zheng W, Cerhan JR, 1997. The association of drinking water source and chlorination by-products with cancer incidence among postmenopausal women in Iowa: A prospective cohort study. Am J Public Health 87(7):1168–1176.9240108
*Drikas M, Chow CW K, Cook D. 2003. The impact of recalcitrant organic character on disinfection stability, trihalomethane formation and bacterial regrowth: An evaluation of magnetic ion exchange resin (MIEX) and alum coagulation. J Water Suppl Res Technol-AQUA 52(7):475–487.
Dunnick JK, Haseman JK, Lilja HS, 1985. Toxicity and carcinogenicity of chlorodibromomethane in Fischer 344/N rats and B63CF_1_ mice. Fundam Appl Toxicol 5:1128–1136.3005099
*Duong HA, Berg M, Hoang MH, 2003. Trihalomethane formation by chlorination of ammonium- and bromide-containing groundwater in water supplies of Hanoi, Vietnam. Water Res 37(13):3242–3252.14509712
*Dwelle EH. 1903. Fatal bromoform poisoning. JAMA 41:1540.
*Dykan VA. 1962. Changes in liver and kidney functions due to methylene bromide and bromoform. Nauchn Tr Ukr Nauchn-Issled Inst Gigieny Truda i Profzabolevanii 29:82–90.
*Dykan VA. 1964. Problems on toxicology, clinical practice, and work hygiene in the production of bromine-organic compounds. Gigiena 5b:100–103.
*Egorov AI, Tereschenko AA, Altshul LM, 2003. Exposures to drinking water chlorination byproducts in a Russian city. Int J Hyg Environ Health 206(6):539–551.14626901
*Eichelberger JW, Bellar TA, Donnelly JP, 1990. Determination of volatile organics in drinking water with USEPA method 524.2 and the ion trap detector. J Chromatogr Sci 28:460–467.2273069
El-Dib MA, Ali RK. 1994. Mixed algal population and Scenedesmus sp. as trihalomethane precursors. Bull Environ Contam Toxicol 52(5):712–717.8186642
Elmore E, Fitzgerald MP. 1990. Evaluation of the bioluminescence assays as screen for genotoxic chemicals. Biol Res 340:379–388.
Environment Canada. 1995. Guidelines for Canadian drinking water quality. Canada Water Act. Ottawa, Ontario: Environment Canada.
*EPA. 1980a. Ambient water quality criteria for halomethanes. Washington, DC: U.S. Environmental Protection Agency, Office of Water Regulations and Standards. EPA440580051.
*EPA. 1980b. Volatile organic compounds isotope dilution GC-MS - method 1624. Washington, DC: U.S. Environmental Protection Agency.
*EPA. 1980c. U.S. Environmental Protection Agency. Fed Regist 45:33133.
*EPA. 1982a. Test method: Purgeable halocarbons - method 601. In: Longbottom JE, Lichtenberg JJ, eds. Test methods: Methods for organic chemical analysis of municipal and industrial wastewater. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development. EPA600482057.
*EPA. 1982b. Test method: Purgeables - method 624. In: Longbottom JE, Lichtenberg JJ, eds. Test methods: Methods for organic chemical analysis of municipal and industrial wastewater. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development. EPA600482057.
EPA. 1983a. Reportable quantity document for chlorodibromomethane (dibromochloromethane). Cincinnati, OH: U.S. Environmental Protection Agency, Office of Environmental Criteria and Assessment.
EPA. 1983b. Reportable quantity document for tribromomethane (bromoform). Cincinnati, OH: U.S. Environmental Protection Agency, Office of Environmental Criteria and Assessment.
EPA. 1983c. Treatability manual. Vol. I. Treatability data. Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development. EPA60028200la.
EPA. 1985. U.S. Environmental Protection Agency: Part II. Fed Regist 50:13456–13522.
*EPA. 1986a. Halogenated volatile organics - method 8010. In: Test methods for evaluating solid waste. 3rd ed. SW-846. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
*EPA. 1986b. Gas chromatography/mass spectrometry for volatile organics, method 8240. In: Test methods for evaluating solid waste. 3rd ed. SW-846. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
EPA. 1986c. External review draft for the drinking water criteria document on trihalomethanes. Washington, DC: U.S. Environmental Protection Agency, Office of Drinking Water.
EPA. 1987a. U.S. Environmental Protection Agency: Part II. Fed Regist 52:25690–25717.
EPA. 1987b. U.S. Environmental Protection Agency: Part II. Fed Regist. 52:25942–25953.
*EPA. 1987c. Land disposal restrictions for certain "California List" hazardous wastes and modifications to the framework; Final rule. Part V. U.S. Environmental Protection Agency. Fed Regist 52(130):25760–25792.
EPA. 1988a. U.S. Environmental Protection Agency: Part V. Fed Regist 53:38642–38654.
EPA. 1988b. Toxic chemical release reporting: Community right-to-know. U.S. Environmental Protection Agency. Part II. Fed Regist 53(30):4500–4554.
EPA. 1988c. U.S. Environmental Protection Agency. Part II. Fed Regist 53:31138–31222.
EPA. 1989. Interim methods for development of inhalation references doses. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA600888066F. Exichem Data Base, 1989.
*EPA. 1990. Interim methods for development of inhalation reference concentrations. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development, Environmental Criteria and Assessment Office. EPA600890066A.
*EPA. 1997a. Automated Form R for Windows: User’s guide (RY97). Washington, DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics.
*EPA. 1997b. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. EPA630R96012.
EPA. 1998a. MCLG for bromoform. Washington, DC: U.S. Environmental Protection Agency, Fed Regist 63(241):69402.
*EPA. 2001a. Occurrence of unregulated contaminants in public water systems - A national summary. U.S. Environmental Protection Agency.
*EPA. 2001b. Exploration of perinatal pharmacokinetic issues. Risk assessment forum. Washington, DC: U.S. Environmental Protection Agency. EPA630R01004. http://cfpub.epa.gov/ncea/raf/recordisplay.cfm?deid=29420.
*EPA. 2002a. EPA public drinking water systems: Facts and figures. http://www.epa.gov/safewater/pws/factoids.html.
*EPA. 2002b. 2002 Edition of the drinking water standards and health advisories. Summer 2002. Washington, DC: U.S. Environmental Protection Agency, Office of Water. EPA822R038. http://www.epa.gov/waterscience/drinking/standards/dwstandards.pdf.
*EPA. 2003a. Criteria for municipal solid waste landfills. List of hazardous inorganic and organic constituents. Washington, DC: U.S. Environmental Protection Agency. 40 CFR 258, Appendix II.
*EPA. 2003b. Designation, reportable quantities, and notification. Designation of hazardous substances. Washington, DC: U.S. Environmental Protection Agency. 40 CFR 302.4. http://www.epa.gov/epahome/cfr40.htm.
*EPA. 2003c. Effluent guidelines and standards. General provisions. Toxic pollutants. Washington, DC: U.S. Environmental Protection Agency. 40 CFR 401.15. http://www.epa.gov/epahome/cfr40.htm.
*EPA. 2003d. Identification and listing of hazardous waste. Hazardous constituents. Washington, DC: U.S. Environmental Protection Agency. 40 CFR 261, Appendix VIII. http://www.epa.gov/epahome/cfr40.m.
*EPA. 2003e. Land disposal restrictions. Universal treatment standards. Washington, DC: U.S. Environmental Protection Agency. 40 CFR 268.48. http://www.epa.gov/epahome/cfr40.htm.
*EPA. 2003f. National primary drinking water regulations. Maximum contaminant levels for trihalomethanes. Washington, DC: U.S. Environmental Protection Agency. 40 CFR 141.12. http://www.epa.gov/epahome/cfr40.htm.
*EPA. 2003g. Standards for the management of specific hazardous wastes and specific types of hazardous waste management facilities. Washington, DC: U.S. Environmental Protection Agency. 40 CFR 266, Appendix V. http://www.epa.gov/epahome/cfr40.htm.
*EPA. 2003h. Standards for owners and operators of hazardous waste treatment, storage, and disposal facilities. Ground-water monitoring list. Washington, DC: U.S. Environmental Protection Agency. 40 CFR 264, Appendix IX. http://www.epa.gov/epahome/cfr40.htm.
*EPA. 2003i. Toxic chemical release reporting: Community right-to-know. Chemicals and chemical categories to which this part applies. Washington, DC: U.S. Environmental Protection Agency. 40 CFR 372.65. http://www.epa.gov/epahome/cfr40.htm.
*EPA. 2003j. Toxic Substances Control Act. Health and safety data reporting. Substances and listed mixtures to which this subpart applies. Washington, DC: U.S. Environmental Protection Agency. 40 CFR 716.120. http://www.epa.gov/epahome/cfr40.htm.
*EPA. 2003k. Toxic Substances Control Act. Chemical information rules. Chemical lists and reporting periods. Washington, DC: U.S. Environmental Protection Agency. 40 CFR 712.30. http://www.epa.gov/epahome/cfr40.htm.
*EPA. 2003l. Toxic Substances Control Act. Identification of specific chemical substance and mixture testing requirements. Washington, DC: U.S. Environmental Protection Agency. 40 CFR 799.5055. http://www.epa.gov/epahome/cfr40.htm.
*EPA. 2003m. Water quality guidance for the Great Lakes system. Pollutants of initial focus in the Great Lakes water quality initiative. Washington, DC: U.S. Environmental Protection Agency. 40 CFR 132, Table 6. http://www.epa.gov/epahome/cfr40.htm.
European Union. 1998. Council Directive No. 98/83/EC on the quality of water intended for human consumption. http://europa.eu.int/comm/energy/nuclear/pdf/ec98-83en.pdf.
*Fabbri A, Crescentini G, Mangani F, 1987. Advances in the determination of volatile organic solvents and other organic pollutants by gas chromatography with thermal desorption sampling and injection. Chromatographia 23:856–860.
*Fantuzzi G, Righi E, Predieri G, 2001. Occupational exposure to trihalomethanes in indoor swimming pools. Sci Total Environ 17(3):257–265.
Farant J-P, Baldwin M, de Repentigny F, 1992. Environmental conditions in a recently constructed office building before and after the implementation of energy conservation measures. Appl Occup Environ Hyg 7(2):93–100.
Faust SD. 1977. Chemical mechanisms affecting the fate of organic pollutants in natural aquatic environments. Adv Environ Sci Technol 8:317–365.
Fawell J. 2000. Risk assessment case study-chloroform and related substances. Food Chem Toxicol 38(Suppl 1):S91–S95.
Fawell JK, Fielding M. 1985. Identification and assessment of hazardous compounds in drinking water. Sci Total Environ 47:317–341.3911416
*Fayad NM, Iqbal S. 1985. Analysis of drinking water for the detection of trihalomethanes. Bull Environ Contam Toxicol 35:576–582.4074919
*FDA. 2003. Beverages. Bottled water. Washington, DC: U.S. Food and Drug Administration. 21 CFR 165.110. http://www.access.gpo.gov/cgi-bin/cfrassemble.cgi?title=200321.
*FEDRIP. 2004. Dialog Information Systems, Inc., Palo Alto, CA: Federal Research in Progress.
Ferek RJ, Reid JS, Hobbs PV, 1998. Emission factors of hydrocarbons, halocarbons, trace gases and particles from biomass burning in Brazil. J Geophys Res 103(D24):32107–32118.
Fernandez M, L’Hariodion J, Gauthier L, 1993. Amphibian micronucleus test(s): A simple and reliable method for evaluating in vivo genotoxic effects of freshwater pollutants and radiations: Initial assessment. Mutat Res 292(1):83–99.7688100
Fernández-Martínez G, López-Vilarino JM, López-Mahía P, 2001. Determination of volatile organic compounds in emissions by coal-fired power stations from Spain. Environ Technol 22:567–575.11424734
Finley BL, Scott P, Paustenbach DJ. 1993. Evaluating the adequacy of maximum contaminant levels as health-protective cleanup goals: An analysis based on Monte Carlo techniques. Regul Toxicol Pharmacol 18(3):438–455.8128005
*Fischer RG, Kastler J, Ballschmiter K. 2000. Levels and patterns of alkyl nitrates, multifunctional alkyl nitrates, and halocarbons in the air over the Atlantic Ocean. J Geophys Res 105(D11):14473–14494.
*Fishbein L. 1985. A survey of the analysis of halogenated alkanes and alkenes in biological samples. In: Fishbein L, O'Neill IK, eds. Environmental carcinogens selected methods of analysis. Vol. 7 - Some volatile halogenated hydrocarbons. Publication No. 68. Lyon, France: International Agency for Research on Cancer, 141–168.
Flocke F, Herman RL, Salawitch RJ, 1999. An examination of chemistry and transport processes in the tropical lower stratosphere using observations of long-lived and short-lived compounds obtained during STRAT and POLARIS. J Geophys Res 104(D21):26625–26642.
*Fomon SJ. 1966. Body composition of the infant: Part I: The male “reference infant”. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
*Fomon SJ, Haschke F, Ziegler EE, 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35:1169–1175.7081099
Fourman P, Mason JM, Valencia R, 1994. Chemical mutagenesis testing in Drosophila. X. Results of 70 coded chemicals tested for the National Toxicology Program. Environ Mol Mutagen 23(3):208–227.8162896
*Fraga CG, Leibovitz BE, Tappel AL. 1987. Halogenated compounds as inducers of lipid peroxidation in tissue slices. Free Radic Biol Med 3:119–123.3666515
Fraga CG, Zamora R, Tappel AL. 1989. Damage to protein synthesis concurrent with lipid peroxidation in rat liver slices: Effect of halogenated compounds, peroxides, and vitamin E1. Arch Biochem Biophys 270:84–91.2930200
Francois C, Mestres R, Causse C. 1979. Volatilization rates of some halogen pollutants in water. Trav Soc Pharm Montpellier 39:49–58.
Franks NP, Jenkins A, Conti E, 1998. Structural basis for the inhibition of firefly luciferase by a general anesthetic. Biophys J 75(5):2205–2211.9788915
FSTRAC. 1988. Summary of state and federal drinking water standards and guidelines. Washington, DC: Federal-State Toxicology and Regulatory Alliance Committee.
Fujie K, Aoki T. 1991a. Acute and subacute cytogenetic effects of the trihalomethanes on rat bone marrow cells in vivo. Mutat Res 252(1):85–86.
Fujie K, Aoki T. 1991b. Four major trihalomethanes as inducers of sister-chromatid exchanges in vitro. Mutat Res 253(3):245.
Fujie K, Aoki T, Ito Y, 1993. Sister-chromatid exchanges induced by trihalomethanes in rat erythroblastic cells and their suppression by crude catechin extracted from green tea. Mutat Res 300(3–4):241–246.7687024
*Fujie K, Aoki T, Wada M. 1990. Acute and subacte cytogenetic effects of the trihalomethanes on rat marrow cells in vivo. Mutat Res 242(2):111–119.2233827
*Furlong EA, D'Itri FM. 1986. Trihalomethane levels in chlorinated Michigan drinking water. Ecol Modell 32:215–225.
Gagne M, Beauchamp M, Seguin J-Y. 1996. Fifteen years experience in ozonation for drinking water in Montreal. Ozone Sci Eng 18:299–310.
Gallagher MD, Nuckols JR, Stallones L, 1998. Exposure to trihalomethanes and adverse pregnancy outcomes. Epidemiology 9(5):484–489.9730025
*Galloway SM, Bloom AD, Resnick M, 1985. Development of a standard protocol for in vitro cytogenetic testing with Chinese hamster ovary cells: Comparison of results for 22 compounds in two laboratories. Environ Mutagen 7:1–51.
*Gao P, Pegram RA. 1996. In vitro microsomal lipid and protein binding by metabolically activated bromodichloromethane [Abstract]. Toxicologist 12:421.
*Gao P, Thortan-Manning JR, Warren SH, 1996. Protective effects of glutathione on bromodichloromethane in vivo toxicity and in vitro macromolecular binding in Fischer 344 rats. J Toxicol Environ Health 49:145–159.8874533
*Gargas ML, Burgess RJ, Voisard DE, 1989. Partition coefficients of low-molecular-weight volatile chemicals in various liquids and tissues. Toxicol Appl Pharmacol 98:87–99.2929023
Gargas ML, Clewell HJ, Andersen ME. 1986. Metabolism of inhaled dihalomethanes in vivo: Differentiation of kinetic constants for two independent pathways. Toxicol Appl Pharmacol 82:211–223.3945949
Gebremichael A, Chang A-M, Buckpitt AR, 1995. Postnatal development of cytochrome P4501A1 and 2B1 in rat lung and liver: Effect of aged and diluted sidestream cigarette smoke. Toxicol Appl Pharmacol 135:246–253.8545834
Geiss KT, Frazier JM. 2001. Assessment of oxidative stress in primary rat heptatocytes following exposures to volatile halogenated methanes [Abstract]. Toxicol Lett 123:18.
*Gemma S, Vittozzi L, Testai E. 2003. Metabolism of chloroform in the human liver and indentification of the competent p450s. Drug Metab Dispos 31(3):266–274.12584152
Geter D, Chang L, Granville C, 2002. Analysis of in vitro and in vivo DNA strand breaks induced by trihalomethanes (THMs) [Abstract]. Environ Mol Mutagen 39:27
*Geter DR, Chang LW, Hanley NM, 2004a. Analysis of in vivo and in vitro DNA strand breaks from trihalomethane exposure. J Carcinog 3(1):2–10.14969591
Geter DR, George MH, Moore TM, 2004b. The effects of high animal fat diet on the induction of aberrant crypt foci in the colons of male F344/N rats exposed to trihalomethanes in the drinking water. Toxicol Lett 147(3):245–252.15104116
Geter DR, George H, Moore TM, 2004c. Vehicle and mode of administration effects on the induction of aberrant crypt foci in the colons of male F344/N rats exposed to bromodichloromethane. J Toxicol Environ Health A 67(1):23–29.14668109
Ghess MJ, Wilbourn J, Tossavainen A, 1986. Information bulletin on the survey of chemicals being tested for carcinogenicity. No. 12. Lyon, France: International Agency for Research on Cancer, 98, 212, 226.
*Giwercman A, Carlsen E, Keiding N, 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl 101(2):65–71.
*Glaze WH, Rawley R. 1979. A preliminary survey of trihalomethane levels in selected East Texas water supplies. JAWWA 71:509–515.
*Glaze WH, Koga M, Cancilla D, 1989. Evaluation of ozonation by-products from two California surface waters. JAWWA 81:66–73.
Golderman L, Gellert J, Teschke R. 1983. Quantitative assessment of carbon tetrachloride levels in human blood by head-space gas chromatography: Application in a case of suicidal carbon tetrachloride intoxication. Intensive Care Med 9:131–135.6863723
*Goodwin KD, Lidstrom ME, Oremland RS. 1997. Marine bacterial degradation of brominated methanes. Environ Sci Technol 31:3188–3192.
*Gotoh M, Sikitani Y, Aramaki T, 1992. Pollution due to volatile halocarbon compound in biota. Bull Environ Contam Toxicol 49:186–191.1611238
Gottlieb MS, Carr JK, Clarkson JR. 1982. Drinking water and cancer in Louisiana: A retrospective mortality study. Am J Epidemiol 116:652–667.7137152
Gowda TP H, Asce AM, Lock JD. 1985. Volatilization rates of organic chemicals of public health concern. J Environ Eng 3:755–776.
*Graham EA. 1915. Late poisoning with chloroform and other alkyl halides in relationship to the halogen acids formed by their chemical dissociation. J Exp Med 221:48–75.
Grant WM. 1974. Toxicology of the eye: Drugs, chemicals, plants, venoms. 2nd ed. Springfield, IL: Charles C. Thomas, 203.
Gribble GW. 1992. Naturally occurring organohalogen compounds: A survey. J Nat Prod 55(10):1353–1395.
Gross PM, Saylor JH. 1931. The solubilities of certain slightly soluble organic compounds in water. J Am Chem Soc 53:1744–1751.
*Gschwend PM, MacFarlane JK, Newman KA. 1985. Volatile halogenated organic compounds released to seawater from temperate marine macroalgae. Science 227:1033–1035.17794227
Gschwend PM, Zafiriou OC, Mantoura RF C, 1982. Volatile organic compounds at a coastal site. 1. Seasonal variations. Environ Sci Technol 16:31–38.
*Guasp E, Wei R. 2003. Dehalogenation of trihalomethanes in drinking water on Pd-Fe bimetallic surface. J Chem Technol Biotechnol 78(6):654–658.
*Guzelian PS, Henry CJ, Olin SS, eds. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences Institute Press.
Hakkola J, Pasanen M, Hukkanen J, 1996a. Expression of xenobiotic-metabolizing cyctochrome P450 forms in human full-term placenta. Pharmacology 51:403–411.
Hakkola J, Raunio H, Purkunen R, 1996b. Detection of cytochrome P450 gene expression in human placenta in first trimester of pregnancy. Biochem Pharmacol 52(2):379–383.8694864
Hakkola J, Tanaka E, Pelkonen O. 1998. Developmental expression of cytochrome P450 enzymes in human liver. Pharmacol Toxicol 82(5):209–217.9646325
Hardin BD, Schuler RL, Burg JR, 1987. Evaluation of 60 chemicals in a preliminary developmental toxicity test. Teratog Carcinogen Mutagen 7:29–48.
Harris MA, Chapin RE, Lockhart AC, 1992. Assessment of short-term reproductive and developmental toxicity screen. Fundam Appl Toxicol 19(2):186–196.1516774
*Harris RN, Ratnayake JH, Garry VF, 1982. Interactive hepatotoxicity of chloroform and carbon tetrachloride. Tox Appl Pharmacol 63:281–291.
Haseman JK, Lockhardt A. 1994. The relationship between use of maximum tolerated dose and study sensitivity for detecting rodent carcinogenicity. Fundam Appl Toxicol 22(3):382–391.8050633
*Hassett JJ, Banwart WL, Griffin RA. 1983. Chapter 15: Correlation of compound properties with sorption characteristics of nonpolar compounds by soils and sediments: Concepts and limitations. In: Francis CW, Averbach SI, eds. Environment and solid wastes: Characterization, treatment, and disposal. Ann Arbor, MI: Ann Arbor Science Publishers, Inc., 161–176.
Haworth S, Lawlor T, Mortelmans K, 1983. Salmonella mutagenicity test results for 250 chemicals. Environ Mutagen Suppl 1:3–142.
Hawthorne B. 1988. Workshop on supercritical fluid chromatography. American Laboratory (August 1988):6–8.
*Hayashi M, Kishi M, Sofuni T, 1988. Micronucleus tests in mice on 39 food additives and eight miscellaneous chemicals. Food Chem Toxicol 26(6):487–500.3169648
*HazDat. 2005. HazDat database. ATSDR’s Hazardous Substance Release and Health Effects Database. Atlanta, GA: Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/hazdat.html.
*Heikes DI. 1987. Pesticide and industrial chemical residues: Purge and trap method for determination of volatile halocarbons and carbon disulfide in table-ready foods. J Assoc Off Anal Chem 70:215–226.3571114
Hekmati M, Bradley RL Jr, Sunde ML. 1983. Use of a fertile egg injection technique to assess toxicity of chlorinated compounds found in drinking water. J Food Prot 46:690–692.30921879
Helmig D, Pollock W, Greenburg J, 1996. Gas chromatography mass spectrometry analysis of volatile organic trace gases at Mauna Loa Observatory, Hawaii. J Geophys Res 101(D9):14697–14710.
Henderson VE. 1930. Anaesthetic toxicity. Arch Int Pharmacodyn Ther 38:150–165.
*Henshaw PF, Bewtra JK, Biswas N. 1993. Occurrence of aluminum, lead, and trihalomethanes in drinking water from the Great Lakes. J Great Lakes Res 19:521–532.
Herren-Freund SL, Pereira MA. 1986. Carcinogenicity of by-products of disinfection in mouse and rat liver. Environ Health Perspect 69:59–65.2880712
*Hewitt WR, Brown EM, Plaa GL. 1983. Acetone-induced potentiation of trihalomethane toxicity in male rats. Toxicol Lett 16:285–296.6857724
*Hoel DG, Davis DL, Miller AB, 1992. Trends in cancer mortality in 15 industrialized countries, 1969–1986. J Natl Cancer Inst 84(5):313–320.1738181
Honma M, Hayashi M, Shimada H, 1999. Evaluation of the mouse lymphoma tk assay (microwell method) as an alternative to the in vitro chromosomal aberration test. Mutagenesis 14(1):5–22.10474816
Hopkins RM, Krantz JC Jr. 1968. Anesthesia LXXV: Relative effects of haloforms and epinephrine on cardiac automaticity. Anesth Analg 47:57–67.
*Horvath AL. 1982. Halogenated hydrocarbons: Solubility-miscibility with water. New York, NY: Marcel Dekker, Inc.
*HSDB. 2004a. Bromoform. Environmental standards and regulations. Bethesda, MD: Hazardous Substances Data Bank. http://toxnet.nlm.nih.gov/cgi-bin/sis/htmlgen?HSDB.htm.
*HSDB. 2004b. Dibromochloromethane. Bethesda, MD: Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Information Program. http://toxnet.nlm.nih.gov/cgibin/sis/htmlgen?HSDB.htm.
*Huang W-J, Chen L-Y, Peng H-S. 2004. Effect of NOM characteristics on brominated organics formation by ozonation. Environ Int 29(8):1049–1055.14680887
Huang Q, Wang X, Liao Y, 1995. Discriminant analysis of the relationship between genotoxicity and molecular structure of organochlorine compounds. Bull Environ Contam Toxicol 55(6):796–801.8601056
*Hutzler NJ, Crittenden JC, Gierke JS. 1986. Transport of organic compounds with saturated groundwater flow: Experimental results. Water Resour Res 22:285–295.
*IARC. 1991a. Bromoform. In: IARC monographs on the on the evaluation of carcinogenic risks to humans: Chlorinated drinking water; chlorination by-products; some other halogenated compounds; cobalt and cobalt compounds. Volume 52. Lyon, France: World Health Organization (WHO), International Agency for Research on Cancer, 213–242.
*IARC. 1991b. Dibromochloromethane. In: IARC monographs on the on the evaluation of carcinogenic risks to humans: Chlorinated drinking water; chlorination by-products; some other halogenated compounds; cobalt and cobalt compounds. Volume 52. Lyon, France: World Health Organization (WHO), International Agency for Research on Cancer, 243–268.
*IARC. 1999a. Bromoform. In: IARC monographs on the evaluation of carcinogenic risks to humans: Re-evaluation of some organic chemicals, hydrazine and hydrogen peroxide. Volume 71, part three. Lyon, France: World Health Organization (WHO), International Agency for Research on Cancer, 1309–1316.
*IARC. 1999b. Chlorodibromomethane. In: IARC monographs on the evaluation of carcinogenic risks to humans: Re-evaluation of some organic chemicals, hydrazine and hydrogen peroxide. Volume 71, Part Three. Lyon, France: World Health Organization, International Agency for Research on Cancer, 1331–1338.
ICRP. 1981. Limits for intakes of radionuclides by workers. International Commission on Radiological Protection. 93–95.
*Illet KF, Reid WD, Sipes I., 1973. Chloroform toxicity in mice: Correlation of renal and hepatic necrosis with covalent binding of metabolites to tissue macromolecules. Exp Mol Pathol 19:215–229.4754791
*ILSI. 1997. An evaluation of EPA’s proposed guidelines for carcinogen risk assessment using chloroform and dichloroacetate as case studies: Report of an expert panel. International Life Sciences Institute, Health and Environmental Sciences Institute. November 1997.
*Imaeda K, Yamamoto D, Watanabe T, 1994. Formation of trihalomethanes during production of bean-curd. Jpn J Toxicol Environ Health 40(6):527–533.
*IRIS. 2004a. Bromoform. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/iris/subst/0214.htm.
*IRIS. 2004b. Dibromochloromethane. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/iris/subst/0222.htm.
Irish DD. 1962. Aliphatic halogenated hydrocarbons. In: Patty FA, ed. Industrial hygiene and toxicology. 2nd ed. Vol. II. Toxicology. New York, NY: Interscience Publishers, 1262–1263.
IRPTC. 1989. IRPTC data profile: Bromoform. Geneva, Switzerland: International Register of Potentially Toxic Chemicals. United Nations Environment Programme. January 1989.
Isacson P, Bean JA, Lynch C. 1981. Relationship of cancer incidence rates in Iowa municipalities to chlorination status of drinking water. In: Jolley RL, Brungs WA, Cotruvo JA, , eds. Water chlorination: Environmental impact on health effects. Vol. 4, Part 2. Ann Arbor, MI: Ann Arbor Science Publishers, 1353–1364.
*IUR. 2002. Inventory Update Rule. Toxic Substances Control Act (TSCA) Inventory Update Database. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/oppt/uiru/iur02/index.htm.
Jackson RE, Patterson RJ. 1989. A remedial investigation of an organically polluted outwash aquifer. Ground Water Monit Rev 119–125.
Jenkins TF, Leggett DC, Parker LV, 1985. Toxic organics removal kinetics in overland flow land treatment. Water Res 19:707–718.
Jenner HA, Taylor CJ L, van Donk M, 1996. Chlorination byproducts in chlorinated cooling water of some European coastal stations. Mar Environ Res 43(4):279–293.
Jerpe J, Davis A. 1987. Ambient capillary chromatography of volatile organics with a portable gas chromatograph. J Chromatogr Sci 25:154–157.
Jo WK, Weisel CP, Lioy PJ. 1990. Chloroform exposure and the health risk associated with multiple uses of chlorinated tap water. Risk Anal 10(4):581–585.2287785
*Johanson CE. 1980. Permeability and vascularity of the developing brain: Cerebellum vs. cerebral cortex. Brain Res 190:3–16.6769537
Johnson TL, Scherer MM, Tratnyek PG. 1996. Kinetics of halogenated organic compound degradation by iron metal. Environ Sci Technol 30:2634–2640.
Jorgenson TA, Meierhenry EF, Rushbrook CJ, 1985. Carcinogenicity of chloroform in drinking water to male Osborne-Mendel rats and female B6C3F1 mice. Fundam Appl Toxicol 5:760–769.4043598
*Juchau MR, Boutelet-Bouchan H, Huang Y. 1998. Cytochrome-P-450-dependent biotransformation of xenobiotics in human and rodent embryonic tissues. Drug Metab Rev 30(3):541–568.9710705
Jury WA, Winer AM, Spencer WF, 1987. Transport and transformations of organic chemicals in the soil-air-water ecosystem. Rev Environ Contam Toxicol 99:120–164.
*Kaczmar SW, D'Itri FM, Zabik MJ. 1984. Vitalization rates of selected haloforms from aqueous environments. Environ Toxicol Chem 3:31–35.
*Kanarek MS, Young TB. 1982. Drinking water treatment and risk of cancer death in Wisconsin. Environ Health Perspect 46:179–186.7151760
Kanitz S, Franco Y, Patrone V, 1996. Association between drinking water disinfection and somatic parameters at birth. Environ Health Perspect 104(5):516–520.8743439
Kargalioglu Y, McMillian BJ, Minear RA, 2002. Analysis of the cytotoxicity and mutagenicity of drinking water disinfection by-products in Salmonella typhimurium. Teratog Carcinog Mutagen 22(2):113–128.11835289
Karimi AA, Singer PC. 1991. Trihalomethane formation in open reservoirs. AWWJ 83(3):84–88.
Kash TL, Jenkins A, Harrison NL. 2003. Molecular volume determines the activity of the halogenated alkane bromoform at wild-type and mutant GABA_A_ receptors. Brain Res 960(1–2):36–41.12505655
Kavlock R, Chernoff N, Carver B, 1979. Teratology studies in mice exposed to municipal drinking-water concentrates during organogenesis. Food Cosmet Toxicol 17:343–347.520968
*Keefe SH, Barber LB, Runkel RL, 2004. Fate of volatile organic compounds in constructed wastewater treatment wetlands. Environ Sci Technol 38(7):2209–2216.15112826
*Keith LH, Garrison AW, Allen FR, 1976. Identification of organic compounds in drinking water from thirteen U.S. cities. In: Keith LH, ed. Identification and analysis of organic pollutants in water. Ann Arbor, MI: Ann Arbor Science Publishers, Inc., 329–373.
*Kelley RD. 1985. Synthetic organic compound sampling survey of public water supplies. Des Moines, IA: Iowa Department of Water, Air and Waste Management. PB85214427.
*Kenaga EE. 1980. Predicted bioconcentration factors and soil sorption coefficients of pesticides and other chemicals. Ecotoxicol Environ Safety 4:26–38.7379718
*Kenneke JF, Weber EJ. 2003. Reductive dehalogenation of halomethanes in iron- and sulfate-reducing sediments. 1. Reactivity pattern analysis. Environ Sci Technol 37(4):713–720.12636269
*Kerger BD, Schmidt CE, Paustenbach DJ. 2000. Assessment of airborne exposure to trihalomethanes from tap water in residential showers and baths. Risk Anal 20(5):637–651.11110211
*Khalanski M. 2003. Organic by-products generated by the chlorination of cooling water at marine power stations. Tribune de l’Eau 55/56(619–621):24–39.
Khristov K, Bratanova Z. 1986. Content of trichloromethane in drinking water and determination of toxicological parameters of some of them in acute experiment [Abstract]. Khig Zoraveopaz 5:39.
Kim JW, Lee CG, Park YG, 2000. Combined analysis of germline polymorphisms of p53, GSTM1, GSTT1, CYP1A1, and CYP2E1: Relation to the incidence rate of cervical carcinoma. Cancer 88(9):2082–2091.
Kim WJ, Kim H, Kim CH, 2002. GSTT1-null genotype is a protective factor against bladder cancer. Urology 60(5):913–918.
King WD, Dodds L, Allen AC. 2000. Relation between stillbirth and specific chlorination by-products in public water supplies. Environ Health Perspect 108(9):883–886.
Klingensmith JS, Mehendale HM. 1981. Potentiation of brominated halomethane hepatotoxicity by chlordecone in the male rat. Toxicol Appl Pharmacol 61:378–384.6173934
Klotz JB, Pyrch LA. 1999. Neural tube defects and drinking water disinfection by-products. Epidemiology 10(4):383–390.10401872
Knecht KT, Mason RP. 1991. The detection of halocarbon-derived radical adducts in bile and liver of rats. Drug Metab Dispos 19(2):325–331.1676631
Kobayashi H, Rittmann BE. 1982. Microbial removal of hazardous organic compounds. Environ Sci Technol 16:170A–183A.
*Kobert R. 1906. Lehrbuch der Intaxikationen. II band. Spezieller teil. Stuttgart: Verlag Von Ferdinand Enke, 914–916.
Komori M, Nishio K, Fujitani T, 1989. Isolation of a new human fetal liver cytochrome P450 cDNA clone: Evidence for expression of a limited number of forms of cytochrome P450 in human livers. Arch Biochem Biophys 272(1):219–225.2786707
*Komori M, Nishio K, Kitada M, 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29:4430–4433.2350547
Komulainen H. 2004. Experimental cancer studies of chlorinated by-products. Toxicology 198 (1–3):239–248.15138047
Kool HF, Van Kreijl CF, Van Kranen HJ, 1981. Toxicity assessment of organic compounds in drinking water in the Netherlands. Sci Total Environ 18:135–153.7015503
Kopfler FC, Melton RG. 1977. Human exposure to water pollutants. In: Suffet IH, ed. Advances in environmental science and technology. Vol. 8. Fate of pollutants in the air and water environments. Part 2. Chemical and biological fate of pollutants in the environment. New York, NY: John Wiley and Sons, 419–433.
Korolev AA, Donchenko AI. 1985. Toxicological characteristics of halomethanes: Dichlorobromomethane and dibromochloromethane formed in water chlorination. Gig Sanit 4:80–82.
*Korz V, Gatterman R. 1997. Behavioral alterations in male golden hamsters exposed to chlorobromomethane. Pharmacol Biochem Behav 58(3):643–647.9329053
*Kostiainen R. 1995. Volatile organic compounds in the indoor air of normal and sick houses. Atmos Environ 29(6):693–702.
Koyama Y, Nakazawa Y. 1986. Comparison of the effect of trihalomethanes on lipid metabolism in rat liver slice. Toxicol Lett 31:37–44.3715915
*Kramer MD, Lynch CF, Isacson P, 1992. The association of waterborne chloroform with intrauterine growth retardation. Epidemiology 3:407–413.
Kraybill HF. 1980. Evaluation of public health aspects of carcinogenic/mutagenic biorefractories in drinking water. Prev Med 9:212–218.7383987
Krewski D, Thomas RD. 1992. Carcinogenic mixtures. Risk Anal 12(1):105–113.1574610
*Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. 3rd ed. New York, NY: Raven Press, Ltd., 149–188.
*Krishnan K, Andersen ME, Clewell HJ III, 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RS H, ed. Toxicology of chemical mixtures: Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kroll RB, Robinson GD, Chung JH. 1994a. Characterization of trihalomethane (THM)-induced renal dysfunction in the rat. I. Effects of THM on glomerular filtration and renal concentrating ability. Arch Environ Contam Toxicol 27(1):1–4.8024315
Kroll RB, Robinson GD, Chung JH. 1994b. Characterization of trihalomethane (THM)-induced renal dysfunction in the rat. II. Relative potency of THMs in promoting renal dysfunction. Arch Environ Contam Toxicol 27(1):5–7.8024322
*Kroneld R. 1985. Recovery and reproducibility in determination of volatile halocarbons in water and blood. Bull Environ Contam Toxicol 34:486–496.3986386
Kroneld R. 1986. Volatile halocarbons in water. Bull Environ Contam Toxico1 37:677–685.
Kroneld R. 1987. Effect of volatile halocarbons on lymphocytes and cells of the urinary tract. Bull Environ Contam Toxicol 38:856–861.3580603
*Kroneld R. 1989a. Volatile pollutants in suburban and industrial air. Bull Environ Contam Toxicol 42:868–872.2743019
*Kroneld R. 1989b. Volatile pollutants in the environment and human tissues. Bull Environ Contam Toxicol 42:873–877.2743020
*Kroneld R, Reunanen M. 1990. Determination of volatile pollutants in human and animal milk. Bull Environ Contam Toxicol 44(6):917–923.2354270
*Kubo T, Urano K, Utsumi H. 2002. Mutagenicity characteristics of 255 environmental chemicals. J Health Sci 48(6):545–554.
Kudchadker AP, Kudchadker SA, Shukla RP, 1979. Vapor pressures and boiling points of selected halomethanes. J Phys Chem Ref Data 8:499–517.
Kutob SD, Plaa GL. 1962. A procedure for estimating the hepatotoxic potential of certain industrial solvents. Toxicol Appl Pharmacol 4:354–361.14460943
Kuzma RJ, Kuzma CM, Buncher CR. 1977. Ohio drinking water source and cancer rates. Am J Public Health 77:725–729.
Lahl U, Cetinkaya M, Duszeln JV, 1982. Health risks for infants caused by trihalomethane generation during chemical disinfection of feeding utensils. Ecol Food Nutr 12:7–17.
*Lai CH, Chen KS, Ho YT. 2004. Characteristics of C_2_-C_15_ hydrocarbons in the air of urban Kaohsiung, Taiwan. Atmos Environ 38(13):1997–2011.
*Lam RH F, Brown JP, Fan AM, 1994. Chemicals in California drinking water: Source contaminants, risk assessment, risk management, and regulatory standards. J Hazard Mater 39:173–192.
Lander RE, Kinefelter GR, Strafer LF, 1994. Acute spermatogenic effects of bromoacetuc acids. Fundam Appl Toxicol 22:422–430.8050637
Landi S. 2000. Mammalian class theta GST and susceptibility to carcinogens: A review. Mutat Res 463(3):247–283.11018744
*Landi S, Hanley NM, Kligerman AD, 1999. Induction of sister chromatid exchanges in human peripheral blood lymphocytes by bromoform: Investigation of the role of GSTT1–1 polymorphism. Mutat Res 429(2):261–267.10526210
*Lapham WW, Moran MJ, Zogorski JS. 2000. Enhancement of nonpoint source monitoring of volatile organic compounds in ground water. J Am Water Resour Assoc 36(6):1321–1334.
*LaRegina J, Bozzelli JW, Harkov R, 1986. Volatile organic compounds at hazardous waste sites and a sanitary landfill in New Jersey. Environ Prog 5:18–27.
Laturnus F. 1996. Volatile halocarbons released from Arctic macroalgae. Mar Chem 55:359–366.
Laturnus F, Giese B, Wiencke C, 2000a. Low-molecular-weight organoiodine and organbromine compounds released by polar macroalgae-the influence of abiotic factors. Fresenius Environ Bull 368(2–3):297–302.
*Laturnus F, Lauritsen FR, Gron C. 2000b. Chloroform in a pristine aquifer system: Toward an evidence of biogenic origin. Water Resour Res 36(10):2999–3009.
Lawrence CE, Taylor PR, Track BJ, 1984. Trihalomethanes in drinking water and human colorectal cancer. J Natl Cancer Inst 72:563–568.6583440
*Lebel GL, Benoit FM, Williams DT. 1997. A one-year survey of halogenated disinfection by-products in the distribution system of treatment plants using three different disinfection processes. Chemosphere 34:2301–2317.
*LeCurieux F, Gauthier L, Erb F, 1995. Use of the SOS chromotest, the Ames-fluctuation test, and the newt micronucleus test to study the genotoxicity of four trihalomethanes. Mutagenesis 10(4):333–341.7476270
Lee J-F, Liao P-M, Lee C-K, 2004a. Clay-catalyzed reactions of coagulant polymers during water chlorination. J Colloid Interface Sci 270(2):381–387.14697704
*Lee SC, Guo H, Lam SM, 2004b. Multipathway risk assessment on disinfection by-products of drinking water in Hong Kong. Environ Res 94(1):47–56.14643286
*Leeder JS, Kearns GL. 1997. Pharmcogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
*Leung H-W. 1993. Physiologically-based pharmacokinetic modelling. In: Ballentine B, Marro T, Turner P, eds. General and applied toxicology. Vol. 1. New York, NY: Stockton Press, 153–164.
Leuze E. 1922. Zur theorie der narkose: Die veteilung der inhalationsnarkotika im tierkorper. Archiv F Experiment Path u Pharmakol 95:145–165.
*Lewis RJ. 1997. Hawley’s condensed chemical dictionary. 13^th^ ed. New York, NY: John Wiley & Sons, Inc., 354.
*Lide DR. 2000. Bromoform. In: CRC handbook and chemistry and physics. 81^st^ ed. Boca Raton, FL: CRC Press LLC, 3–207.
Lieber L. 1997. Cytochrome P-4502E1: Its physiological and pathological role. Physiol Rev 77(2):517–544.9114822
Ligocki MP, Pankow JF. 1985. Assessment of adsorption/solvent extraction with polyurethane foam and adsorption/thermal desorption with Tenax gas chromatography for the collection and analysis of ambient organic vapors. Anal Chem 57:1138–1144.
Ligocki MP, Leuenberger C, Pankow JF. 1985. Trace organic compounds in rain-II. Gas scavenging of neutral organic compounds. Atmos Environ 19:1609–1617.
*Livingston AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4:301–324.351201
*Lopes TJ, Bender DA. 1998. Nonpoint sources of volatile organic compounds in urban areas – relative importance of land surfaces and air. Envrion Pollut 101:221–230.
Loveday KS, Anderson BE, Resnick BE, 1990. Chromosome aberration and sister chromatid exchange tests in Chinese hamster ovary cells in vitro: V. Results with 46 chemicals. Environ Mol Mutagen 16(4):272–303.2253606
*Low JC, Wang NY, Williams J, 2003. Measurements of ambient atmospheric C_2_H_5_Cl and other ethyl and methyl halides at coastal California sites and over the Pacific Ocean. J Geophys Res 108(D19):ACH 7–1–ACH 7–13.
Lucas GH W. 1928. A study of the fate and toxicity of bromine and chlorine containing anesthetics. J Pharmacol 34:223–237.
Luciene da Silva M, Charest-Tardif G, Krishnan K, 1999. Influence of oral administration of a quaternary mixture of trihalomethanes on their blood kinetics in the rat. Toxicol Lett 106:49–57.10378450
*Lynberg M, Nuckols JR, Langlois P, 2001. Assessing exposure to disinfection by-products in women of reproductive age living in Corpus Christi, Texas, and Cobb County, Georgia: Descriptive results and methods. Environ Health Perspect 109:597–604.11445514
*Mabey W, Mill T. 1978. Critical review of hydrolysis of organic compounds in water under environmental conditions. J Phys Chem Ref Data 7:383–409.
*Mabey WR, Smith JH, Podoll RT, 1982. Aquatic fate process data for organic priority pollutants. Washington, DC: U.S. Environment Protection Agency, Office of Water Regulations and Standards. EPA440481014.
*Mack GA, Stanley J. 1985. The national human adipose tissue survey. Washington, DC: U.S. Environmental Protection Agency, Office of Pesticides and Toxic Substances.
*Mackay D, Shiu WY. 1981. A critical review of Henry's law constants for chemicals of environmental interest. J Phys Chem Ref Data 10:1175–1199.
*Mackay D, Bobra A, Chan D, 1982. Vapor pressure correlations for low-volatility environmental chemicals. Environ Sci Technol 16:645–649.
Mackay DM, Ball WP, Durant MG. 1986a. Variability of aquifer sorption properties in a field experiment on groundwater transport of organic solutes: Methods and preliminary results. J Contam Hydrol 1:119–132.
Mackay DM, Freyberg DL, Goltz MN, 1983. A field experiment on ground water transport of halogenated organic solutes. American Chemical Society: Division of Environmental Chemistry 23:368–371.
Mackay DM, Freyberg DL, Roberts PV, 1986b. A natural gradient experiment on solute transport in a sand aquifer: 1. Approach and overview of plume movement. Water Resource Research 22:2017–2029.
*Maddock MB, Kelly JJ. 1980. A sister chromatid exchange assay for detecting genetic damage to marine fish exposed to mutagens and carcinogens. In: Jolley RL, Qrungs WA, Cumming RB, , eds. Water chlorination: Environmental impact and health effects. Vol. 3. Ann Arbor, MI: Ann Arbor Science Publishers, Inc., 835–844.
*Mansour H, Robson M, Meyer R, 1999. Potential impact of chlorination of sandy bottom swimming areas on drinking water sources. Int J Environ Stud 56(5):653–665.
Maresova Z, Mach O, Friedberger V, 1957. The dissolution of gallstones with bromoform [Abstract]. Casopis Lekaru Ceskych 96:179–182.13413915
*Marienfeld CJ, Collins M, Wright H, 1986. Cancer mortality and the method of chlorination of public drinking water: St. Louis City and St. Louis County, Missouri. J Environ Pathol Toxicol Oncol 7:141–158.3795009
*Marshall RA, Hamilton JT, Dring MJ, 2003. Do vesicle cells of the red alga Asparagopsis (Falkenbergia stage) play a role in bromoform production? Chemosphere 52(2):471–475.12738272
*Martinez E, Llobet I, Lacorte S, 2002. Patterns and levels of halogenated volatile compounds in Portuguese surface waters. J Environ Monit 4:253–257.11993765
Mathews JM, Troxler PS, Jeffcoat AR. 1990. Metabolism and distribution of bromodichloromethane in rats after single and multiple oral doses. J Toxicol Environ Health 30:15–22.2112202
Matsuoka A, Yamakage K, Kusakabe H, 1996. Re-evaluation of chromosomal aberration induction on nine mouse lymphoma assay 'unique positive' NTP carcinogens. Mutat Res 369(3–4):243–252.8792842
*Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74:135–149.1387742
McGeehin MA, Reif JS, Becher J, 1993. A case-control study of bladder cancer and water disinfection in Colorado. Am J Epidemiol 138:492–501.8213753
*McGregor DB, Brown AG, Howgate S, 1991. Responses of the L5178Y mouse lymphoma cell forward mutation assay. V. 27 coded chemicals. Environ Mol Mutagen 17(3):196–219.1902415
*McNeal TP, Hollifield HC, Diachenko GW. 1995. Survey of trihalomethanes and other volatile chemical contaminants in processed foods by purge-and-trap capillary gas chromatography with mass selective detection. J AOAC Int 78:391–397.7756854
*McQuarrie JP, Carlson K. 2003. Secondary benefits of aquifer storage and recovery: Disinfection byproduct control. J Environ Eng 129(5):412–418.
*Melnick RL, Kohn MC, Dunnick JK, 1998. Regenerative hyperplasia is not required for liver tumor induction in female B6C3F1 mice exposed to trihalomethanes. Toxicol Appl Pharmacol 148(1):137–147.9465273
Mera N, Ohmori S, Itahashi S, 1994. Immunochemical evidence for the occurrence of Mu class glutathione S-transferase in human fetal livers. J Biochem 116:315–320.7822249
Mersch-Sundermann V. 1989. [Examination of mutagenicity of organic microconcentrations of the environment. II. Communication: The mutagenicity of halogenated aliphatic hydrocarbons with the Salmonella-Microsome-Test (Ames-Test) as to contamination of ground – and drinking water]. Abl Bakt Hyg B 187:230–243. (German)
*Merzbach L. 1928. [The pharmacology of methyl bromide and related compounds.] Z Gesamte Ep Med 63:383–392. (German)
Michael LC, Pellizzari ED, Wiseman RW. 1988. Development and evaluation of a procedure for determining volatile organics in water. Environ Sci Technol 22:565–570.22195629
*Milanovich FP. 1986. Detecting chloroorganics in groundwater. Environ Sci Technol 20:441–442.19994926
*Miles AM, Singer PC, Ashley DL. 2002. Comparison of trihalomethanes in tap water and blood. Environ Sci Technol 36:1692–1698.11993865
Mill T, Winterle JS, Davenport JE, 1982. Validation of estimation techniques for predicting environmental transformation of chemicals. Washington, DC: U.S. Environmental Protection Agency, Office of Pesticides and Toxic Substances.
*Mills WB, Lew CS, Loh JY. 1998. Predictions of potential human health and ecological risks from power plant discharges of total residual chlorine and chloroform into rivers. Environ Sci Technol 32:2162–2171.
*Mink FL, Brown JT, Rickabaugh J. 1986. Absorption, distribution, and excretion of ^14^C-trihalomethanes in mice and rats. Bull Environ Contam Toxicol 37:752–758.3779162
*Miyagawa M, Takasawa H, Sugiyama A, 1995. The in vivo-in vitro replicative DNA synthesis (RDS) test with hepatocytes prepared from male B6C3F1 mice as an early prediction assay for putative nongenotoxic (Ames-negative) mouse hepatocarcinogens. Mutat Res 343:157–183.7791810
Mochida K, Yamasaki M. 1984. Toxicity of halomethanes to cultured human and monkey cells. Bull Environ Contam Toxicol 33:253–256.6478072
*Mohamed MF, Kang D, Aneja VP. 2002. Volatile organic compounds in some urban locations in United States. Chemosphere 47:863–882.12079081
Moody DA, Smuckler EA. 1986. Disturbances in hepatic heme metabolism in rats administered alkyl halides. Toxicol Lett 32:209–214.3775805
Moody DE, James JL, Clawson GA, 1981. Correlations among the changes in hepatic microsomal components after intoxication with alkyl halides and other hepatotoxins. Mol Pharmacol 20:685–693.6173739
*Morimoto K, Koizumi A. 1983. Trihalomethanes induce sister chromatid exchanges in human lymphocytes in vitro and mouse bone marrow cells in vivo. Environ Res 32:72–79.6617620
*Morris RL, Johnson LG. 1976. Agricultural runoff as a source of halomethanes in drinking water. JAWWA 68:492–494.
Morris RS, Audet AM, Angelillo IF, 1993a. Chlorination, chlorination by-products, and cancer: A meta-analysis. Am J Public Health 82(7):955–963.
Morris RS, Audet AM, Angelillo IF, 1993b. Chlorination, chlorination by-products, and cancer: A meta-analysis. Erratum. Am J Public Health 83(9):1257.
Morris RS, Audet AM, Angelillo IF, 1993c. Chlorination, chlorination by-products, and cancer: A meta-analysis. Am J Public Health 83(9):1347–1348.8363019
*Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokin 5:485–527.
*Moschandreas D, Cha D, Kao SN. 1997. Organic compound concentrations in wastewater of water control plants. Chimika Chronika 26(3):345–378.
*Müller SP, Wolna P, Wunscher U, 1997. Cardiotoxicity of chlorodibromomethane and trichloromethane in rats and isolated rat cardiac myocytes. Arch Toxicol 71(12):766–777.9388010
*Munson AE, Sain LE, Sanders VM, 1982. Toxicology of organic drinking water contaminants: Trichloromethane, bromodichloromethane, dibromochloromethane, and tribromomethane. Environ Health Perspect 46:117–126.7151752
*Munz C, Roberts PV. 1987. Air-water phase equilibria of volatile organic solutes. JAWWA 79:62–69.
Nakajima T, Elovaara E, Okino T, 1995. Different contributions of cytochrome P450 2E1 and P450 2B1/2 to chloroform hepatoxicity in rat. Toxicol Appl Pharmacol 133:215–222.7645016
Narotsky MG, Best DS, Rogers EH, 2001. Developmental effects of disinfectant by-products bromoform, bromodichloroacetic acid, and bromochloroacetic acid in mice. Teratology 63(6):279.
Narotsky MG, Brownie CF, Kavlock RJ. 1997. Critical period of carbon tetrachloride-induced pregnancy loss in Fischer-344 rats, with insights into the detection of resorption sites by ammonium sulfide staining. Teratology 56:252–261.9408976
Nartosky MG, Hamby BT, Mitchell DS, 1993. Full-litter resorptions caused by low-molecular-weight halocarbons in F-344 rats. Teratology 472–473.
Nartosky MG, Pegram RA, Kavlock RJ. 1997. Effect of dosing vehicle on the development toxicity of bromodichloromethane and carbon tetrachloride in rats. Fundam Appl Toxicol 30:30–36.
NAS. 1977. Drinking water and health. Washington, DC: National Academy of Sciences, 695–697.
NAS. 1980. Drinking water and health: Vol. 3. Washington, DC: National Academy of Sciences, 189, 205–206.
NAS. 1987. Drinking water and health: Disinfectants and disinfectant byproducts. Vol. 7. Washington, DC: National Academy of Sciences, 111–112.
*NAS/NRC. 1989. Biologic markers in reproductive toxicology. National Academy of Sciences/National Research Council. Washington, DC: National Academy Press, 15–35.
NATICH. 1988. National air toxics information clearing house: NATICH data base report on state, local and EPA air toxics activities: Final. Austin, TX: Radian Corporation. EPA450588007.
*Needham LL, Hill RH J, Ashley DL, 1995. The priority toxicant reference range study: Interim report. Environ Health Perspect Suppl 103(3):89–94.
*Nelson DR, Koymans L, Kamataki T, 1996. P450 superfamily: Update on new sequences, gene mapping, accession numbers and nomenclature. Pharmacogenetics 6:1–42.8845856
*Nestman ER, Lee EG-H. 1985. Genetic activity in Saccharomyces cerevisiae of compounds found in effluents of pulp and paper mills. Mutat Res 155:53–60.3881665
Newsom JM. 1985. Transport of organic compounds dissolved in ground water. Ground Water Monit Rev 51:28–36.
*Nicholson BC, Maguire BP, Bursill DB. 1984. Henry's law constants for the trihalomethanes: Effects of water composition and temperature. Environ Sci Technol 18:518–521.
*Nieuwenhuijsen MJ, Toledano MB, Eaton N, 2000. Chlorination disinfection byproducts in water and their association with adverse reproductive outcomes: A review. Occup Environ Med 57(2):73–85.10711274
NIOSH. 1988. National Occupational Hazard Survey Printout. Cincinnati, OH: National Institute of Occupational Safety and Health. December 1988.
*NIOSH. 1994. Hydrocarbons, halogenated - method 1003. In: Eller PM, ed. NIOSH manual of analytical methods. 3rd ed. Vol. 2. Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health. DHHS (NIOSH) Publication No. 84–100.
*NIOSH. 2003. NIOSH pocket guide to chemical hazards. Bromoform. Washington, DC: National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/npg/npg.html.
*Nirmalakhandan N, Arulgnanendran V, Moshin M, 1994. Toxicity of mixtures of organic chemicals to microorganisms. Water Res 28(3):543–551.
*Nissinen TK, Miettinen IT, Martikainen PJ, 2002. Disinfection by-products in Finnish drinking waters. Chemosphere 48:9–20.12137063
NLM. 1988. National Library of Medicine CHEMLINE database. Bethesda, MD: National Library of Medicine. December 1988.
Norin H, Renberg L. 1980. Determination of trihalomethanes in water using high efficiency solvent extraction. Water Res 14:1397–1402.
*NRC. 1993. Pesticides in the diets of infants and children. Washington, DC: National Research Council. National Academy Press.
*NTP. 1985. Toxicology and carcinogenesis studies of chlorodibromomethane (CAS No. 124–48-1) in F344/N rats and B6C3F, mice (gavage studies). Technical report series no. 282. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health, National Toxicology Program. NIH Publication No. 88–2538.
*NTP. 1989a. Toxicology and carcinogenesis studies of tribromomethane (bromoform) (CAS No. 75–25-2) in F344/N rats and B6C3F1 mice (gavage studies). Technical report series no. 350. Research Traingle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Institute of Health, National Toxicology Program. NIH Publication No. 88–2805.
*NTP. 1989b. Bromoform: Reproduction and fertility assessment in Swiss CD-1 mice when administered by gavage. Research Triangle Park, NC: National Toxicology Program. NTP-89–068. PB89169254.
*NTP. 1996. Short-term reproductive & developmental toxicity of chlorodeibromomethane (CAS No. 124–48-1) administered in drinking water to Sprague-Dawley rats. NTP Study No. RDGT94003.
Nygren O. 2002. New approaches for assessment of occupational exposure to metals using on-site measurements. J Environ Monit 4:623–627.12400905
*O'Brien PJ. 1988. Radical formation during the peroxidase catalyzed metabolism of carcinogens and xenobiotics: The reactivity of these radicals with GSH, DNA, and unsaturated lipid. Free Radic Biol Med 4:169–184.3281871
Odland JO, Nieboer E, Romanova N, 2003. Intercommunity and temporal variation of eleven essential and five toxic elements in human placentas from deliveries in thirteen arctic and sub-chronic areas of Russia and Norway. J Environ Monit 5:166–174.12619773
Omiencinski CJ, Hassett C, Costa P. 1990. Developmental expression and in situ localization of the phenobarbitol-inducible rat hepatic mRNAs for cytochromes CYP2B1, CYP2B2, CYP2C6, and CYP3A1. Mol Pharmacol 38(2):462–470.2233688
*O’Neil NJ, Smith A, Heckelman PE, eds. 2001. The Merck index. An encyclopedia of chemicals, drugs, and biologicals, 11^th^ edition. Whitehouse Station, NJ: Merck & Co., Inc., 1410.
Ono Y, Somiya I, Kawamura M. 1991. Genotoxicity of the by-products produced in chlorination and ozonation processes. Mutat Res 252:102.
*Oppenheimer JA, Jacangelo JG, Laine J-M, 1997. Testing the equivalency of ultraviolet light and chlorine for disinfection of wastewater to reclamation standards. Water Environ Res 69(1):14–24.
*Orrell JK, Mackie M. 1988. Economic impact analysis of final test rule for 33 solid waste chemicals. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances, Economics and Technology Division, 23–24.
*ORVWSC. 1979. Water treatment process modifications for trihalomethane control and organic substances in the Ohio River. Cincinnati, OH: Ohio River Valley Water Sanitation Commission.
*OSHA. 1989. Department of Labor, Occupational Safety and Health Administration: Part III. Fed Regist. 54:2332–2983.
*OSHA. 2003a. Occupational safety and health standards. Limits for air contaminants. Washington, DC: Occupational Safety and Health Administration. 29 CFR 1910.1000. Table Z-1. http://www.osha.gov/comp-links.html.
*OSHA. 2003b. Occupational safety and health standards for shipyard employment. Air contaminants. Washington, DC: Occupational Safety and Health Administration. 29 CFR 1915.1000. http://www.osha.gov/comp-links.html.
*OSHA. 2003c. Safety and health regulations for construction. Gases, vapors, fumes, dusts, and mists. Washington, DC: Occupational Safety and Health Administration. 29 CFR 1926.55, Appendix A.
OTA. 1990. Neurotoxicity: Identifying and controlling poisons of the nervous system. Washington, DC: Office of Technology Assessment. OTA-BA-438.
Otson R, Williams DT, Bothwell PD. 1982. Volatile organic compounds in water at thirty Canadian potable water treatment facilities. J Assoc Off Anal Chem 65:1370–1374.
*Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
*Page GW. 1981. Comparison of groundwater and surface water for patterns and levels of contamination by toxic substances. Environ Sci Technol 15:1475–1481.
*Pankow D, Damme B, Wunscher U, 1997. Chlorodibromomethane metabolism to bromide and carbon monoxide in rats. Arch Toxicol 71(4):203–210.9101035
Pankow JF, Isabelle LM, Asher WE. 1984. Trace organic compounds in rain. 1. Sampler design and analysis by adsorption/thermal desorption (ATD). Environ Sci Technol 18:310–318.22280076
*Pankow JF, Ligocki MP, Rosen ME, 1988. Adsorption/thermal desorption with small cartridges for the determination of trace aqueous semivolatile organic compounds. Anal Chem 60:40–47.
*Pankow JF, Luo W, Bender DA, 2003. Concentrations and co-occurrence correlations of 88 volatile organic compounds (VOCs) in the ambient air of 13 semi-rural to urban locations in the United States. Atmos Environ 37(36):5023–5046.
*Pankow JF, Luo W, Isabells LM, 1998. Determination of a wide range of volatile compounds in ambient air using multisorbent adsorption/thermal desorption and gas chromatography/mass spectrometry. Anal Chem 70(24):5213–5221.
Pasanen M. 1994. The expression and environmental regulation of P450 enzymes in human placenta. Crit Rev Toxicol 24:211–229.7945891
*Pecher K, Hederlein SB, Schwarzenbach RP. 2002. Retention of polyhalogenated methanes by surface-bound Fe (II) in aqueous suspensions of iron oxides. Environ Sci Technol 36(8):1734–1741.11993871
*Pegram RA, Andersen ME, Areen SH, 1977. Glutathione S-transferase-mediated mutagenicty of trihalomethanes in Salmonella typhimurium: Contrasting results with bromodichloromethane and chloroform. Toxicol Appl Pharmacol 144(1):183–188.
*Pellizzari ED. 1978. Environmental monitoring near industrial sites: Brominated chemicals. Part I. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. EPA560678002. PB286484.
Pellizzari ED, Harwell TD, Harris BS, 1982. Purgeable organic compounds in mother's milk. Bull Environ Contam Toxicol 28:322–328.7082873
Pellizzari ED, Sheldon LS, Bursey JT. 1985a. GC/MS determination of volatile halocarbons in blood and tissue. In: Fishbein L, O'Neill IK, eds. Environmental carcinogens selected methods of analysis. Vol. 7. Lyon, France: International Agency for Research on Cancer, 435–444.
*Pellizzari ED, Zweidinger RA, Sheldon LS. 1985b. Method 24: GC/MS determination of volatile hydrocarbons in breath samples. In: Fishbein L, O'Neill IK, eds. Environmental carcinogens selected methods of analysis. Vol. 7. Lyon, France: International Agency For Research on Cancer, 413–431.
*Peltier S, Benezet M, Gatel D, 2002. Effects of nanofiltration on water quality in the distribution system. J Water Supply Res Technol-AQUA 51(5):253–262.
*Peoples AJ, Pfaffenberger CD, Shafik TM. 1979. Determination of volatile purgeable halogenated hydrocarbons in human adipose tissue and blood serum. Bull Environ Contam Toxicol 23:244–249.497433
Pereira MA. 1983. Carcinogenicity of chlorination byproducts: Trihalomethanes. In: Jolley RL, Brungs WA, Cotruvo JA, , eds. Water chlorination: Environmental impact and health effects. Vol. 4, Book 2. Environment, health and risk. Ann Arbor, MI: Ann Arbor Science Publishers, 1165–1176.
Pereira MA, Herren SL, Britt AL, 1982a. Initiation/promotion bioassay in rat liver: Use of gamma glutamyltranspeptidase-positive foci to indicate carcinogenic activity. Toxicol Pathol 10:11–18.28094711
Pereira MA, Lin L-HC, Lippitt JM, 1982b. Trihalomethanes as initiators and promoters of carcinogenesis. Environ Health Perspect 46:151–156.7151756
*Perry DL, Chuang CC, Jungclaus, 1979. Identification of organic compounds in industrial effluent discharges. Athens, GA: U.S. Environmental Protection Agency, Office of Research and Development.
*Perwak J, Goyer M, Harris J, 1980. An exposure and risk assessment for trihalomethanes. Washington, DC: U.S. Environmental Protection Agency, Office of Water Regulations and Standards.
*Peters R JB, De Leer E WB, Versteegh J FM. 1994. Identification of halogenated compounds produced by chlorination of humic acid in the presence of bromide. J Chromatogr A 686(2):253–261.
PHRED. 1988. Public Health Risk Evaluation Database. Washington, DC: U.S. Environmental Protection Agency. December 1988.
Piet GJ, Morra CH F, Kruijf DE. 1981. The behavior of organic micropollutants during passage through the soil. Stud Environ Sci 17:557–564.
Plaa GL. 1988. Experimental evaluation of haloalkanes and liver injury. Fundam Appl Toxicol 10:563–570.3294072
*Plaa GL, Hewitt WR. 1982a. Methodological approaches for interaction studies: Potentiation of haloalkane-induced hepatotoxicity. National Research Council of Canada. Workshop on the Combined Effects of Xenobiotics, 67–96.
*Plaa GL, Hewitt WR. 1982b. Potentiation of liver and kidney injury of ketones and ketogenic substances. Adv Pharmacol Ther Proc Int Cong 5:65–75.
*Plumb RH Jr. 1991. The occurrence of Appendix IX organic constituents in disposal site ground water. Ground Water Monit Rev 11:157–164.
*Pohl LR, Martin JL, George JW. 1980. Mechanism of metabolic activation of chloroform by rat liver microsomes. Biochem Pharmacol 29:3271–3276.6783046
*Polkowska Z, Kozlowska K, Mazerska Z, 2003. Relationship between volatile organohalogen compounds in drinking water and human urine in Poland. Chemosphere 53(8):899–909.14505712
*Potter CL, Chang LW, DeAngelo AB, 1996. Effects of four trihalomethanes on DNA strand breaks, renal hyaline droplet formation, and serum testosterone in male F-344 rats. Cancer Lett 106:235–242.8844978
*Prah JD, Blount B, Cardinali FL, 2002. The development and testing of a dermal exposure system for pharmacokinetic studies of administered and ambient water contaminants. J Pharmacol Toxicol Methods 47(3):189–195.12628310
Premble S, Schroeder KR, Spencer SR, 1994. Human glutathione S-transferase theta (GSTT1): cDNA cloning and the characterization of a genetic polymorphism. Biochem J 300:271–276.8198545
*Quack B, Wallace DW R. 2003. Air-sea flux of bromoform: Controls, rates, and implications. Global Biogeochem Cycles 17(1):23–1–23–27.
*Radding SB, Liu DH, Johnson HL, 1977. Review of the environmental fate of selected chemicals. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. EPA560577003, 69–72.
*Rapson WH, Nazar MA, Butsky W. 1980. Mutagenicity produced by aqueous chlorination of organic compounds. Bull Environ Contam Toxicol 24:590–596.6991030
Raucy JL. 1995. Risk assessment: Toxicity from chemical exposure resulting from enhanced expression of CYP2E1. Toxicology 105:217–223.8571359
Rebhun M, Heller-Grossman L, Manka J. 1997. Formation of disinfection byproducts during chlorination of secondary effluent and renovated water. Water Environ Res 69(6):1154–1162.
*Redeker KR, Meinardi S, Blake D. 2003. Gaseous emissions from flooded rice paddy agriculture. J Geophys Res 108(D113):ACH 3–1–ACH 3–13.
Reif JS, Hatch MC, Bracken M, 1996. Reproductive and developmental effects of disinfection byproducts in drinking water. Environ Health Perspect 104(10):1056–1061.8930546
*Reitz RH, Mendrala AL, Guengerich FP. 1989. In vitro metabolism of methylene chloride in human and animal tissues: Use in physiologically based pharmacokinetic models. Toxicol Appl Pharmacol 97:230–246.2922756
*Richardson SD, Thruston AD Jr. 2003. Tribromopyrrole, brominated acids, and other disinfection byproducts produced by disinfection of drinking water rich in bromide. Environ Sci Technol 37(17):3782–3793.12967096
*Ritter L, Solomon K, Sibley P, 2002. Sources, pathways, and relative risks of contaminants in surface water and ground water: A perspective prepared for the Walkerton inquiry. J Toxicol Environ Health A 65:1–142.11809004
Rittmann BE, McCarty PL, Roberts PV. 1980. Trace-organics biodegradation in aquifer recharge. Ground Water 18:236–243.
*Roberts PV, Goltz MN, Mackay DM. 1986. A natural gradient experiment on solute transport in a sand aquifer. 3. Retardation estimates and mass balances for organic solutes. Water Resour Res 22:2047–2058.
*Rodriguez MJ, Huard M, Serodes JB. 2004. Experimental study of the formation of chlorination by products in potable water of Quebec City, Canada. Bull Environ Contam Toxicol 72(1):211–218.15058675
Rodriguez MJ, Yannick V, Serodes J-B, 2003. Trihalomethanes in drinking water of greater Quebec region (Canada): Occurrence, variations and modelling. Environ Monit Assess 89(1):69–93.14609275
*Roldan-Arjona T, Pucyo C. 1993. Mutagenic and lethal effects of halogenated methanes in the Ara test of Salmonella typhimurium: Quantitative relationship with chemical reactivity. Mutagenesis 8(2):127–131.8464381
*Rook JJ. 1977. Chlorination reactions of fulvic acids in natural waters. Environ Sci Technol 11:478–482.
Rosenkranz HS, Ennever FK. 1990. An association between mutagenicity and carcinogenic potency. Mutat Res 244(1):61–66.2186271
Rosenkranz HS, Klopman G. 1990. The structural basis of the mutagenicity of chemicals in Salmonella typhimurium: The National Toxicology Program data base. Mutat Res 228(1):51–80.2405260
Rosenkranz HS, Klopman G. 1993. Structural relationships between mutagenicity, maximum tolerated dose, and carcinogenicity in rodents. Environ Mol Mutagen 21(2):193–206.8444146
*Ross MK, Pegram RA. 2003. Glutathione transferase theta 1–1-dependent metabolism of the water disinfection byproduct bromodichloromethane. Chem Res Toxicol 16:216–226.12588193
*Roth O. 1904. Zeitschr f Medizinalbeamte 17:233.
*Roy WR, Griffen RA. 1985. Mobility of organic solvents in water- saturated soil materials. Environ Geol Water Sci 7:241–247.
*RTECS. 2003. Registry of Toxic Effects of Chemical Substances. National Library of Medicine, Bethesda, MD: National Toxicology Information Program. February 2000.
*Ruddick JA, Villeneuve DC, Chu I, 1983. A teratological assessment of four trihalomethanes in the rat. Environ Sci Health B18:333–349.
*Russo MV, Campanella L, Avino P. 2003. Identification of halocarbons in the Tiber and Marta rivers by static headspace and liquid-liquid extraction analysis. J Sep Sci 26(5):376–380.
*Sangster J. 1994. LOGKOW databank. Sangster Research Laboratory, Montreal, Quebec.
*Sarafova VI, Sapelinikova SV, Djazhenko EV, 2004. Gas-chromatography-mass spectrometry with headspace for the analysis of volatile organic compounds in waste water. J Chromatogr B Biomed Sci Appl 800(1–2):325–330.
*Savitz DA, Andrews KW, Pastore LM. 1995. Drinking water and pregnancy outcome in central North Carolina: Source, amount, and trihalomethane levels. Environ Health Perspect 103(6):592–596.7556013
Sax NI. 1984. Dangerous properties of industrial materials. 6th ed. New York, NY: Van Nostrand Reinhold Company, 529–530.
Sax NI, Lewis RJ, eds. 1987. Hawley's condensed chemical dictionary. 11th ed. New York, NY: Van Nostrand Reinhold Company.
Schall C, Laturnus F, Heumann KG. 1994. Biogenic volatile organochloride and organobromine compounds released from polar macroalgae. Chemosphere 28(7):1315–1324.
Schwander P. 1936. Uber die diffusion halogenisierter kohlenwasserstoffe durch die haut. Arch Gewerbepath Gewerbehg 7:109–116.
Scott DR. 1987. Classification and identification of hazardous organic compounds in ambient air by pattern recognition of mass spectral data. Environ Sci Technol 21:891–897.
Sekihashi K, Yamamoto A, Matsumura Y, 2002. Comparative investigation of multiple organs of mice and rats in the comet assay. Mutat Res 517(1–2):53–75.12034309
*Setchell BP, Waites GM H. 1975. The blood-testis barrier. In: Creep RO, Astwood EB, Geiger SR, eds. Handbook of physiology: Endocrinology V. Washington, DC: American Physiological Society.
*Shelton JJ, Burow KR, Belitz K, 2001. Low-level volatile organic compounds in active public supply wells as ground-water tracers in the Los Angeles physiographic basin, California, 2000. Water-resources investigations report. Sacramento, CA: United States Geological Survey, 1029.
*Shetty G, Chellam S. 2003. Predicting contaminant removal during nanofiltration using artificial neural networks. Maximizing the resources: Solutions for pure and plentiful water. Atlanta, GA: Membrane Technology Conference Proceedings. March 2–5, 2003.
Shen TT. 1982. Estimation of organic compound emissions from waste lagoons. J Air Pollut Control Assoc 32:79–82.
Simmon VF. 1977. Structural correlations of carcinogenic and mutagenic alkyl halides. In: Structural correlates of carcinogenesis and mutagenesis: A guide to testing priorities. Washington, DC: U.S. Food and Drug Administration, 163–171.
*Simmon VF, Tardiff RG. 1978. The mutagenic activity of halogenated compounds found in chlorinated drinking water. In: Jolley RL, Gorchev H, Hamilton DH Jr, , eds. Water chlorination: Environmental impact and health effects. Vol. 2. Ann Arbor, MI: Ann Arbor Science Publishers, Inc., 417–431.
*Simmon VF, Kauhanen K, Tardiff RG. 1977. Mutagenic activity of chemicals identified in drinking water. Dev Toxicol Environ Sci 2:249–258.
Simmons JE. 1994. Nephrotoxicity resulting from multiple chemical exposures and chemical interactions. In: Yang RS H, ed. Toxicology of chemical mixtures: Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, Inc., 335–360.
Singer PC, Obolensky A, Greiner A. 1995. DBPs in chlorinated North Carolina drinking waters. AWWA 832–892.
Sistrunk C, DeAngelo T. 2001. The induction of colorectal neoplasia in male F344/N rats exposed to a mixture high in brominated trihalomethanes (THMs) in the drinking water. Int J Toxicol 20(6):408–409.
Sittig M. 1985a. Bromoform. In: Handbook of toxic and hazardous chemicals and compounds. Park Ridge, NJ: Noyes Publications, 149–150.
Sittig M. 1985b. Dibromochloromethane. In: Handbook of toxic and hazardous chemicals and compounds. Park Ridge, NJ: Noyes Publications, 306.
*Smith VL, Cech I, Brown JH, 1980. Temporal variations in trihalomethane content of drinking water. Environ Sci Technol 14:190–196.
So B-J, Bull RJ. 1995. Dibromoacetate (DBA) acts as a promoter of abnormal crypt foci in the colon of F344 rats. Toxicologist 15:1242.
*Sobti RC. 1984. Sister chromatid exchange induction potential of the halogenated hydrocarbons produced during water chlorination. CIS Chromosome Inf Serv 37:17–19.
*Sofuni T, Honma M, Hayashi M, 1996. Detection of in vitro clastogens and spindle poisons by the mouse lymphoma assay using the microwell method: Interim report of an international collaborative study. Mutagenesis 11(4):349–355.8671759
Sonoyama N, Seike S, Sueoka T, 2003. Electrochemical decomposition of ppb level trihalomethane in tap water. J Appl Electrochem 33(11):1049–1055.
SRI. 1985. Directory of chemical producers: United States of America. Palo Alto, CA. SRI International, 457.
SRI. 1986. Directory of chemical producers: United States of America. Palo Alto, CA. SRI International, 512.
SRI. 1987. Directory of chemical producers: United States of America. Palo Alto, CA. SRI International, 495.
SRI. 1988. Directory of chemical producers: United States of America. Palo Alto, CA. SRI International, 490.
SRI. 2002. Directory of chemical producers: United States of America. Palo Alto, CA. SRI International, 490.
*SRI. 2004. Directory of chemical producers. United States of America. Palo Alto, CA. SRI International.
*Stangroom SJ, Collins CD, Lester JN. 1998. Sources of organic micropollutants to lowland rivers. Environ Technol 19:643–666.
*Stanley JS. 1986. Broad scan analysis of human adipose tissue: Vol. 1: Executive summary. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. EPA560586035.
*Staples CA, Werner AF, Hoogheem TJ. 1985. Assessment of priority pollutant concentrations in the United States using STORET database. Environ Toxicol Chem 4:131–142.
*Stenger VA. 1978. Bromine compounds: Organic. In: Kirk-Othmer’s encyclopedia of chemical technology, 3rd ed., Vol. 4. New York, NY: John Wiley and Sons, 243–263.
*Stevens JL, Anders MW. 1979. Metabolism of haloforms to carbon monoxide-III: Studies on the mechanism of the reaction. Biochem Pharmacol 28:3189–3194.526325
*Stevens JL, Anders MW. 1981. Metabolism of haloforms to carbon monoxide. IV. Studies on the reaction mechanism in vivo. Chem Biol Interact 37:365–374.7296701
Stevens RH, Cole DA, Lindholm PT, 1984. Identification of carcinogens by measurement of cell-mediated immunity v. antitumor immunity in rats to halogen-containing organic compounds. In: Jolley RL, Bull RJ, Davis WP, , eds. Water chlorination: Chemistry, environmental impact, and health effects. Vol. 5. Chelsea, MI: Lewis Publishers, Inc., 251–264.
*Stocker KJ, Statham J, Howard WR, 1997. Assessment of the potential in vivo genotoxicity of three trihalomethanes: Chlorodibromomethane, bromodichloromethane and bromoform. Mutagenesis 12(3):169–173.9175643
*Stokes CE. 1900. Memoranda: Medical, surgical, obstetrical, therapeutical, pathological, etc. Two cases of bromoform poisoning: Recovery. Br Med J May 26, 1900.
Stoltz C, Vachon E, Trottier E, 1998. The CYP2B2 phenobarbitol response unit contains an accessory factor element and a putative glucocoticoid response element essential for conferring maximal Phenobarbital responsiveness. J Biol Chem 273:8528–8536.9525968
*Storm DL. 1994. Chemical monitoring of California's public drinking water sources: Public exposures and health impacts. In: Wang RGM, ed. Water contamination and health: Integration of exposure assessment, toxicology, and risk assessment. New York, NY: Marcel Dekker, Inc., 67–124.
*Stubin AI, Brosnan TM, Porter KD, 1996. Organic priority pollutants in New York City municipal wastewaters: 1989–1993. Water Environ Res 68:1037–1044.
Sturges WT, Harrison RM. 1986. Bromine in marine aerosols and the origin, nature and quantity of natural atmospheric bromine. Atmos Environ 20:1485–1496.
Sturges WT, Cota GF, Buckley PT. 1992. Bromoform emission from Arctic ice algae. Nature 358:660–662.
*Sturges WT, McIntyre HP, Penkett SA, 2001. Methyl bromide, other brominated methanes, and methyl iodine in polar firn air. J Geophys Res 106(D2):1595–1606.
Suitheimer C, Bost R, Sunshine I. 1982. Volatiles by headspace chromatography. In: Sunshine I, Jatlow PI, eds. Methodology for analytical technology. Vol. II. Boca Raton, FL: CRC Press, 1–9.
*Symons JM, Bellar TA, Carswell JK, 1975. National organics reconnaissance survey for halogenated organics. JAWWA 67:634–647.
*Symons JM, Krasner SW, Simms LA, 1993. Measurement of THM and precursor concentrations revisited: The effect of bromide ion. JAWWA 85(1):51–62.
*Tabak HH, Quaze SA, Mashni CI, 1981. Biodegradability studies with organic priority pollutant compounds. J Water Pollut Control Fed 53:1503–1518.
Tardiff RG, Carlson GP, Simmon V. 1975. Halogenated organics in tap water. In: Jolley RL, ed. Water chlorination: Environmental impact and health effects. Vol. 1. Ann Arbor, MI: Ann Arbor Science Publishers, Inc., 195–209.
Tennant RW, Ashby J. 1991. Classification according to chemical structure, mutagenicity to Salmonella and level of carcinogenicity by the U.S. National Toxicology Program. Mutat Res 257(3):209–228.2014033
Tennant RW, Elwell R, Spalding JW, 1991. Evidence that toxic injury is not always associated with induction of chemical carcinogenesis. Mol Carcinog 4:420–440.1793481
*Thacker NP, Nitnaware V. 2003. Factors influencing formation of trihalomethanes in swimming pool water. Bull Environ Contam Toxicol 71:633–640.14567592
Their R, Taylor JB, Pemble SE, 1993. Expressions of mammalian glutathione S-transferase 5–5 in Salmonella typhimurium tester strains to study the activation/detoxification of mutagenic compounds: Studies with halogenated compounds, aromatic amines, and aflatoxin B1. Proc Natl Acad Sci USA 90(18):8576–8580.8378332
Theiss JC, Stoner GD, Shimkin MB, 1977. Test for carcinogenicity of organic contaminants of United States drinking waters by pulmonary tumor response in strain A mice. Cancer Res 37:2717–2720.872098
Thiyagarajah A, Teuschler LK, Lipscomb JC, 2000. Chronic pathological effects from exposure of Japanese medaka (Oryzias latipes) embryos to bromoform [Abstract]. Toxicologist 54(1):185.
*Thomas JM, McKay WA, Cole E, 2000. The fate of haloacetic acids and trihalomethanes in an aquifer storage and recovery program, Las Vegas, Nevada. Ground Water 38(4):605–614.
*Thornton-Manning JR, Seely JC, Pegram RA. 1994. Toxicity of bromodichloromethane in female rats and mice after repeated oral dosing. Toxicology 94(1–3):3–18.7801327
*Tobe M, Suzuki Y, Aida K, 1982. Studies on the chronic oral toxicity of tribromomethane, dibromochloromethane, and bromodichloromethane. National Institute of Hygienic Sciences, Division of Toxicology, Biological Safety Research Center, 8–43.
*Todoya M, Takagi K, Tsurumizu A, 1990. Estimation of daily intake of four kinds of trihalomethane by Japanese housewives. J Food Saf 10:191–200.
*Tomasi A, Albano E, Biasi F, 1985. Activation of chloroform and related trihalomethanes to free radical intermediates in isolated hepatocytes and in the rat in vivo as detected by the ESR-spin trapping technique. Chem Biol Interact 55:303–316.3000632
TPCDB. 1988. Testing Priority Committee Data Base. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances.
*TRI02. 2004. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access. Office of Environmental Information. U.S. Environmental Protection Agency. Toxic Release Inventory. http://www.epa.gov/triexplorer/.
Trussell RR, Umphres MD. 1978. The formation of trihalomethanes. JAWWA 70:604–612.
*Tyson CA, Prather KH, Story DL, 1983. Correltation of in vitro and in vivo hepatotoxicity for five haloalkanes. Toxicol Appl Pharmacol 70:289–302.6623471
Uhler AD, Means JC. 1985. Reaction of dissolved chlorine with surficial sediment: Oxidant demand and production of trihalomethanes. Environ Sci Technol 19:340–344.22283346
Urhahn T, Ballschmiter K. 2000. Analysis of halogenated C1/C2-trace compounds in marine atmosphere. Fresenius J Anal Chem 366(4):365–367.11220320
*USC. 2003. Hazardous air pollutants. Washington, DC: United States Code. 42 USC 7412. http://www4.law.cornell.edu/uscode.
Van Winkle MR, Scheff PA. 2001. Volatile organic compounds, polycyclic aromatic hydrocarbons, and elements in the air of ten urban homes. Indoor Air 11(1):49–64.11235231
*Varma MM, Ampy FR, Verma K, 1988. In vitro mutagenicity of water contaminants in complex mixtures. J Appl Toxicol 8:243–248.3183290
*Varma MM, Balram A, Katz HM. 1984. Trihalomethanes in ground water systems. J Environ Syst 14:115–126.
Veenstra JN, Schnoor JL. 1980. Seasonal variations in trihalomethane levels in an Iowa river water supply. JAWWA 72:583–590.
*Verschueren K. 2001. Handbook of environmental data on organic chemicals. 2nd ed. New York, NY: Van Nostrand Reinhold Company.
Vieira I, Pasanen M, Raunio H, 1998. Expression of CYP2E1 in human lung and kidney during development and in full-term placenta: A differential methylation of the gene is involved in the regulation process. Pharmacol Toxicol 83:183–187.9834965
*Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238:476–483.8681961
VIEW Database. 1989. Atlanta, GA: Agency for Toxic Substances and Disease Registry (ATSDR), Office of External Affairs, Exposure and Disease Registry Branch.
Villanueva CM, Fernandez F, Malats N, 2003. Meta-analysis of studies on individual consumption of chlorinated drinking water and bladder cancer. J Epidemiol Commun Health 57(3):166–173.
Vogel TM, Criddle CS, McCarty PL. 1987. Transformations of halogenated aliphatic compounds. Environ Sci Technol 21:722–736.19995052
Vogt C, Regli S. 1981. Controlling trihalomethanes while attaining disinfection. JAWWA 73:33–40.
*Von Oettingen WF. 1955. The halogenated aliphatic, olefinic, cyclic, aromatic, and aliphatic-aromatic hydrocarbons including the halogenated insecticides, their toxicity and potential dangers. Washington, DC: U.S. Department of Health, Education and Welfare, Public Health Service, 65–67.
Voronin VM, Donchenko AI, Korolev AA. 1987. An experimental study of the carcinogenicity of dichlorobromomethane and dibromochloromethane released during the water chlorination process. Gig Sanit 0:19–21.
Wackett LP, Logan MS P, Blocki FA, 1992. A mechanical perspective on bacterial metabolism of chlorinated methanes. Biodegradation 3:19–36.
*Walker BL, Cooper CD. 1992. Air pollution emission factors for medical waste incinerators. J Air Waste Manage Assoc 42:784–791.
*Wallace LA. 1997. Human exposure and body burden for chloroform and other trihalomethanes. Crit Rev Environ Sci 27:113–194.
*Wallace LA, Pellizzari ED, Harwell TD, 1986a. Total exposure assessment methodology (TEAM) study: Personal exposures, indoor/outdoor relationships, and breath levels of volatile organic compounds in New Jersey. Environ Int 12:369–387.
Wallace LA, Pellizzari ED, Hartwell TD, 1987. The TEAM study: Personal exposures to toxic substances in air, drinking water, and breath of 400 residents of New Jersey, North Carolina, and North Dakota. Environ Res 43:290–307.3608934
*Wallace LA, Pellizzari ED, Sheldon L, 1986b. The total exposure assessment methodology (TEAM) study: Direct measurement of personal exposures through air and water for 600 residents of several U.S. cities. In: Cohen Y, ed. Pollutants in a multimedia environment. New York, NY: Plenum Publishing Corporation, 289–315.
*Waller K, Swan SH, Delorenze G, 1999. Trihalomethanes in drinking water and spontaneous abortion. Epidemiology 10(2):203–204.10069263
*Walters SM. 1986. Cleanup of samples. In: Zweig G, Sherma J, eds. Analytical methods for pesticides and plant growth regulators. Vol. 15: Principles, statistics, and applications. New York, NY: Academic Press Inc., 67–110.
Wang PY, Kaneko T, Tsukada H, 1994. Dose and route dependency of metabolism and toxicity on chloroform in ethanol-treated rats. Arch Toxicol 69(1):18–23.7717850
Washall JW, Wampler TP. 1988. Purge and trap analysis of aqueous samples with cryofocusing. American Laboratory (July 1988):70–74.
Washington JW. 1996. Gas portioning of dissolved volatile organic compounds in the vadose zone: Principles, temperature effect, and literature review. Ground Water 34(4):709–717.
Weast RC, ed. 1985. CRC handbook of chemistry and physics. 66th ed. Boca Raton, FL: CRC Press, Inc.
*Weisel CP, Kim H, Haltmeirer P, 1999. Exposure estimates to disinfection by-products of chlorinated drinking water. Environ Health Perspect 107:103–110.9924004
*Weiss WJ, Bouwer EJ, Ball EJ, 2003. Riverbank filtration- fate of DCP precursors and selected microorganisms. J Am Water Works Assoc 95(10):68–81.
*West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
*Westerhoff P, Chao P, Mash H. 2004. Reactivity of natural organic matter with aqueous chlorine and bromine. Water Res 38(6):1502–1513.15016527
*Westrick JJ, Mellow JW, Thomas RF. 1984. The groundwater supply survey. JAWWA 76:52–59.
Wever R, Tromp MG M, Krenn BE, 1991. Brominating activity of the seaweed Ascophyllum nodosum: Impact on the biosphere. Environ Sci Technol 25(3):446–449.
WHO. 1984. Guidelines for drinking-water quality. Vol. 2: Health criteria and other supporting information. Geneva, Switzerland: World Health Organization, 240–246.
*WHO. 1996. Guidelines for drinking water quality. Geneva, Switzerland: World Health Organization. http://www.who.int/en/.
*Widdowson EM, Dickerson JW T. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise. Volume II: The elements Part A. New York: Academic Press.
Wilkins JR, Comstock GW. 1981. Source of drinking water at home and site-specific cancer incidence in Washington County, Maryland. Am J Epidemiol 114:178–190.7304553
Williams DT, Benoit FM, Lebel GL. 1998. Trends in levels of disinfection by-products. Environmetrics 9:555–563.
Williams DT, Nestman ER, LeBel GL, 1982. Determination of mutagenic potential and organic contaminants of Great Lakes drinking water. Chemosphere 11:263–276.
*Windham GC, Waller K, Anderson M, 2003. Chlorination by-products in drinking water and menstrual cycle function. Environ Health Perspect 111(7):935–941.12782495
Withey JR, Karpinski K. 1985. The fetal distribution of some aliphatic chlorinated hydrocarbons in the rat after vapor phase exposure. Biol Res Pregnancy 6:79–88.
*Withey JR, Collins BT, Collins PG. 1983. Effect of vehicle on the pharmacokinetics and uptake of four halogenated hydrocarbons from the gastrointestinal tract of the rat. J Appl Toxicol 3:249–253.6662999
*Woodruff RC, Mason JM, Valencia R, 1985. Chemical mutagenesis testing in Drosophila. V. Results of 53 coded compounds tested for the National Toxicology Program. Environ Mutagen 7:677–702.3930237
*Xu X, Mariano TM, Laskin JD, 2002. Percutaneous absorption of trihalomethanes, haloacetic acids, and haloketones. Toxicol Appl Pharmacol 184(1):19–26.12392965
Yamazaki H, Yamaguchi T, Yamauchi A, 1992. Effect of halogenated and styrene on thrombin and calcium ionophore induced activation of rabbit platelets. Chemosphere 25(5):665–673.
Yoshikawa K. 1996. Anomalous nonidentity between Salmonella genotoxicants and rodent carcinogens and genotoxic noncarcinogens. Environ Health Perspect 104(1):40–46.8834860
Young TB. 1981. Epidemiologic study of drinking water chlorination and Wisconsin female cancer mortality. J Natl Cancer Inst 67:1191–1198.6947104
Young TB, Wolf DA, Kanarek MS. 1987. Case-control study of colon cancer and drinking water trihalomethanes in Wisconsin. Int J Epidemiol 16(2):190–197.3610446
Zakhari S, Aviado DM. 1982. Cardiovascular toxicology of aerosol propellants, refrigerants, and related solvents. In: Van Stee EW, ed. Cardiovascular toxicology. New York, NY: Raven Press, 281–326.
*Zeiger E, Anderson B, Haworth S, 1987. Salmonella mutagenicity tests: III. Results from the testing of 255 chemicals. Environ Mutagen 9(Suppl 9):1–110.
*Ziegler EE, Edwards BB, Jensen RL, 1978. Absorption and retention of lead by infants. Pediatr Res 12:29–34.643372
*Zielinska B, Fujita E, Sagebiel J, 1998. Arizona hazardous air pollutants monitoring program. J Air Waste Manage Assoc 48:1038–1050.
*Zielinska B, Sagebiel J, Hashfield G, 2001. Volatile organic compound measurements in the California/Mexico border region during SCOS97. Sci Total Environ 26(1–3):19–31.
Zierler S, Danley RA, Feingold L. 1986. Type of disinfectant in drinking water and patterns of mortality in Massachusetts. Environ Health Perspect 69:275–279.3816730
Zierler S, Feingold RA, Danley RA, 1988. Bladder cancer in Massachusetts related to chlorinated and chloraminated drinking water: A case-control study. Arch Environ Health 43(2):195–200.3377557
*Zlatkis A, Kim K. 1976. Column elution and concentration of volatile compounds in biological fluids. J Chromatogr 126:475–485.977691
Zoeteman CJ, DeGreef E, Brinkman FJ J. 1981. Persistency of organic contaminants in groundwater, lessons from soil pollution incidents in The Netherlands. Sci Total Environ 21:187–202.