# 8 REGULATIONS AND ADVISORIES

The international, national, and state regulations and guidelines regarding bromoform and dibromochloromethane in air, water, and other media are summarized in Table 8-1.

An acute-duration oral MRL of 0.7 mg/kg/day has been derived for bromoform. This MRL is based on a NOAEL of 72 mg/kg/day and a LOAEL of 145 mg/kg/day for centrilobular pallor in mice receiving gavage doses of bromoform for 14 days (Condie et al. 1983). The MRL was derived by dividing the NOAEL by an uncertainty factor of 100 (10 for animal to human extrapolation and 10 for human variability).

An intermediate-duration oral MRL of 0.2 mg/kg/day has been derived for bromoform. This MRL is based on a NOAEL of 50 mg/kg for hepatocellular vacuolization in rats administered gavage doses of bromoform in corn oil 5 days/week for 13 weeks (NTP 1989a). The MRL was derived by dividing the duration adjusted NOAEL of 18 mg/kg/day by an uncertainty factor of 100 (10 for animal to human extrapolation and 10 for human variability).

A chronic-duration oral MRL of 0.02 mg/kg/day has been derived for bromoform. This MRL is based on a LOAEL of 100 mg/kg for hepatocellular vacuolization in rats administered gavage doses of bromoform in corn oil 5 days/week for 2 years (NTP 1989a). The MRL was derived by dividing the duration adjusted LOAEL of 71 mg/kg/day by an uncertainty factor of 300 (3 for use of a minimal LOAEL, 10 for animal to human extrapolation, and 10 for human variability) and a modifying factor of 10 to account for the identification of a lower LOAEL in a 13-week study (NTP 1989a).

An acute-duration oral MRL of 0.1 mg/kg/day has been derived for dibromochloromethane. This MRL is based on a LOAEL of 37 mg/kg for hepatocellular vacuolization in mice administered gavage doses of dibromochloromethane in corn oil for 14 days (Condie et al. 1983). The MRL was derived by dividing the LOAEL by an uncertainty factor of 300 (3 for use of a minimal LOAEL, 10 for animal to human extrapolation, and 10 for human variability).

A chronic-duration oral MRL of 0.09 mg/kg/day has been derived for dibromochloromethane. This MRL is based on a LOAEL of 40 mg/kg for fatty changes in the liver of rats administered gavage doses of dibromochloromethane in corn oil for 2 years (NTP 1985). The MRL was derived by dividing the duration-adjusted LOAEL of 28 mg/kg/day by an uncertainty factor of 300 (3 for use of a minimal LOAEL, 10 for animal to human extrapolation, and 10 for human variability).

Table 8-1 Regulations and Guidelines Applicable to Bromoform and Dibromochloromethane

Agency | Description | Information | | Reference
[underlined: INTERNATIONAL]
Guidelines:
IARC | Carcinogenicity classification | | | IARC 1999a, 1999b
| Bromoform | Group 3^a^
| Dibromochloromethane | Group 3^a^
WHO | Drinking water guideline | | | WHO 1996
| Bromoform | 100 mg/L
| Dibromochloromethane | 100 mg/L
[underlined: NATIONAL]
Regulations and Guidelines:
a. Air:
ACGIH | TLV (8-hour TWA) | | | ACGIH 2003
| Bromoform^b^ | 0.5 ppm
NIOSH | REL (10-hour TWA) | | | NIOSH 2003
| Bromoform^c^ | 0.5 ppm
| IDLH | 850 ppm
OSHA | PEL (8-hour TWA) for general industry | | | OSHA 2003a; 29 CFR 1910.1000, Table Z-1
| Bromoform^d^ | 0.5 ppm | | OSHA 2003a; 29 CFR 1910.1000, Table Z-1
| PEL (8-hour TWA) for construction industry | | | OSHA 2003c; 29 CFR 1926.55, Appendix A
| Bromoform^d^ | 0.5 ppm | | OSHA 2003c; 29 CFR 1926.55, Appendix A
| PEL (8-hour TWA) for shipyard industry | | | OSHA 2003b; 29 CFR 1915.1000
| Bromoform^d^ | 0.5 ppm
USC | Hazardous air pollutant | Bromoform | | USC 2003
b. Water
EPA | Drinking water health advisories | | | EPA 2002a, 2002b
| Bromoform
| 1-day (10-kg child) | 5.0 mg/L
| 10-day (10-kg child) | 2.0 mg/L
| DWEL^e^ | 0.7 mg/L
| 10^−4^ Cancer risk^f^ | 0.4 mg/L
| Dibromochloromethane
| 1-day (10-kg child) | 6.0 mg/L
| 10-day (10-kg child) | 6.0 mg/L
| DWEL^e^ | 0.7 mg/L
| Lifetime^g^ | 0.06 mg/L
| 10^−4^ Cancer risk^f^ | 0.04 mg/L
| Effluent guidelines and standards; toxic pollutants pursuant to Section 307 (a)(1) of the Clean Water Act | Bromoform | | EPA 2003c; 40 CFR 401.15
EPA | National primary drinking water regulations | | | EPA 2003f; 40 CFR 141.12
| MCL for total trihalomethanes^h^ | 0.10 mg/L
| Pollutants of initial focus in the Great Lakes Water Quality Initiative | Bromoform and dibromochloromethane | | EPA 2003m; 40 CFR 132, Table 6
c. Food
FDA | Bottled drinking water allowable concentrations for total trihalomethanes^i^ | 0.10 mg/L | | FDA 2003; 21 CFR 165.110
d. Other
ACGIH | Carcinogenicity classification | A3^j^ | | ACGIH 2003; IRIS 2004a,2004b
EPA | Carcinogenicity classification | | | ACGIH 2003; IRIS 2004a,2004b
| Bromoform | B2^k^
| Dibromochloromethane | C^l^
| RfC | No data | | IRIS 2004a, 2004b
| RfD | | | IRIS 2004a, 2004b
| Bromoform | 2.0×10^−2^ mg/kg/day
| Dibromochloromethane | 2.0×10^−2^ mg/kg/day
| Community right-to-know; release report; effective date of reporting | | | EPA 2003i; 40 CFR 372.65
| Bromoform | 01/01/87
| Identification and listing of hazardous waste; hazardous waste number | | | EPA 2003d; 40 CFR 261, Appendix VIII
| Bromoform | U225
| Land disposal restrictions; universal treatment standards | [underlined: Waste water (mg/L)] | [underlined: Non-waste water mg/kg)] | EPA 2003e; 40 CFR 268.48
| Bromoform | 0.63 | 15
| Dibromochloromethane | 0.57 | 15
| Municipal solid waste landfills; hazardous constituents | [underlined: Suggested method] | [underlined: PQL (μg/L)] | EPA 2003a; 40 CFR 258, Appendix II
| Bromoform | 8010 | 2 | EPA 2003a; 40 CFR 258, Appendix II
| | 8021 | 15
| | 8260 | 5
| Dibromochloromethane | 8010 | 1
| | 8021 | 0.3
| | 8260 | 5
| Reportable quantity of hazardous substance in accordance with Section 307 (a) of the Clean Water Act, Section 112 of RCRA, and Section 112 of the Clean Air Act | | | EPA 2003b; 40 CFR 302.4
| Bromoform | 100 pounds
EPA | Reportable quantity of hazardous substance in accordance with Section 112 of RCRA | | | EPA 2003b; 40 CFR 302.4
| Dibromochloromethane | 100 pounds
| Standards for the management of specific hazardous waste and types of hazardous waste management facilities | | | EPA 2003g; 40 CFR 266, Appendix V
| Standards for the management of specific hazardous waste and types of hazardous waste management facilities | [underlined: Risk specific doses]
| Bromoform | 7.0×10^−1^ μg/m^3^
| Standards for owners or operators of hazardous waste TSD facilities; maximum concentration for groundwater protection | | | EPA 2003h; 40 CFR 264, Appendix IX
| Standards for owners or operators of hazardous waste TSD facilities; maximum concentration for groundwater protection | [underlined: Suggested method] | [underlined: PQL (μg/L)] | EPA 2003h; 40 CFR 264, Appendix IX
| Bromoform | 8010 | 2
| | 8240 | 5
| Dibromochloromethane | 8010 | 1
| | 8240 | 5
| TSCA; chemical information rules | [underlined: Effective date] | [underlined: Sunset date] | EPA 2003k; 40 CFR 712.30
| Bromoform | 03/11/94 | 05/10/94
| TSCA; health and safety data reporting | [underlined: Effective date] | [underlined: Sunset date] | EPA 2003j; 40 CFR 716.120
| Bromoform | 06/01/87 | 06/01/97
| Dibromochloromethane | 06/01/87 | 06/01/87
| TSCA; identification of specific chemical substance and mixture testing requirements for | | | EPA 2003l; 40 CFR 799.5055
| Bromoform | Hydrolysis testing
[underlined: STATE]
a. Air | No data
b. Water
Arizona | Drinking water guideline | | | HSDB 2004a, 2004b
| Bromoform | 0.19 μg/L
| Dibromochloromethane | 0.19 μg/L
Florida | Drinking water guideline | | | HSDB 2004a, 2004b
| Bromoform | 4.0 μg/L
| Dibromochloromethane | 1.0 μg/L
Minnesota | Drinking water guideline | | | HSDB 2004a, 2004b
| Bromoform | 40 μg/L
| Dibromochloromethane | 10 μg/L
New Hampshire | Drinking water guideline | | | HSDB 2004a
| Bromoform | 4.0 μg/L
Wisconsin | Drinking water guideline | | | HSDB 2004a, 2004b
| Bromoform | 4.4 μg/L
| Dibromochloromethane | 60 μg/L
c. Food | No data
d. Other | No data

a Group 3: not classifiable as to its carcinogenicity to humans

b Skin notation: refers to the potential significant contribution to the overall exposure by the cutaneous route, including mucous membranes and the eyes, either by contact with vapors or, of probable greater significance, by direct skin contact with the substance.

c Skin designation: indicates the potential for dermal absorption; skin exposure should be prevented as necessary through the use of good work practices and gloves, coveralls, goggles, and other appropriate equipment.

d Skin designation

e DWEL: a lifetime exposure concentration protection of adverse, non-cancer health effects, that assumes all of the exposure to a contaminant is from drinking water.

f 10^−2^ Cancer risk: the concentration of a chemical in drinking water corresponding to an excess estimated lifetime cancer risk of 1 in 10,000.

g Lifetime: the concentration of a chemical in drinking water that is not expected to cause any adverse noncarcinogenic effects for a lifetime of exposure. The Lifetime HA is based on exposure of a 70-kg adult consuming 2 L water/day.

h Total trihalomethanes (the sum of the concentrations of bromoform, dibromochloromethane, bromodichloromethane, and chloroform) applies to subpart H community water systems which serve a population of 10,000 people or more until December 31, 2001. This level applies to community water systems that use only groundwater not under the direct influence of surface water and serves a population of 10,000 people or more until December 31, 2003. Compliance with the MCL for total trihalomethanes is calculated pursuant to 40 CFR 141.30. After December 31, 2003, this section no longer applies.

i Total trihalomethanes: sum of the concentration in mg/L of the trihalomethane compounds (bromoform, dibromochloromethane, bromodichloromethane, and chloroform), rounded to two significant figures.

j A3: confirmed animal carcinogen with unknown relevance to humans

k B2: probable human carcinogen

l C: possible human carcinogen

ACGIH = American Conference of Governmental Industrial Hygienists; CFR = Code of Federal Regulations; DWEL = drinking water equivalent level; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; HSDB = Hazardous Substances Data Bank; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; MCL = maximum contaminant level; NIOSH = National Institute for Occupational Safety and Health; OSHA = Occupational Safety and Health Administration; PEL = permissible exposure limit; PQL = practical quantitation level; RCRA = Resource Conservation and Recovery Act; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TLV = threshold limit values; TSCA = Toxic Substances Control Act; TSD = treatment, storage, and disposal; TWA = time-weighted average; USC = United States Code; WHO = World Health Organization