# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity of bromoform and dibromochloromethane is located in Table 4-1.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of bromoform and dibromochloromethane is located in Table 4-2.

Table 4-1 Chemical Identity of Bromoform and Dibromochloromethane

Characteristic | Bromoform | Dibromochloromethane | Reference
Synonyms | Tribromomethane; methenyltribromide; methane, tribromo- | Chlorodibromomethane dibromochloromethane; methane, dibromochloro-; methane, chlorodibromo- | HSDB 2004a, 2004b
Registered trade name(s) | No data | No data
Chemical formula | CHBr_3_ | CHBr_2_Cl | O’Neil et al. 2001
Chemical structure | [image] | [image]
Identification numbers:
CAS registry | 75-25-2 | 124-48-1 | O’Neil et al. 2001
NIOSH RTECS | PB5600000 | PA6360000 | RTECS 2003
EPA hazardous waste | U225 | No data | RTECS 2003
OHM/TADS | No data | No data | HSDB 2004a, 2004b
DOT/UN/NA/IMCO shipping | UN2515; IMCO 6.1 | No data | HSDB 2004a, 2004b
HSDB | 2517 | 2763 | HSDB 2004a, 2004b
NCI | C55130 | C55254 | RTECS 2003
Beilstein reference number | 1731048 | 1731046 | RTECS 2003
Beilstein handbook reference | 4-01-00-00082 | 4-01-00-0081 | RTECS 2003
Wisesser line notation | EYEE | GYEE | RTECS 2003

CAS = Chemical Abstracts Service; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of Bromoform and Dibromochloromethane

Property | Bromoform | Dibromochloromethane | Reference
Molecular weight | 252.73 | 208.28 | O’Neil et al. 2001
Color | Colorless | Colorless to pale yellow | Verschueren 2001
Physical state | Liquid | Liquid | Verschueren 2001
Melting point | 8.0 °C | −20 °C | Lide 2000
Boiling point | 149.1 °C | 120 °C | Lide 2000
Density at 20 °C | 2.899 | 2.451 | Lide 2000
Odor | Sweet, similar to chloroform | No data | Verschueren 2001
Taste | Similar to chloroform | No data | Lewis 1997
Odor threshold:
Water | 0.51 mg/L | No data | Amoore and Hautala 1983
Air | 13.45 mg/m^3^ | No data | Amoore and Hautala 1983
Solubility:
Water | 3.10×10^3^ mg/L (25 °C) | 2.7×10^3^ mg/L (20 °C) | Horvath 1982; Heikes 1987
Organic solvents | Miscible in ethanol, benzene, petroleum ether, acetone, oils | Soluble in ethanol, ether, acetone | Lide 2000
Corrosivity | Will attack some forms of plastics, rubber, and coatings. | No data | HSDB 2004a
Partition coefficients:
Log octanol/water | 2.4 | 2.16 | CITI 1992; Sangster 1994
Log K_oc_ | 2.06 | 1.92 | Mabey et al. 1982
Vapor pressure at 20 °C | 5 mmHg | 76 mmHg | Mabey et al. 1982
Vapor density | 8.7 (air=1) | No data | IARC 1991a, 1991b
Henry’s law constant | 5.6×10^−4^ atm-m^3^/mol | 9.9×10^−4^ atm-m^3^/mol | Mabey et al. 1982
Surface tension | 41.53 dynes/cm | No data | Lewis 1997
Heat of vaporization | 46.05 KJ/mol (25 °C) | No data | Lide 2000
Autoignition temperature | No data | No data
Flashpoint | No data | No data
Flammability limits | Non-flammable | Non-flammable | HSDB 2004a, 2004b
Conversion factor | 1 ppm = 10.34 mg/m^3^; 1 mg/m^3^ = 0.097 ppm | 1 ppm = 8.52 mg/m^3^; 1 mg/m^3^ = 0.12 ppm | IARC 1999a, 1999b