# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-32, Atlanta, Georgia 30333.

## Bromoform Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Bromoform
CAS Number: | 75-25-2
Date: | August 2005
Profile Status: | Final Draft of Post-Public Comment Toxicological Profile
Route: | [ ] Inhalation [X] Oral
Duration: | [X] Acute [ ] Intermediate [ ] Chronic
Key to Figure: | 13
Species: | Mice

[underlined: Minimal Risk Level]: 0.7 [X] mg/kg/day [ ] mg/m^3^

[underlined: Reference]: Condie LW, Smallwood CL, Laurie RD. 1983. Comparative renal and hepatotoxicity of halomethanes: Bromodichloromethane, bromoform, chloroform, dibromochloromethane and methylene chloride. Drug Chem Toxicol 6:563–578.6653442

[underlined: Experimental design]:

Groups of 5–16 male CD-1 mice received daily gavage doses of 0, 72, 145, or 289 mg/kg/day bromoform in corn oil for 14 days. Body weight was measured on days 1 and 14. Blood was collected for clinical chemistry at study termination. Renal cortical slices of kidney tissue were collected for measurement of para-aminohippurate (PAH) uptake, and samples of liver and kidney tissue were collected for histopathological examination.

[underlined: Effects noted in study and corresponding concentrations]:

No significant alterations in body weight gain were observed. PAH uptake by kidney slices was decreased by 30% in the 289 mg/kg/day group; a significant increase in SGPT was also observed at this dose. Minimal to moderate liver and kidney histological alterations were observed. Liver effects included centrilobular pallor at 145 and 289 mg/kg/day and focal inflammation at 289 mg/kg/day. Kidney effects consisted of epithelial hyperplasia at 289 mg/kg/day and mesangial nephrosis at 145 and 289 mg/kg/day.

[underlined: Concentration and end point used for MRL derivation]:

The MRL is based on a NOAEL of 72 mg/kg/day and a LOAEL of 145 mg/kg/day for hepatice centrilobular pallor in mice.

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?] No.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent concentration]: NA

[underlined: Was a conversion used from intermittent to continuous exposure?] No.

[underlined: Other additional studies or pertinent information that lend support to this MRL]:

Several acute-duration studies support the identification of the liver as the most sensitive target of bromoform toxicity. The observed effects include hepatocellular vacuolization and swelling (Chu et al. 1982a; Coffin et al. 2000), centrilobular pallor (Condie et al. 1983), increased absolute and relative liver weights (Munson et al. 1982), alterations in serum chemistry enzymes such as SGPT (Munson et al. 1982), and impaired liver function (Munson et al. 1982). The highest NOAEL for liver effects is 72 mg/kg/day in mice (Condie et al. 1983); in this study, centrilobular pallor (Condie et al. 1983), which was considered to be indicative of liver degeneration, was observed at 145 mg/kg/day. At 125 mg/kg/day, increases in liver weight were observed (Munson et al. 1982) and hepatocellular vacuolization and swelling were observed at 200 mg/kg (164 mg/kg/day) (Coffin et al. 2000). Other adverse effects that have been observed at similar or higher dose levels include mesangial nephrosis at 145 mg/kg/day (NOAEL of 72 mg/kg/day) (Condie et al. 1983), impaired immune function at 125 mg/kg/day (NOAEL of 50 mg/kg/day) (Munson et al. 1982), skeletal anomalies in the offspring of rats exposed to 200 mg/kg/day (NOAEL of 100 mg/kg/day) (Ruddick et al. 1983), and central nervous system depression at ≥600 mg/kg (Balster and Borzelleca 1982; Bowman et al. 1978; NTP 1989a). Although several adverse effects have been reported at 100–200 mg/kg/day, the liver was selected as the critical target because the adverse liver effects are consistently observed in animals following acute-, intermediate-, and chronic-duration exposure.

[underlined: Agency Contact (Chemical Managers)]: John Risher, Dennis Jones

## Bromoform Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Bromoform
CAS Number: | 75-25-2
Date: | August 2005
Profile Status: | Final Draft of Post-Public Comment Toxicological Profile
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Key to Figure: | 26
Species: | Rat

[underlined: Minimal Risk Level]: 0.2 [X] mg/kg/day [ ] mg/m^3^

[underlined: Reference]: NTP. 1989a. Toxicology and carcinogenesis studies of tribromomethane (bromoform) in F344/N rats and B6C3F1 mice (gavage studies). National Toxicology Program. Technical Report Series No. 350. Research Triangle Park, NC: U.S. Department of Health and Human Services.

[underlined: Experimental design]:

Groups of F344/N male and female F344/N rats (10/sex/group) received gavage doses of 0, 12, 25, 50, 100, or 200 mg/kg bromoform in corn oil 5 days/week for 13 weeks. The rats were observed twice per day and weighed weekly. At sacrifice, all animals were necropsied and tissues from the vehicle control and high dose groups were examined histologically.

[underlined: Effects noted in study and corresponding concentrations]:

None of the rats died before the end of the study. Final mean body weights were similar in dosed and control groups. Lethargy was observed in all male rats exposed to 100 or 200 mg/kg and in all females exposed to 200 mg/kg. Hepatocellular vacuolization was observed in male rats (3/10, 6/10, 5/10, 8/10, 8/10, and 10/10 in the 0, 12, 25, 50, 100, and 200 mg/kg groups, respectively); the response reached statistical significance (Fisher exact one-tailed p-value of 0.03) at 50 mg/kg/day. Severity data were not reported for this lesion, but the study authors noted that vacuoles were more numerous in the 200 mg/kg group. Corresponding hepatic effects were not observed in females.

[underlined: Concentration and end point used for MRL derivation]:

The MRL is based on a NOAEL of 25 mg/kg (duration-adjusted to 18 mg/kg/day) and a LOAEL of 50 mg/kg (duration-adjusted to 36 mg/kg/day) for hepatic lesions (hepatocellular vacuolization).

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?] No.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent concentration]: NA

Was a conversion used from intermittent to continuous exposure?

The NOAEL was adjusted for intermittent exposure: 25 mg/kg × 5 days/7 days = 18 mg/kg/day

[underlined: Other additional studies or pertinent information that lend support to this MRL]:

A number of animal studies have identified the liver as the critical target of bromoform oral toxicity. An intermediate-duration study in rats (Aida et al. 1992) supports the identification of 50 mg/kg as the critical dose. In this study, a LOAEL of 56.4 mg/kg/day was identified for hepatocellular vacuolization and swelling in rats exposed to bromoform in the diet for 1 month. At a higher dose (207.5 mg/kg/day), a decrease in serum triglycerides and an increase in serum cholesterol levels were found; these findings are consistent with the liver histological alterations. Mice appear to be less sensitive to the toxicity of bromoform than rats. NOAEL and LOAEL values of 100 and 200 mg/kg (5 days/week) for hepatocellular vacuolization were identified in the intermediate-duration mouse NTP study (NTP 1989a). Melnick et al. (1998) found hydropic degeneration and increases in SGPT and sorbitol dehydrogenase levels in mice receiving gavage doses of 500 mg/kg, 5 days/week for 3 weeks. Acute- and chronic-duration studies have also identified the liver as the most sensitive target of toxicity.

[underlined: Agency Contact (Chemical Managers)]: John Risher, Dennis Jones

## Bromoform Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Bromoform
CAS Number: | 75-25-2
Date: | September 2005
Profile Status: | Final Draft of Post-Public Comment Toxicological Profile
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [ ] Intermediate [X] Chronic
Key to Figure: | 38
Species: | Rat

[underlined: Minimal Risk Level]: 0.02 [X] mg/kg/day [ ] mg/m^3^

[underlined: Reference]: NTP. 1989a. Toxicology and carcinogenesis studies of tribromomethane (bromoform) in F344/N rats and B6C3F1 mice (gavage studies). National Toxicology Program. Technical Report Series No. 350. Research Triangle Park, NC: U.S. Department of Health and Human Services.

[underlined: Experimental design]:

Groups of male and female F344/N rats (50/sex/group) were administered via gavage 0, 100, or 200 mg/kg bromoform in corn oil 5 days/week for 103 weeks. Animals were observed for clinical signs throughout the study. Body weights were measured weekly for 12 weeks and monthly thereafter. At termination, all study animals were necropsied. Full histopathological examination was performed on all control and high dose animals and on low dose males. Selected tissues including esophagus, gross lesions, kidney, liver, lymph nodes, mammary gland, pancreas, pituitary gland, salivary glands, thyroid gland, trachea, and uterus were examined in low-dose females.

[underlined: Effects noted in study and corresponding concentrations]:

Significantly increased mortality was observed in male rats exposed to 200 mg/kg after week 91 (36–78% vs. 26–32%). Survival was comparable to vehicle controls in males exposed to 100 mg/kg and in females exposed to 100 or 200 mg/kg. Bromoform-related clinical signs included lethargy in both sexes and aggressiveness in males. After 15 weeks, the difference between control body weights and body weights of males exposed to 200 mg/kg males was consistently ≥10%; terminal body weights were 21% lower than controls. In the females exposed to 200 mg/kg, the difference in body weights was ≥10% after week 41; terminal body weights were 25% lower than controls. Body weights in the 100 mg/kg groups were typically within 10% of controls. Bromoform-related hepatic lesions included fatty change (characterized as hepatocellular vacuolization) in 23/50, 49/50, and 50/50 males exposed to 0, 100, or 200 mg/kg, respectively, and 19/50, 39/49, and 46/50 females; chronic active inflammation (male: 0/50, 29/50, and 23/50; female: 9/50, 8/49, and 27/50); and necrosis (male: 7/50, 3/50, and 20/50; female: 11/50, 3/49, and 2/50). Other lesions with significantly increased incidences included salivary gland duct squamous metaplasia at 100 and 200 mg/kg (males: 0/50, 15/50, and 31/48; females: 0/49, 10/49, and 16/50) and chronic active inflammation (male: 0/50, 14/50, and 22/48; female: 0/49, 9/49, and 18/50); ulcers of the forestomach in males at 200 mg/kg (1/49, 5/50, and 10/50); chronic active inflammation in the lungs in males at 100 and 200 mg/kg (1/50, 7/50, and 15/50); squamous metaplasia in the prostate gland at 200 mg/kg (2/49, 6/46, and 12/50); hyperplasia of the anterior lobe of the pituitary gland in males at 100 mg/kg (9/48, 26/50, and 15/50); and spleen pigmentation in females at 200 mg/kg (7/49, 6/28, and 29/50), which was characteristic of hemosiderin. The occurrence of ulcers in the forestomach may have resulted from gavage bolus dose delivery. Lesions observed in the lungs and salivary glands were reported to be consistent with infection by sialodacryloadenitis (SDA) virus. However, since the occurrence of these lesions was clearly dose-related, the study authors concluded that they were likely to represent a combination of viral and chemical-related effects.

It should be noted that the study authors did not report statistical analysis data for nonneoplastic lesions. An independent statistical analysis was conducted; statistical significance was determined using a Fisher exact test, one tailed p<0.05).

[underlined: Concentration and end point used for MRL derivation]:

The MRL is based on a LOAEL of 100 mg/kg (duration-adjusted to 71 mg/kg/day) for histopathological changes (vacuolization) in the liver.

[ ] NOAEL [X] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [X] 3 for use of a minimal LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

Modifying Factors used in MRL derivation:

- [X] 10 to account for the identification of a lower LOAEL in the 13-week NTP (1989a) study.

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?] No.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent concentration]: NA

[underlined: Was a conversion used from intermittent to continuous exposure?] Yes.

The LOAEL was adjusted for intermittent exposure: 100 mg/kg × 5 days/7 days = 71 mg/kg/day

[underlined: Other additional studies or pertinent information that lend support to this MRL]:

Two studies have examined the chronic toxicity of bromoform (NTP 1989a; Tobe et al. 1982). Both studies identified the liver as the most sensitive target of toxicity. Both the NTP (1989a) rat and mouse studies identified LOAEL values of 100 mg/kg (5 days/week) for hepatocellular vacuolization. The rat study was selected over the mouse study because the effects were observed in both sexes. This study is supported by a 2-year dietary study conducted by Tobe et al. (1982). Yellowing of the liver and increases in absolute and liver weights were observed in female rats exposed to 140 mg/kg/day; histological examinations were not conducted. Alterations in several clinical chemistry parameters are also indicative of liver damage. Increases in SGOT and SGPT and decreases in serum triglycerides and cholesterol were observed at 590–720 mg/kg/day. A number of intermediate-duration studies (Aida et al. 1992; Chu et al. 1982b; Melnick et al. 1998; NTP 1989a) support the identification of the liver as the critical target of bromoform toxicity.

[underlined: Agency Contact (Chemical Managers)]: John Risher, Dennis Jones

## Dibromochloromethane Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Dibromochloromethane
CAS Number: | 124-48-1
Date: | August 2005
Profile Status: | Final Draft of Post-Public Comment Toxicological Profile
Route: | [ ] Inhalation [X] Oral
Duration: | [X] Acute [ ] Intermediate [ ] Chronic
Key to Figure: | 16
Species: | Mouse

[underlined: Minimal Risk Level]: 0.1 [X] mg/kg/day [ ] mg/m^3^

[underlined: Reference]: Condie LW, Smallwood CL, Laurie RD. 1983. Comparative renal and hepatotoxicity of halomethanes: Bromodichloromethane, bromoform, chloroform, dibromochloromethane and methylene chloride. Drug Chem Toxicol 6:563–578.6653442

[underlined: Experimental design]:

Groups of 5–16 male CD-1 mice received daily gavage doses of 0, 37, 74, or 147 mg/kg/day dibromochloromethane in corn oil for 14 days. Body weight was measured on days 1 and 14. Blood was collected for clinical chemistry at study termination. Renal cortical slices of kidney tissue were collected for measurement of para-aminohippurate uptake, and samples of liver and kidney tissue were histopathological examination.

[underlined: Effects noted in study and corresponding concentrations]:

No deaths or treatment-related clinical signs were reported. No significant alterations in body weight gain were observed. Para-aminohippurate uptake by kidney slices was decreased by approximately 30% in the 147 mg/kg/day group; a significant increase in SGPT was also observed at this dose. Minimal to moderate liver and kidney histological alterations were observed. Liver effects included hepatocellular vacuolization at 37 mg/kg/day and higher (1/16, 3/5, 4/10, and 8/10 in the 0, 37, 74, and 147 mg/kg/day groups, respectively) and mitotic figures at 147 mg/kg/day (0/16, 0/5, 2/10, and 4/10). Kidney effects consisted of mesangial hypertrophy was observed at 37 mg/kg/day and higher (0/16, 4/5, 7/10, and 7/10).

[underlined: Concentration and end point used for MRL derivation]:

The MRL is based on a LOAEL of 37 mg/kg/day for hepatocellular vacuolization (Condie et al. 1983).

[ ] NOAEL [X] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [X] 3 for use of a minimal LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? No.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent concentration]: NA

[underlined: Was a conversion used from intermittent to continuous exposure?] No.

[underlined: Other additional studies or pertinent information that lend support to this MRL]:

There are numerous studies that support the identification of the liver as the critical target of dibromochloromethane toxicity. Hepatocellular vacuolization and/or swelling were observed in mice exposed to 100 and 300 mg/kg (9 doses in an 11-day period) (Coffin et al. 2000), at ≥50 mg/kg in rats and mice exposed to dibromochloromethane for an intermediate duration (Aida et al. 1992; Daniel et al. 1990; NTP 1985) and in rats and mice exposed to ≥40 for 2 years (NTP 1985). At higher doses, hepatocellular necrosis is observed (Aida et al. 1993; Daniel et al. 1990; NTP 1985) in rats and mice exposed to ≥100 mg/kg for intermediate durations.

The Condie et al. study (1983) also identified the 37 mg/kg/day dose as a LOAEL for kidney effects, mesangial cell hyperplasia. Other animal studies have also found kidney lesions following oral exposure to dibromochloromethane. Nephropathy, characterized by tubular cell degeneration and tubular cast formation was noted in 80% of male rats and 100% of female rats, but was not found in the controls or other dose groups exposed to dibromochloromethane in corn oil for 13 weeks (NTP 1985). The liver was selected as the critical target because the results of other studies suggest that it may be the more sensitive target of toxicity.

[underlined: Agency Contact (Chemical Managers)]: John Risher, Dennis Jones

## Dibromochloromethane Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Dibromochloromethane
CAS Number: | 124-48-1
Date: | August 2005
Profile Status: | Final Draft of Post-Public Comment Toxicological Profile
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [ ] Intermediate [X] Chronic
Key to Figure: | 46
Species: | Rat

[underlined: Minimal Risk Level]: 0.09 [X] mg/kg/day [ ] mg/m^3^

[underlined: Reference]: NTP. 1985. Toxicology and carcinogenesis studies of dibromochloromethane in F344/N rats and B6C3F1 mice (gavage studies). National Toxicology Program. Technical Report Series No. 282. Research Triangle Park, NC: U.S. Department of Health and Human Services.

[underlined: Experimental design]:

Groups of 50 male and 50 female F344/N rats received 0, 40, or 80 mg/kg gavage doses of dibromochloromethane in corn oil 5 days/week for 2 years. Clinical signs were recorded weekly. Body weights were recorded weekly for the first twelve weeks of the study and monthly thereafter. Necropsy was performed on all animals. Histopathological examination was conducted on tissues from all dose groups.

[underlined: Effects noted in study and corresponding concentrations]:

Survival was comparable in all study groups. Body weight gain was within 10% of controls throughout the study. In the liver, fatty change (male: 27/50, 47/50, and 49/50; female: 12/50, 23/50, and 50/50) and "ground glass" cytoplasmic changes (male: 8/50, 22/50, and 34/50; female: 0/50, 1/50, and 12/50) were observed. A dose-related increase in nephrosis was observed in female rats (7/50, 11/50, and 14/50); however, the incidences in exposed rats was not statistically higher than in vehicle controls assessed using the Fisher exact test.

It should be noted that the study authors did not report statistical analysis data for nonneoplastic lesions. An independent statistical analysis was conducted; statistical significance was determined using a Fisher exact test, one tailed p<0.05).

[underlined: Concentration and end point used for MRL derivation]:

The MRL is based on a LOAEL of 40 mg/kg (duration-adjusted to 28 mg/kg/day) for liver histopathology (fatty change) (NTP 1985).

[ ] NOAEL [X] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [X] 3 for use of a minimal LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?] No.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent concentration]: NA

Was a conversion used from intermittent to continuous exposure?

The LOAEL was adjusted for intermittent exposure: 40 mg/kg × 5 days/7 days = 28 mg/kg/day

[underlined: Other additional studies or pertinent information that lend support to this MRL]:

The identification of the liver as the critical target is supported by numerous acute-duration studies in rats and mice exposed to ≥37 mg/kg (Chu et al. 1982a; Coffin et al. 2000; Condie et al. 1983; Hewitt et al. 1983; Munson et al. 198; NTP 1985), 50 mg/kg for intermediate durations (Aida et al. 1992; Daniel et al. 1990; Melnick et al. 1998; NTP 1985), and 40 mg/kg for chronic durations (NTP 1985; Tobe et al. 1982). The identification of the LOAEL of 40 mg/kg for fatty changes in the liver is supported by the NTP (1985) mouse study and a rat study by Tobe et al. (1982). Fatty metamorphosis was found in mice receiving gavage doses of 50 mg/kg, 5 days/week for 2 years (NTP 1985). Necrosis was observed at 100 mg/kg. In the Tobe et al. (1982) study, groups of rats were exposed to dibromochloromethane in diet for 2 years. No histological examinations were conducted; however, hypertrophy and yellowing of the liver was found at 85 mg/kg/day. Alterations in a number of clinical chemistry parameters, which are indicative of liver damage, were also observed. Decreases in serum triglycerides were observed at 20 mg/kg/day and decreases in serum cholesterol were observed at 540 mg/kg/day.

[underlined: Agency Contact (Chemical Managers):] John Risher, Dennis Jones