# 9 REFERENCES

ACGIH. 2006. Boron. Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists, 14–15.
Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27(4):532–537.4029526
Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
Agency for Toxic Substances and Disease Registry. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry, Division of Toxicology. Fed Regist 54(174):37618–37634.
AIHA. 1999. Boron trifluoride. Emergency response planning guidelines (ERPG). Fairfax, VA: American Industrial Hygiene Association.
Akar D. 2007. Potential boron pollution in surface water, crop, and soil in the lower Buyuk Menderes Basin. Environ Eng Sci 24(9):1273–1279.
Alam F, Evans F, Mani G, . 2003. Boron halides. Kirk-Othmer encyclopedia of chemical technology. John Wiley & Sons, Inc. http://www.mrw.interscience.wiley.com/emrw/9780471238966/kirk/article/boroalam.a01/current/pdf. March 11, 2009.
Alimonti A, Fornarelli L, Coni E, . 1992. Assessment of trace element concentrations in human lungs of urban subjects. Microchem J 46(2):191–198.
Allen BC, Strong PL, Price CJ, . 1996. Benchmark dose analysis of developmental toxicity in rats exposed to boric acid. Fundam Appl Toxicol 32(2):194–204.8921322
Allen GT, Blackford SH, Tabor VM, . 2001. Metals, boron, and selenium in Neosho madtom habitats in the Neosho River in Kansas, USA. Environ Monit Assess 66(1):1–21.11214445
Altman PL, Dittmer DS. 1974. Biological handbooks: Biology data book. Vol. III. 2nd ed. Bethesda, MD: Federation of American Societies for Experimental Biology, 1987–2008, 2041.
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York: Marcel Dekker, Inc., 9–25.
Andersen ME, Clewell HJ, Gargas ML, . 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87(2):185–205 3824380
APHA. 1998a. Method 3120 A. Introduction. Method 3120 B. Inductively coupled plasma (ICP) method. In: Clesceri LS, Greenberg AE, Eaton AD, eds. Standard methods for the examination of water and wastewater. 20th ed. Washington, DC: American Public Health Association. American Water Works Association. Water Environmental Federation, 3-37 to 3-43.
APHA. 1998b. Method 4500 BB. Curcumin method. In: Clesceri LS, Greenberg AE, Eaton AD, eds. Standard methods for the examination of water and wastewater. 20th ed. Washington, DC: American Public Health Association. American Water Works Association. Water Environmental Federation, 4-21 to 4-22.
APHA. 1998c. Method 4500 BC. Carmine method. In: Clesceri LS, Greenberg AE, Eaton AD, eds. Standard methods for the examination of water and wastewater. 20th ed. Washington, DC: American Public Health Association. American Water Works Association. Water Environmental Federation, 4–23.
Arslan M, Topaktas M, Rencuzogullari E. 2008. The effects of boric acid on sister chromatid exchanges and chromosome aberrations in cultured human lymphocytes. Cytotechnology 56(2):91–96.19002846
Barber LB, Murphy SF, Verplanck PL, . 2006. Chemical loading into surface water along a hydrological, biogeochemical, and land use gradient: A holistic watershed approach. Environ Sci Technol 40(2):476–486.
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486.3222488
Barranco WT, Hudak PF, Eckhert CD. 2007. Evaluation of ecological and in vitro effects of boron on prostate cancer risk (United States). Cancer Causes Control 18:71–77.17186423
Baselt RC. 1988. Borate. In: Biological monitoring methods for industrial chemicals. 2nd ed. Littleton, MA: PSG Publishing Company, Inc., 48–50.
Beckett WS, Oskvig R, Gaynor ME, . 2001. Association of reversible alopecia with occupational topical exposure to common borax-containing solutions (Comment in J Am Acad Dermatol 47(4):636-637). J Am Acad Dermatol 44(4):599–602.11260532
Benson WH, Birge WJ, Dorough HW. 1984. Absence of mutagenic activity of sodium borate (borax) and boric acid in the Salmonella preincubation test. Environ Toxicol Chem 3:209–214.
Berger GS, ed. 1994. Epidemiology of endometriosis. In: Endometriosis: Advanced management and surgical techniques. New York, NY: Springer-Verlag, 3–7.
Bertine KK, Goldberg ED. 1971. Fossil fuel combustion and the major sedimentary cycle. Science 173:233–235.17741418
Beyer KH, Bergfeld WF, Berndt WO, . 1983. Final report on the safety assessment of sodium borate and boric acid. J Am Coll Toxicol 2(7):87–125.
Biggar JW, Fireman M. 1960. Boron adsorption and release by soils. Soil Sci Soc Proc 115–120.
Bingham FT, Page AL, Coleman NT, . 1971. Boron adsorption characteristics of selected amorphous soils from Mexico and Hawaii. Soil Sci Am Proc 35:546–550.
Butterwick L, de Oude N, Raymond K. 1989. Safety assessment of boron in aquatic and terrestrial environments. Ecotoxicol Environ Safety 17:339–371.2743923
Cain WS, Jalowayski AA, Kleinman M, . 2004. Sensory and associated reactions to mineral dusts: Sodium borate, calcium oxide, and calcium sulfate. J Occup Environ Hyg 1:222–236.15204861
Cain WS, Jalowayski AA, Schmidt R, . 2008. Chemesthetic responses to airborne mineral dusts: Boric acid compared to alkaline materials. Int Arch Occup Environ Health 81:337–345.17609973
Chang BL, Robbins WA, Wei F, . 2006. Boron exposure in China: Exploring work and lifestyle factors to boron exposure. AAOHN J 54(10):435–443.17059161
Chao TC, Maxwell SM, Lyen K, . 1991a. Mass poisoning in Perak, Malaysia or the Tale of the Nine Emperor Gods and rat tail noodles. J Forensic Sci Soc 31(2):283–288.1940842
Chao TC, Maxwell SM, Wong SY. 1991b. An outbreak of aflatoxicosis and boric acid poisoning in Malaysia: A clinicopathological study. J Pathol 164(3):225–233.1890547
Chapin RE, Ku WW, Kenney MA, . 1997. The effects of dietary boron on bone strength in rats. Fundam Appl Toxicol 35(2):205–215.9038242
ChemIDplus. 2009. Boron and selected boron chemicals. ChemIDplus. Bethesda, MD: U.S. National Library of Medicine. http://sis.nlm.nih.gov/chemical.html. April 01, 2009.
Cherrington JW, Chernoff N. 2002. Periods of vertebral column sensitivity to boric acid treatment in CD-1 mice in utero. Reprod Toxicol 16(3):237–243.12128096
Chetelat B, Gaillardet J. 2005. Boron isotopes in the Seine River, France: A probe of anthropogenic contamination. Environ Sci Technol 39(8):2486–2493.15884339
Choi WW, Chen KY. 1979. Evaluation of boron removal by adsorption on solids. Environ Sci Technol 13(2):189–196.
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Cotton FA, Wilkinson G, Murillo CA, ., eds. 1999. Boron. In: Advanced inorganic chemistry. 6th ed. New York, NY: John Wiley & Sons, Inc., 131–174.
Cozzolino D, Kwiatkowski MJ, Dambergs RG, . 2008. Analysis of elements in wine using near infrared spectroscopy and partial least squares regression. Talanta 74(4):711–716.18371698
Cui Y, Winton MI, Zhang Z, . 2004. Dietary boron intake and prostate cancer risk. Oncol Rep 11:887–892.15010890
Culver BD, Shen PT, Taylor TH, . 1994a. The relationship of blood- and urine-boron exposure in borax-workers and usefulness of urine-boron as an exposure marker. Environ Health Perspect 102:133–137.
Culver BD, Smith RG, Brotherton RJ, . 1994b. Boron. In: Clayton GD, Clayton FE, eds. Patty’s industrial hygiene and toxicology. Vol. II. Part F. 4th ed. New York, NY: John Wiley & Sons, Inc., 4411–4448.
Culver BD, Strong PL, Murray JF. 2001. Boron. In: Bingham E, Cohrssen B, Powell CH, eds. Patty’s toxicology. Vol. 3. 5th ed. New York, NY: John Wiley & Sons, Inc., 519–582.
Davidson GR, Bassett RL. 1993. Application of boron isotopes for identifying contaminants such as fly ash leachate in groundwater. Environ Sci Technol 27(1):172–176.
Davies K. 1990. Human exposure pathways to selected organochlorines and PCBs in Toronto and Southern Ontario. Adv Environ Sci Technol 23:525–540.
Demerec M, Bertani G, Flint J. 1951. A survey of chemicals for mutagenic action on E. coli. American Naturalist 85:119–136.
Deverel SJ, Millard SP. 1988. Distribution and mobility of selenium and other trace elements in shallow groundwater of the western San Joaquin Valley, California. Environ Sci Technol 22:697–702.
Dieter MP. 1994. Toxicity and carcinogenicity studies of boric acid in male and female B6C3F1 mice. Environ Health Perspect Suppl 102(7):93–97.
Dixon RL, Lee IP, Sherins RJ. 1976. Methods to assess reproductive effects of environmental chemicals: Studies of cadmium and boron administered orally. Environ Health Perspect 13:59–67.1269508
Dixon RL, Sherins RJ, Lee IP. 1979. Assessment of environmental factors affecting male fertility. Environ Health Perspect 30:53–68.446458
Dourson M, Maier A, Meek B, . 1998. Boron tolerable intake: Re-evaluation of toxicokinetics for data-derived uncertainty factors. Biol Trace Elem Res 66:453–463.10050937
Draize JH, Kelley EA. 1959. The urinary excretion of boric acid preparations following oral administration and topical applications to intact and damaged skin of rabbits. Toxicol Appl Pharmacol 1:267–276.13659534
Dunlop W. 1981. Serial changes in renal haemodynamics during normal human pregnancy. Br J Obstet Gynaecol 88(1):1–9.7459285
Eckel W, Langley WD. 1988. A background-based ranking technique for assessment of elemental enrichment in soils at hazardous waste sites. In: Superfund ’88: Proceedings of the 9th National Conference, November 28-30, 1988, Washington, D.C. Silver Spring, MD: The Hazardous Materials Control Research Institute, 282–286.
Ellenhorn MJ, Schonwald S, Ordog G, ., eds. 1997. Ellenhorn’s medical toxicology: Diagnosis and treatment of human poisoning. 2nd ed. Baltimore, MA: Williams & Wilkins, 106t, 162t, 1098–1100.
Ellenhorn MJ, Barceloux DG. 1988. Medical toxicology: Diagnosis and treatment of human poisoning. New York, NY: Elsevier, 921–924.
EPA. 1983. Method 212.3. Boron (colorimetric, curcumin). In: EPA methods and guidance for analysis of water. U.S. Environmental Protection Agency. http://web1.er.usgs.gov/nemi/method_pdf/5279.pdf. March 22, 2007.
EPA. 1986a. Broad scan analysis of the FY82 national human adipose tissue survey specimens: Vol. I. Executive summary. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. EPA560586035.
EPA. 1986b. Quality criteria for water. Washington, DC: U.S. Environmental Protection Agency, Office of Water Planning and Standards. EPA440586001.
EPA. 1987. Toxic air pollutant/source crosswalk: A screening tool for locating possible sources emitting toxic air pollutants. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards. EPA450487023a. PB88161146.
EPA. 1990. Interim methods for development of inhalation reference concentrations. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development, Environmental Criteria and Assessment Office. EPA600890066A.
EPA. 1993. Reregistration Eligibility Decision (RED). Boric acid and its sodium salts. Washington, DC: U.S. Environmental Protection Agency. EPA738F93006.
EPA. 1994. Method 200.7. Determination of metals and trace elements in water and wastes by inductively coupled plasma-atomic emission spectrometry. In: EPA methods and guidance for analysis of water. U.S. Environmental Protection Agency. http://web1.er.usgs.gov/nemi/method_pdf/4690.pdf. March 22, 2007.
EPA. 1997. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. EPA630R96012.
EPA. 1998. The drinking water contaminant candidate list. Washington, DC: U.S. Environmental Protection Agency. Fed Regist 63:10274. http://www.gpoaccess.gov/fr/index.html. April 11, 2007.
EPA. 2000. Method 6010C. Inductively coupled plasma-atomic emission spectrometry. In: EPA methods and guidance for analysis of water. U.S. Environmental Protection Agency. http://web1.er.usgs.gov/nemi/method_pdf/4712.pdf. March 21, 2007.
EPA. 2003. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency, Office of Ground Water and Drinking Water. EPA816F03016. http://www.epa.gov/safewater/mcl.html. March 07, 2006.
EPA. 2004. Inert pesticide ingredients in pesticide products. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/opprd001/inerts/lists.html. April 11, 2007.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. Office of Environmental Information. EPA260B05001.
EPA. 2006. Drinking water standards and health advisories. Washington, DC: Office of Water, U.S. Environmental Protection Agency. EPA822R04005. http://epa.gov/waterscience/criteria/drinking/. April 11, 2007.
EPA. 2007a. Boron trifluoride. Acute exposure guideline levels (AEGLs). Washington, DC: Office of Pollution Prevention and Toxics, U.S. Environmental Protection Agency. http://www.epa.gov/oppt/aegl/pubs/compiled.pdf. April 11, 2007.
EPA. 2007b. Tolerances and exemptions from tolerances for pesticide chemicals in food. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.101. http://www.epa.gov/epacfr40/chapt-I.info/chi-toc.htm. March 12, 2009.
EPA. 2008a. Regulated toxic substances and threshold quantities for accidental release prevention. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 68.130. http://edocket.access.gpo.gov/cfr_2008/julqtr/pdf/40cfr68.130.pdf. March 31, 2009..
EPA. 2008b. Superfund, emergency planning, and community right-to-know programs. Extremely hazardous substances and their threshold planning quantities. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 355, Appendix A. http://edocket.access.gpo.gov/cfr_2008/julqtr/pdf/40cfr355AppA.pdf. March 31, 2009.
Fail PA, Chapin RE, Price CJ, . 1998. General, reproductive, developmental, and endocrine toxicity of boronated compounds. Reprod Toxicol 12(1):1–18.9431568
Fail PA, George JD, Seely JC, . 1991. Reproductive toxicity of boric acid in Swiss (CD-1) mice: Assessment using the continuous breeding protocol. Fundam Appl Toxicol 17(2):225–239.1765217
Farr LE, Konikowski T. 1963. The renal clearance of sodium pentaborate in mice and men. Clin Chem 9(6):717–726.
FDA. 2006. Indirect food additives: adhesives and components of coatings. Washington, DC: U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 175.105. http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfcfr/CFRSearch.cfm. April 11, 2007.
FDA. 2007. Everything added to food in the United States (EAFUS). Washington, DC: U.S. Food and Drug Administration. http://vm.cfsan.fda.gov/~dms/eafus.html. April 11, 2007.
FEDRIP. 2009. Boron and selected boron compounds. Federal Research in Progress database. Springfield, VA: National Technical Information Service.
Ferrando AA, Green NR. 1993. The effect of boron supplementation on lean body mass, plasma testosterone levels, and strength in male bodybuilders. Int J Sport Nutr 3(2):140–149.8508192
Fisher RS, Freimuth HC. 1958. Blood boron levels in human infants. J Invest Dermatol 30:85–86.13514159
FNB/IOM. 2001. Dietary reference intakes for vitamin A, vitamin K, arsenic, boron, chromium, copper, iodine, iron, manganese, molybdenum, nickel, silicon, vanadium, and zinc (2000). A Report of the Panel on Micronutrients, subcommittees on upper reference levels of nutrients and of interpretation and uses of dietary reference intakes, and the standing committee on the scientific evaluation of dietary reference intakes. Food and Nutrition Board. Institute of Medicine. Washington, DC: National Academy Press, 510–520. http://books.nap.edu/openbook.php?record_id=10026&page=R2. August 06, 2007.
Fomon SJ. 1966. Body composition of the infant: Part I: The male reference infant. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
Fomon SJ, Haschke F, Ziegler EE, . 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35(Suppl 5):1169–1175.7081099
Fox KK, Cassani G, Facchi A, . 2002. Measured variation in boron loads reaching European sewage treatment works. Chemosphere 47(5):499–505.11996125
Fukuda R, Hirode M, Mori I, . 2000. Collaborative work to evaluate toxicity on male reproductive organs by repeated dose studies in rats. 24). Testicular toxicity of boric acid after 2- and 4-week administration periods. J Toxicol Sci 25:233–239.11349449
Gallardo-Williams MT, Chapin RE, King PE, . 2004. Boron supplementation inhibits the growth and local expression of IGF-1 in human prostate adenocarcinoma (LNCaP) tumors in nude mice. Toxicol Pathol 32:73–78.14713551
Garabrant DH, Bernstein L, Peters JM, . 1984. Respiratory and eye irritation from boron oxide and boric acid dusts. J Occup Med 26(8):584–586.6332889
Garabrant DH, Bernstein L, Peters JM, . 1985. Respiratory effects of borax dust. Br J Ind Med 42:831–837.3878156
Giwercman A, Carlsen E, Keiding N, . 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl 101(2):65–71.
Goldfrank LR, Flomenbaum NE, Lewin NA, . 1990. Goldfrank’s toxicologic emergencies. 4th ed. Norwalk, CT: Appleton & Lange, 664–665.
Goldfrank LR, Flomenbaum NE, Lewin NA, ., eds. 2002. Goldfrank’s toxicologic emergencies. 7th ed. New York, NY: McGraw-Hill, 1282, 1289–1290, 1134.
Gonzales M, Shah V, Bobelu A, . 2004. Concentrations of surface-dust metals in Native American jewelry-making homes in Zuni Pueblo, New Mexico. Arch Environ Health 59(5):245–249.16201670
Gordon AS, Prichard JS, Freedman MH. 1973. Seizure disorders and anemia associated with chronic borax intoxication. Can Med Assoc J 108:719–721, 724.4691106
Goullé JP, Mahieu L, Castermant J, . 2005. Metal and metalloid multi-elementary ICP-MS validation in whole blood, plasma, urine and hair. Forensic Sci Int 153(1):39–44.15979835
Graedel TE. 1978. Inorganic elements, hydrides, oxides and carbonates. In: Chemical compounds in the atmosphere. New York, NY: Academic Press, 35–49.
Green DR, Le Pape D. 1987. Stability of hydrocarbon samples on solid-phase extraction columns. Anal Chem 59:699–703.
Griffin RA, Burau RG. 1974. Kinetic and equilibrium studies of boron desorption from soil. Soil Sci Soc Am Proc 38:892–897.
Guzelian PS, Henry CJ, Olin SS, eds. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences Institute Press.
Hall LW, Killen WD, Anderson RD, . 2004. Analysis of historical salinity and boron surface water monitoring data from the San Joaquin river watershed: 1985-2002. Environ Monit Assess 95(1–3):125–151.15195824
Harris MA, Chapin RE, Lockhart AC, . 1992. Assessment of short-term reproductive and developmental toxicity screen. Fundam Appl Toxicol 19(2):186–196.1516774
Haworth S, Lawlor T, Mortelmans K, . 1983. Salmonella mutagenicity test results for 250 chemicals. Environ Mutagen 5(Suppl 1):3–142.
HazDat. 2007. Boron. HazDat Database: ATSDR’s Hazardous Substance Release and Health Effects Database. Atlanta, GA: Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/hazdat.html. April 23, 2007.
Heindel JJ, Price CJ, Field EA, . 1992. Developmental toxicity of boric acid in mice and rats. Fundam Appl Toxicol 18(2):266–277.1601227
Heindel JJ, Price CJ, Schwetz BA. 1994. The developmental toxicity of boric acid in mice, rats, and rabbits. Environ Health Perspect Suppl 102(7):107–112.
Hill WH, Smith RC. 1959. Analysis of blood for boron. Am Ind Hyg Assoc J 20:131–133.13649571
Hoel DG, Davis DL, Miller AB, . 1992. Trends in cancer mortality in 15 industrialized countries, 1969-1986. J Natl Cancer Inst 84(5):313–320.1738181
Hollis JF, Keren R, Gal M. 1988. Boron release and sorption by fly ash as affected by pH and particle size. J Environ Qual 17:181–184.
Howe PD. 1998. A review of boron effects in the environment. Biol Trace Elem Res 66(1–3):153–166.10050917
HSDB. 2009. Boron and selected boron chemicals. Hazardous Substances Data Bank. National Library of Medicine. http://toxnet.nlm.nih.gov/cgi-bin/sis/htmlgen?HSDB. April 01, 2009.
Hu X, Wegman DH, Eisen EA, . 1992. Dose related acute irritant symptom responses to occupational exposure to sodium borate dusts. Br J Ind Med 49(10):706–713.1419859
Hubbard SA. 1998. Comparative toxicology of borates. Biol Trace Elem Res 66:343–357.10050929
Hunt CD, Meacham SL. 2001. Aluminum, boron, calcium, copper, iron, magnesium, manganese, molybdenum, phosphorus, potassium, sodium, and zinc: Concentrations in common Western food and estimated daily intakes by infants, toddlers, and male and female adolescents, adults, and seniors in the United States. J Am Diet Assoc 101:1058–1060.11573761
Hunt CD, Butte NF, Johnson, LK. 2005. Boron concentrations in milk from mothers of exclusively breast-fed healthy full-term infants are stable during the first four months of lactation. J Nutr 135(10):2383–2386.16177200
Hunt CD, Friel JK, Johnson LK. 2004. Boron concentrations in milk from mothers of full-term and premature infants. Am J Clin Nutr 80(5):1327–1333.15531683
Hunt CD, Shuler TR, Mullen LM. 1991. Concentration of boron and other elements in human foods and personal-care products. J Am Diet Assoc 91(5):558–568.2019698
IARC. 2006. Agents reviewed by the IARC monographs. Volumes 1–96. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Classification/index.php. April 11, 2007.
Imbus HR, Cholak J, Miller LH, . 1963. Boron, cadmium, chromium, and nickel in blood and urine. Arch Environ Health 6:286–295.13956417
IRIS. 2007. Boron and boron compounds. Washington, DC: Integrated Risk Information System. U.S. Environmental Protection Agency. http://www.epa.gov/iris/subst/index.html. April 11, 2007.
Ishii Y, Fujizuka N, Takahashi T, . 1993. A fatal case of acute boron poisoning. J Toxicol Clin Toxicol 31(2):345–352.8492348
Jackson RE, Reddy KJ. 2007. Trace element chemistry of coal bed natural gas produced water in the Powder River Basin, Wyoming. Environ Sci Technol 41(17):5953–5959.17937266
Jansen JA, Anderson J, Schou JS. 1984b. Boric acid single dose pharmacokinetics after intravenous administration to man. Arch Toxicol 55:64–67.6732506
Jansen JA, Schou JS, Aggerback B. 1984a. Gastro-intestinal absorption and in vitro release of boric acid from water-emulsifying ointments. Food Chem Toxicol 22:49–53.6537937
Jansen LH. 2003. Boron, elemental. In: Kirk-Othmer encyclopedia of chemical technology. John Wiley & Sons, Inc. http://www.mrw.interscience.wiley.com/emrw/9780471238966/kirk/article/borojans.a01/current/pdf. March 11, 2009.
Jensen AA. 2009. Risk assessment of boron in glass wool insulation. Environ Sci Pollut Res 16:73–78.
Johanson CE. 1980. Permeability and vascularity of the developing brain: Cerebellum vs cerebral cortex. Brain Res 190(1):3–16.6769537
Keren R, Mezuman U. 1981. Boron adsorption by clay minerals using a phenomenological equation. Clays Clay Miner 29:198–204.
Keren R, Gast RG, Bar-Yosef B. 1981. pH-dependent boron adsorption by Na-montmorillonite. Soil Sci Soc Am J 45:45–48.
Kloppmann W, Van Houtte E, Picot G, . 2008. Monitoring reverse osmosis treated wastewater recharge into a coastal aquifer by environmental isotopes (B, Li, O, H). Environ Sci Technol 14(23):8759–8765.
Koc C. 2007. Effects on environment and agriculture of geothermal wastewater and boron pollution in Great Menderes Basin. Environ Monit Assess 125(1–3):377–388.17171286
Komori M, Nishio K, Kitada M, . 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29(18):4430–4433.2350547
Korkmaz M, Uzgoren E, Bakirdere S, . 2007. Effects of dietary boron on cervical cytopathology and on micronucleus frequency in exfoliated buccal cells. Environ Toxicol 22(1):17–25.17295277
Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. 3rd ed. New York, NY: Raven Press, Ltd., 149–188.
Krishnan K, Anderson ME, Clewell HJ, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, eds. Toxicology of chemical mixtures. New York, NY: Academic Press, 399–437.
Krutzen E, Olofsson P, Back SE, . 1992. Glomerular filtration rate in pregnancy: a study in normal subjects and in patients with hypertension, preeclampsia and diabetes. Scand J Clin Lab Invest 52(5):387–392.1514017
Krystofiak SP, Schaper MM. 1996. Prediction of an occupational exposure limit for a mixture on the basis of its components: Application to metalworking fluids. Am Ind Hyg Assoc J 57(3):239–244.8776194
Ku WW, Chapin RE, Moseman RF, . 1991. Tissue disposition of boron in male Fischer rats. Toxicol Appl Pharmacol 111:145–151.1949031
Ku WW, Chapin RE, Wine RN, . 1993a. Testicular toxicity of boric acid (BA): Relationship of dose to lesion development and recovery in the F344 rat. Reprod Toxicol 7(4):305–319.8400621
Ku WW, Shih LM, Chapin RE. 1993b. The effects of boric acid (BA) on testicular cells in culture. Reprod Toxicol 7:321–331.7691281
Kudo S, Tanase H, Yamasaki M, . 2000. Collaborative work to evaluate toxicity on male reproductive organs by repeated dose studies in rats. A comparative 2- and 4-week repeated oral dose testicular toxicity study of boric acid in rats. J Toxicol Sci 25:223–232.
Landolph JR. 1985. Cytotoxicity and negligible genotoxicity of borax and borax ores to cultured mammalian cells. Am J Ind Med 7:31–43.3970022
Lang FJ, Bingham FT, Hendrix FF, . 1986. Boron deposition on soil and native vegetation from geothermal emissions. J Environ Qual 15(3):260–265.
Lee IP, Sherins RJ, Dixon RL. 1978. Evidence for induction of germinal aplasia in male rats by environmental exposure to boron. Toxicol Appl Pharmacol 45:577–590.705788
Leeder JS, Kearns GL. 1997. Pharmcogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
Leung H. 1993. Physiologically-based pharmacokinetic modeling. In: Ballentyne B, Marrs T, Turner P, eds. General and applied toxicology. Vol. 1. New York, NY: Stockton Press, 153–164.
Lide DR. 2008. CRC handbook of chemistry and physics. 2007-2008. 86th ed. Boca Raton, FL: CRC Press. Taylor & Francis Group, 4-6 to 4-7.
Linden CH, Hall AH, Kulig KW, . 1986. Acute ingestions of boric acid. Clin Toxicol 24:269–279.
Litovitz TL, Klein-Schwartz W, Oderda GM, . 1988. Clinical manifestations of toxicity in a series of 784 boric acid ingestions. Am J Emerg Med 6:209–213.3370093
Liu P, Hu W, Wei FS, . 2006a. Effect of boron on human semen quality. Chin J Public Health 22:940–942.
Liu P, Hu W, Gooping W, . 2006b. Effect of occupational exposure to boron on the sperm quality of males. Chin J Ind Occup Dis 24:167–169.
Livingston AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4(2–3):301–324.351201
Locatelli C, Minoia C, Tonini M, . 1987. Human toxicology of boron with special reference to boric acid poisoning. G Ital Med Lav 9:141–146.3334378
Lopez-Garcia I, Vinas P, Romero-Romero R, . 2009. Preconcentration and determination of boron in milk, infant formula, and honey samples by solid phase extraction-electrothermal atomic absorption spectrometry. Spectrochim Acta Part B 64B(2):179–183.
Lowe TP, Day DD. 2002. Metal concentrations in zebra mussels and sediments from embayments and riverine environments of eastern Lake Erie, southern Lake Ontario, and the Niagara River. Arch Environ Contam Toxicol 43(3):301–308.12202926
Matthijs E, Holt MS, Kiewiet A, . 1999. Environmental monitoring for linear alkylbenzene sulfonate, alcohol ethoxylate, alcohol ethoxy sulfate, alcohol sulfate, and soap. Environ Toxicol Chem 18(11):2634–2644.
Maurer JK, Molai A, Parker RD, . 2001. Pathology of ocular irritation with bleaching agents in the rabbit low-volume eye test. Toxicol Pathol 29(3):308–319.11442017
Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74(2–3):135–149.1387742
McCabe LJ, Symons JM, Lee RD, . 1970. Survey of community water supply systems. J Am Water Work Assoc 62:670–687.
Meacham S, Hunt CD. 1994. Boron content of commercial baby foods and beverages typically consumed by infants. FASEB J 8(4–5):A430.
Mezuman U, Keren R. 1981. Boron adsorption by soils using a phenomenological equation. Soil Sci Soc Am J 45:722–726.
Minoia C, Sabbioni E, Ronchi A, . 1994. Trace element reference values in tissues from inhabitants of the European Community. IV. Influence of dietary factors. Sci Total Environ 141:181–195.
Moore SJ, Bassett RL, Liu B, . 2008. Geochemical tracers to evaluate hydrogeologic controls on river salination. Ground Water 46(3):489–501.18266732
Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokin 5(6):485–527.
Moseman RF. 1994. Chemical disposition of boron in animals and humans. Environ Health Perspect 102:113–117.
Mumma RO, Raupach DC, Waldman JP, . 1984. National survey of elements and other constituents in municipal sewage sludges. Arch Environ Contam Toxicol 13:75–83.
Naderi AS, Palmer BF. 2006. Successful treatment of a rare case of boric acid overdose with hemodialysis. Am J Kidney Dis 48(6):95–97.
NAS/NRC. 1989. Report of the oversight committee. In: Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press, 15–35.
NEMI. 2007. Boron and selected boron compounds. National Environmental Methods Index. U.S. Environmental Protection Agency. U.S. Geological Survey. http://www.nemi.gov. August 06, 2007.
Nielsen FH, Hunt CD, Muller LM, . 1987. Effect of dietary boron on mineral, estrogen, and testosterone metabolism in postmenopausal women. FASEB Monogr 1:394–397.
NIH. 2004. Boric acid, sodium borate decahydrate (borax), and sodium tetraborate anhydrous. Household products database. National Institutes of Health. U.S. National Library of Medicine. http://hpd.nlm.nih.gov/ingredients.htm. March 13, 2009.
NIOSH. 1994. Boron carbide. Method 7506. NIOSH manual of analytical methods (NMAM). 4th ed. National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/nmam/pdfs/7506.pdf. March 14, 2007.
NIOSH. 2003. Method 7303. Elements by ICP. (Hot block/HCl/HNO3 digestion). In: NIOSH manual of analytical manual. (NMAM). National Institute for Occupational Safety and Health. http://www.cdc.gov.niosh/nmam/pdfs/7303.pdf. March 14, 2007.
NIOSH. 2005. NIOSH pocket guide to chemical hazards. Boron oxide. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. http://www.cdc.gov/niosh/npg/. April 11, 2007.
NIOSH. 2007. Boron compounds. International chemical safety cards (ICSCs): U.S. National Version. National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/ipcs/nicstart.html. March 14, 2007.
NIRS. 1987. National inorganics and radionuclides survey. Distribution tables. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Drinking Water.
NOES. 1989. National Occupational Exposure Survey. Cincinnati, OH: National Institute of Occupational Safety and Health. October 18, 1989.
NOHS. 1989. National Occupational Hazard Survey. National Institute of Occupational Safety and Health, Cincinnati, OH. October 18, 1989.
Nolte J. 1988. Pollution source analysis of river water and sewage sludge. Environ Technol Lett 9:857–868.
Nomiyama T, Omae K, Uemura T, . 1995. No-observed-effect level of diborane on the respiratory organs of male mice in acute and subacute inhalation experiments. Sangyo Eiseigaku Zasshi 37(3):157–160.7796306
Nriagu JO. 1979. Copper in the atmosphere and precipitation. In: Nriagu JO, ed. Copper in the environment. Part I: Ecological cycling. New York, NY: John Wiley and Sons, Inc., 43–67.
NRC. 1993. Pesticides in the diets of infants and children. Washington, DC: National Research Council. National Academy Press. PB93216091.
NTP. 1987. National Toxicology Program--technical report series no. TR324 on the toxicology and carcinogenesis studies of boric acid (CAS No. 10043-35-3) in B6C3F1 mice (feed studies). Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. NIH Publication No. 88-2580.
NTP. 1990. National Toxicology Program. Final report on the reproductive toxicity of boric acid in CD-1-Swiss mice. National Institute of Environmental Health Sciences. NTP Report No. 90-105.
NTP. 1991. Final report on the developmental toxicity of boric acid (CAS No. 10043-35-3) in New Zealand white rabbits. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. PB92129550.
NTP. 2005. Report on carcinogens. 11th ed. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. http://ntp-server.niehs.nih.gov/ntp/roc/toc11.html. March 08, 2006.
Nusier M, Bataineh HN. 2005. Effect of boric acid on fertility, aggressiveness and sex behaviour in male rats. Asian J Chem 17(4):2579–2588.
Odunola OA. 1997. Individual and combined genotoxic response to boric acid and aflatoxin B1 in Escherichia coli PQ37. East Afr Med J 74(8):499–502.9487415
Ordonez A, Loredo J, De Miguel E, . 2003. Distribution of heavy metals in the street dusts and soils of an industrial city in northern Spain. Arch Environ Contam Toxicol 44:160–170.12520388
OSHA. 1989. Method ID216SG. Boron trifluoride (BF3). Occupational Safety and Health Administration. http://www.osha.gov/dts/sltc/methods/partial/id216sg/id216sg.html. March 14, 2007.
OSHA. 2006a. Air contaminants. Occupational safety and health standards for shipyard employment. Washington, DC: Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. http://www.osha.gov/comp-links.html. April 11, 2007.
OSHA. 2006b. Gases, vapors, fumes, dusts, and mists. Safety and health regulations for construction. Washington, DC: Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55, Appendix A. http://www.osha.gov/comp-links.html. April 11, 2007.
OSHA. 2006c. Limits for air contaminants. Occupational safety and health standards. Washington, DC: Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. http://www.osha.gov/comp-links.html. April 11, 2007.
OSHA. 2006d. List of highly hazardous chemicals, toxics, and reactives. Occupational safety and health standards. Washington, DC: Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.119. http://www.osha.gov/comp-links.html. April 11, 2007.
O’Sullivan K, Taylor M. 1983. Chronic boric acid poisoning in infants. Arch Dis Child 58:737–739.6625636
Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
Ozturkcan S, Dundar R, Katilmus H, . 2008. The ototoxic effect of boric acid solutions applied into the middle ear of guinea pigs. Eur Arch Otorhinolaryngol [epub ahead of print].
Pahl MV, Culver BD, Strong PL, . 2001. The effect of pregnancy on renal clearance of boron in humans: A study based on normal dietary intake of boron. Toxicol Sci 60(2):252–256.11248136
Parks WL, White JL. 1952. Boron retention by clay and humus systems saturated with various cations. Soil Sci Soc Proc 16:298–300.
Price CJ, Marr MC, Myers CB, . 1996b. The developmental toxicity of boric acid in rabbits. Fundam Appl Toxicol 34(2):176–187.8954748
Price CJ, Strong PL, Marr MC, . 1996a. Developmental toxicity NOAEL and postnatal recovery in rats fed boric acid during gestation. Fundam Appl Toxicol 32:179–193.8921321
Price CJ, Strong PL, Murray FJ, . 1998. Developmental effects of boric acid in rats related to maternal blood boron concentrations. Biol Trace Elem Res 66:359–372.10050930
Rai D, Zachara JM, Schwab AP, . 1986. Chemical attenuation rates, coefficients, and constants in leachate migration. Vol. 1. A critical review. Palo Alto, CA: Electric Power Research Institute, Research Project 2198-1.
Rainey CJ, Nyquist LA, Christensen RE, . 1999. Daily boron intake from the American diet. J Am Diet Assoc 99(3):335–340.10076586
Rainey CJ, Nyquist LA, Coughlin JR, . 2002. Dietary boron intake in the United States: CSFII 1994-1996. J Food Comp Anal 15:237–250.
Restuccio A, Mortensen ME, Kelley MT. 1992. Fatal ingestion of boric acid in an adult. Am J Emerg Med 10(6):545–547.1388380
Rope SK, Arthur WJ, Craig TH, . 1988. Nutrient and trace elements in soil and desert vegetation of southern Idaho. Environ Monit Assess 10:1–24.24248523
Rosborg I, Nihlgard B, Gerhardsson L. 2003. Hair element concentrations in females in one acid and one alkaline area in southern Sweden. Ambio 32(7):440–446.14703901
RTECS. 2007. Boron. Registry of Toxic Effects on Chemical Substances. National Institute of Occupational Safety and Health. MDL Information Systems, Inc. May 7, 2007.
Ruth JH. 1986. Odor threshold and irritation levels of several chemical substances: A review. Am Ind Hyg Assoc J 47:142–151.
Sah RN, Brown PH. 1997. Boron determination: A review of analytical methods. Microchem J 56:285–304.
Sakata M. 1987. Relationship between adsorption of arsenic (III) and boron by soil and soil properties. Environ Sci Technol 21:1126–1130.
Sayli BS. 1998a. An assessment of fertility in boron-exposed Turkish subpopulations. Evidence that boron has no effect on human reproduction. Biol Trace Elem Res 66:409–422.10050934
Sayli BS. 1998b. The sex ratio of offspring of people exposed to boron. Reprod Toxicol 12(6):673–674.9875701
Sayli BS. 2003. Low frequency of infertility among workers in a borate processing facility. Biol Trace Elem Res 93:19–29.12835486
Sayli BS, Tuccar E, Elhan AH. 1998. An assessment of fertility in boron-exposed Turkish subpopulations. Reprod Toxicol 12(3):297–304.9628553
Schillinger BM, Berstein M, Goldberg LA, . 1982. Boric acid poisoning. J Am Acad Dermatol 7:667–673.6216273
Schou JS, Jansen JA, Aggerbeck B. 1984. Human pharmacokinetics and safety of boric acid. Arch Toxicol Suppl 7:232–235.
Schubert DM, Brotherton, RJ. 2006. Boron: Inorganic chemistry. In: Encyclopedia of inorganic chemistry. John Wiley & Sons, Inc. http://mrw.interscience.wiley.com/emrw/9780470862100/eic/article/ia025/current/pdf. March 11, 2009.
Seal BS, Weeth HJ. 1980. Effect of boron in drinking water on the male laboratory rat. Bull Environ Contam Toxicol 25:782–789.7470654
Setchell BP, Waites GMH. 1975. The blood-testis barrier. In: Creep RO, Astwood EB, Geiger SR, eds. Handbook of physiology: Endocrinology V. Washington, DC: American Physiological Society, 143–172.
Settimi L, Elovaara E, Savolainen H. 1982. Effects of extended peroral borate ingestion on rat liver and brain. Toxicol Lett 10:219–223.7080088
Sittig M. 1985. Handbook of toxic and hazardous chemicals and carcinogens. 2nd ed. Park Ridge, NJ: Noyes Publications, 137–142.
Smyth HF, Carpenter CP, Weil CS, . 1969. Range-finding toxicity data: List VII. Am Ind Hyg Assoc J 30:470–476.5823428
SRI. 2008. 2008 Directory of chemical producers. Menlo Park, CA: SRI Consulting, 453, 851.
Stewart NJ, McHugh TP. 1990. B. Borates. In: Haddad LM, Winchester JF, eds. Clinical management of poisoning and drug overdose. 2nd ed. Philadelphia, PA: W.B. Saunders Company, 1447–1451.
Stokinger HE. 1981. Boron. In: Clayton GD, Clayton FE, eds. Patty’s industrial hygiene and toxicology. Vol. 2B. Toxicology. 3rd ed. New York, NY: John Wiley and Sons, 2978–3005.
Sturgiss SN, Wilkinson R, Davison JM. 1996. Renal reserve during human pregnancy. Am J Physiol 271(40):F16–F20.8760238
Tagawa T, Kono K, Dote T, . 2000. Pharmacokinetics and effects after intravenous administration of high-dose boron to rat. Int Arch Occup Environ Health 73:S98–S100.10968569
Takahashi T, Yawata S, Hoshino H. 2008. Determination of boron in water samples at nanograms per cubic decimeter levels by reversed-phase partition high performance liquid chromatography with pecolumn complexation reaction using salicylaldehyde and 1-amino-8-naphthol-3,6-disulfonate. Anal Bioanal Chem 391:1101–1106.18415086
Tarasenko NY, Kaspurov AA, Strongina OM. 1972. [Effect of boric acid on the generative function in males.] Gigirna Truda i Professionalyne Zabolevaniya 11:13–16. (Russian)
Thomas K, Colborn T. 1992. Organochlorine endocrine disruptors in human tissue. In: Colborn T, Clement C, eds. Chemically induced alterations in sexual and functional development: The wildlife/human connection. Princeton, NJ: Princeton Scientific Publishing, 365–394.
Thompson SE, Burton CA, Quinn DJ, . 1972. Concentration factors of chemical elements in edible aquatic organisms. Livermore, CA: Lawrence Livermore Laboratory, Bio-Medical Division, University of California. UCRL50564REV1.
Treinen KA, Chapin RE. 1991. Development of testicular lesions in F344 rats after treatment with boric acid. Toxicol Appl Pharmacol 107:325–335.1994514
TRI06. 2008. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access. Office of Environmental Information. U.S. Environmental Protection Agency. Toxics Release Inventory. http://www.epa.gov/triexplorer/. February 12, 2009.
Tsui PT, McCart PJ. 1981. Chlorinated hydrocarbon residues and heavy metals in several fish species from the Cold Lake area in Alberta, Canada. Intern J Environ Anal Chem 10:277–285.
Tuccar E, Elhan AH, Yaduz Y, . 1998. Comparison of infertility rates in communities from boron-rich and boron-poor territories. Biol Trace Elem Res 66:401–407.10050933
Uemura T, Omae K, Nakashima H, . 1995. Acute and subacute inhalation toxicity of diborane in male ICR mice. Arch Toxicol 69(6):397–404.7495378
USGS. 1984. Element concentrations in soils and other surficial materials of the conterminous United States. Alexandria, VA: U.S. Geological Survey. Geological Survey Professional Paper 1270.
USGS. 1989. In: Fishman MJ, Friedman LC, eds. Techniques of water-resources investigations, Book 5, Chapter A1. Methods for determination of inorganic substances in water and fluvial sediments. Washington, DC: U.S. Geological Survey. http://pubs.usgs.gov/twri/twri5-a1/pdf/TWRI_5-A1.pdf. April 12, 2007.
USGS. 1996a. Methods of analysis by the U.S. Geological Survey National Water Quality Laboratory-Preparation procedure for aquatic biological material determined for trace metals. Denver, CO: U.S. Geological Survey. Open-File Report 96-362. http://pubs.er.usgs.gov/usgspubs/ofr/ofr96362. March 26, 2007.
USGS. 1996b. Methods of analysis by the U.S. Geological Survey National Water Quality Laboratory-Determination of dissolved aluminum and boron in water by inductively coupled plasma-atomic emission spectrometry. Denver, CO: U.S. Geological Survey. Open-File Report 96-149. http://pubs.er.usgs.gov/usgspubs/ofr/ofr96149. March 26, 2007.
USGS. 1998. Methods of analysis by the U.S. Geological Survey National Water Quality Laboratory-Determination of elements in whole-water digests using inductively coupled plasma-optical emission spectrometry and inductively coupled plasma-mass spectrometry. Denver, CO: U.S. Geological Survey. Open-File Report 98-165. http://pubs.er.usgs.gov/usgspubs/ofr/ofr98165. March 26, 2007.
USGS. 1999. Methods of analysis by the U.S. Geological Survey National Water Quality Laboratory-Determination of dissolved arsenic, boron, lithium, selenium, strontium, thallium, and vanadium using inductively coupled plasma-mass spectrometry. Denver, CO: U.S. Geological Survey. Open-File Report 99-093. http://pubs.er.usgs.gov/usgspubs/ofr/ofr99093. March 26, 2007.
USGS. 2008. Boron. 2007 minerals yearbook. U.S. Geological Survey, 13-1 to 13-10. http://minerals.usgs.gov/minerals/pubs/commodity/boron/boronmyb05.pdf. March 31, 2009.
USGS. 2009. Boron. Mineral commodity studies. U.S. Geological Survey, 34–35. http://minerals.usgs.gov/minerals/pubs/commodity/boron/mcs-2009-boron.pdf. March 31, 2009.
Usuda K, Kono K, Dote T, . 1998. Study on urine boron reference values of Japanese men: Use of confidence intervals as an indicator of exposure to boron compounds. Sci Total Environ 220(1):45–53.9800385
Vanderpool RA, Hoff D, Johnson PE. 1994. Use of inductively coupled plasma-mass spectrometry in boron-10 stable isotope experiments with plants, rats, and humans. Environ Health Perspect 102(Suppl 7):13–20.
Van Ormer DG. 1975. Atomic absorption analysis of some trace elements of toxicological interest. J Forensic Sci 20:595–623.1100768
Vaziri ND, Oveisi F, Culver BD, . 2001. The effect of pregnancy on renal clearance of boron in rats given boric acid orally. Toxicol Sci 60:257–263.11248137
Vengosh A, Heumann KG, Juraske S, . 1994. Boron isotope applications for tracing sources of contamination in groundwater. Environ Sci Technol 28(11):1968–1974.22175940
Viccellio P, Bania T, Brent J, ., eds. 1998. Emergency toxicology. 2nd ed. Philadelphia, PA: Lippincott-Raven, 448–449, 470, 1141.
Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238(2):476–483.8681961
Vignec AJ, Ellis R. 1954. Inabsorbability of boric acid in infant powder. Am J Dis Child 88:72–80.
Waggott A. 1969. An investigation of the potential problem of increasing boron concentrations in rivers and water courses. Water Res 3:749–765.
Wegman DH, Eisen EA, Hu X, . 1994. Acute and chronic respiratory effects of sodium borate particulate exposures. Environ Health Perspect (Suppl 7):102:119–128.
Weir RJ, Fisher RS. 1972. Toxicologic studies on borax and boric acid. Toxicol Appl Pharmacol 23:351–364.4673567
Wery N, Narotsky MG, Pacico N, . 2003. Defects in cervical vertebrae in boric acid-exposed rat embryos are associated with anterior shifts of hox gene expression domains. Birth Defects Res A Clin Mol Teratol 67(1):59–67.12749385
West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
Wester RC, Hui X, Hartway T, . 1998. In vivo percutaneous absorption of boric acid, borax, and disodium octaborate tetrahydrate in humans compared to in vitro absoption in human skin from infinite and finite doses. Toxicol Sci 45:42–51.9848109
WHO. 2000. Air quality guidelines. 2nd ed. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/Document/AIQ/AirQualRepMtg.pdf. March 08, 2006.
WHO. 2004. Guidelines for drinking-water quality. Vol. 1. Recommendations. 3rd ed. Geneva, Switzerland: World Health Organization. http://www.who.int/water_sanitation_health/dwq/gdwq3/en/. March 08, 2006.
Whorton D, Haas J, Trent L. 1994. Reproductive effects of inorganic borates on male employees: Birth rate assessment. Environ Health Perspect Suppl 102(7):129–132.7889872
Widdowson EM, Dickerson JWT. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise. Vol. II: The elements. Part A. New York, NY: Academic Press, 1–247.
Wilding JL, Smith WJ, Yevich P, . 1959. The toxicity of boron oxide. Am Ind Hyg Assoc J 20:284–289.13670105
Wittig A, Michel J, Moss RL, . 2008. Boron analysis and boron imaging in biological materials for Boron Neutron Capture Therapy (BNCT). Crit Rev Oncol Hematol 68(1):66–90.18439836
Wong LC, Heimbach MD, Truscott DR, . 1964. Boric acid poisoning: Report of 11 cases. Can Med Assoc J 90:1018–1023.14166459
Woskie SR, Shen P, Eisen EA, . 1994. The real-time dust exposure of sodium borate workers: Examination of exposure variability. Am Ind Hyg Assoc J 55(3):207–217.8184800
Xiao YK, Li SZ, Wei HZ, . 2007. Boron isotopic fractionation during seawater evaporation. Mar Chem 103(3–4):382–392.
Xing X, Wu G, Wei F, . 2008. Biomarkers of environmental and workplace boron exposure. J Occup Environ Hyg 5:141–147.18183527
Yoshizaki H, Izumi Y, Hirayama C, . 1999. Availability of sperm examination for male reproductive toxicities in rats treated with boric acid. J Toxicol Sci 24(3):199–208.10478334
Ziegler EE, Edwards BB, Jensen RL, . 1978. Absorption and retention of lead by infants. Pediatr Res 12(1):29–34.643372