# 8 REGULATIONS, ADVISORIES, AND GUIDELINES

MRLs are substance specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites.

ATSDR has derived an acute-duration inhalation MRL of 0.3 mg boron/m^3^ for boron. This MRL is based on a NOAEL of 0.8 mg boron/m^3^ for significantly increased nasal secretions in volunteers (Cain et al. 2004) and an uncertainty factor of 3 (10^0.5^ for human variability in the pharmacodynamic response to boron).

ATSDR has derived an acute-duration oral MRL of 0.2 mg boron/kg/day for boron. This MRL is based on a NOAEL of 22 mg boron/kg/day associated with a LOAEL of 44 mg boron/kg/day for increased incidence of external, visceral, and cardiovascular malformations and reduced body weight in the fetuses of rabbits administered boric acid via gavage on gestation days 6–19 (Price et al. 1996b) and an uncertainty factor of 100 (10 for interspecies extrapolation and 10 for human variability).

ATSDR has derived an intermediate-duration oral MRL of 0.2 mg boron/kg/day for boron. This MRL is based on a BMDL_05_ of 10.3 mg boron/kg/day estimated from fetal body weight data from two studies in which pregnant rats were exposed to boron in the diet on gestation days 0–20 (Heindel et al. 1992; Price et al. 1996a) and chemical-specific uncertainty factor of 66 (3.3 for toxicokinetic extrapolation from animals to humans, 3.16 for toxicodynamic extrapolation from animals to humans, 2.0 for variability in human toxicokinetics, and 3.16 for variability in human toxicodynamics).

EPA has established an oral reference dose (RfD) of 0.2 mg/kg/day based on decreased fetal weight in a developmental study in Sprague-Dawley rats orally exposed to boric acid from gestation days 0 to 20 (IRIS 2007). EPA has not established an inhalation reference concentration (RfC) for boron and compounds.

Under the Federal Insecticide, Fungicide, and Rodenticide Act (FIFRA), boron oxide, boric acid, borax, and sodium tetraborate are exempt from tolerances for pesticide chemicals in food (EPA 2007b); they are also listed as inerts of unknown toxicity (List 3) in EPA’s Categorized List of Inert Pesticide Ingredients (EPA 2004).

The international and national regulations, advisories, and guidelines regarding boron in air, water, and other media are summarized in Table 8-1.

Table 8-1 Regulations, Advisories and Guidelines Applicable to Boron and Boron Compounds

Agency | Description | Information | Reference
[underlined: INTERNATIONAL]
Guidelines:
IARC | Carcinogenicity classification | No data | IARC 2006
WHO | Air quality guidelines | No data | WHO 2000
WHO | Drinking water quality guidelines (boron) | 0.5 mg/L^a^ | WHO 2004
[underlined: NATIONAL]
Regulations and Guidelines:
a. Air
ACGIH | TLV (8-hour TWA) | | ACGIH 2006
ACGIH | Borate compounds, inorganic (borax, boric acid, and sodium tetraborate) | 2 mg/m^3^ | ACGIH 2006
ACGIH | Boron oxide | 10 mg/m^3^ | ACGIH 2006
ACGIH | TLV (ceiling) | | ACGIH 2006
ACGIH | Boron tribromide | 10 mg/m^3^ | ACGIH 2006
ACGIH | Boron trifluoride | 3 mg/m^3^ | ACGIH 2006
ACGIH | STEL (15-minute TWA) | | ACGIH 2006
ACGIH | Borate compounds, inorganic (borax, boric acid, and sodium tetraborate) | 6 mg/m^3^ | ACGIH 2006
AIHA | Boron trifluoride | | AIHA 1999
AIHA | ERPG-1^b^ | 2 mg/m^3^ | AIHA 1999
AIHA | ERPG-2^b^ | 30 mg/m^3^ | AIHA 1999
AIHA | ERPG-3^b^ | 100 mg/m^3^ | AIHA 1999
EPA | AEGL-1^c^ (boron trifluoride) | | EPA 2007a
EPA | 10 minutes | 2.5 mg/m^3^ | EPA 2007a
EPA | 30 minutes | 2.5 mg/m^3^ | EPA 2007a
EPA | 60 minutes | 2.5 mg/m^3^ | EPA 2007a
EPA | 4 hours | 2.5 mg/m^3^ | EPA 2007a
EPA | 8 hours | 2.5 mg/m^3^ | EPA 2007a
EPA | AEGL-2^c^ (boron trifluoride) | | EPA 2007a
EPA | 10 minutes | 47 mg/m^3^ | EPA 2007a
EPA | 30 minutes | 47 mg/m^3^ | EPA 2007a
EPA | 60 minutes | 37 mg/m^3^ | EPA 2007a
EPA | 4 hours | 24 mg/m^3^ | EPA 2007a
EPA | 8 hours | 12 mg/m^3^ | EPA 2007a
EPA | AEGL-3^c^ (boron trifluoride) | | EPA 2007a
EPA | 10 minutes | 140 mg/m^3^ | EPA 2007a
EPA | 30 minutes | 140 mg/m^3^ | EPA 2007a
EPA | 60 minutes | 110 mg/m^3^ | EPA 2007a
EPA | 4 hours | 72 mg/m^3^ | EPA 2007a
EPA | 8 hours | 36 mg/m^3^ | EPA 2007a
EPA | Regulated toxic substances and threshold quantities for accidental release prevention pursuant to Section 112(r) of the Clean Air Act | | EPA 2008a; 40 CFR 68.130
EPA | Boron trichloride | 5,000 pounds | EPA 2008a; 40 CFR 68.130
EPA | Boron trifluoride | 5,000 pounds | EPA 2008a; 40 CFR 68.130
NIOSH | REL | | NIOSH 2005
NIOSH | Borax (10-hour TWA) | 5 mg/m^3^ | NIOSH 2005
NIOSH | Boron oxide (10-hour TWA) | 10 mg/m^3^ | NIOSH 2005
NIOSH | Boron tribromide (ceiling) | 10 mg/m^3^ | NIOSH 2005
NIOSH | Boron trifluoride (ceiling) | 3 mg/m^3^ | NIOSH 2005
NIOSH | Sodium tetraborate (10-hour TWA) | 1 mg/m^3^ | NIOSH 2005
NIOSH | IDLH (30-minute exposure) | | NIOSH 2005
NIOSH | Borax | No data | NIOSH 2005
NIOSH | Boron oxide | 2,0000 mg/m^3^ | NIOSH 2005
NIOSH | Boron tribromide | No data | NIOSH 2005
NIOSH | Boron trifluoride | 70 mg/m^3^ | NIOSH 2005
NIOSH | Sodium tetraborate | No data | NIOSH 2005
OSHA | PEL for general industry | | OSHA 2006c; 29 CFR 1910.1000
OSHA | Boron oxide, total dust (8-hour TWA) | 15 mg/m^3^ | OSHA 2006c; 29 CFR 1910.1000
OSHA | Boron trifluoride (ceiling) | 3 mg/m^3^ | OSHA 2006c; 29 CFR 1910.1000
OSHA | PEL for shipyard industry | | OSHA 2006a; 29 CFR 1915.1000
OSHA | Boron oxide, total dust (8-hour TWA) | 15 mg/m^3^ | OSHA 2006a; 29 CFR 1915.1000
OSHA | Boron tribromide (8-hour TWA) | 10 mg/m^3^ | OSHA 2006a; 29 CFR 1915.1000
OSHA | Boron trifluoride (ceiling) | 3 mg/m^3^ | OSHA 2006a; 29 CFR 1915.1000
OSHA | PEL for construction industry | | OSHA 2006b; 29 CFR 1926.55, Appendix A
OSHA | Boron oxide, total dust (8-hour TWA) | 15 mg/m^3^ | OSHA 2006b; 29 CFR 1926.55, Appendix A
OSHA | Boron tribromide (8-hour TWA) | 10 mg/m^3^ | OSHA 2006b; 29 CFR 1926.55, Appendix A
OSHA | Boron trifluoride (ceiling) | 3 mg/m^3^ | OSHA 2006b; 29 CFR 1926.55, Appendix A
OSHA | Threshold quantity of highly hazardous chemicals, toxics, and reactives | | OSHA 2006d; 29 CFR 1910.119
OSHA | Boron trichloride | 2,500 pounds | OSHA 2006d; 29 CFR 1910.119
OSHA | Boron trifluoride | 250 pounds | OSHA 2006d; 29 CFR 1910.119
b. Water
EPA | Drinking water contaminant candidate list | | EPA 1998; 63 FR 10274
EPA | Boron | Yes | EPA 1998; 63 FR 10274
EPA | Drinking water standards and health advisories for boron | | EPA 2006
EPA | 1-day health advisory for a 10-kg child | 4 mg/L | EPA 2006
EPA | 10-day health advisory for a 10-kg child | 0.9 mg/L | EPA 2006
EPA | DWEL | 7 mg/L | EPA 2006
EPA | Lifetime | 1 mg/L | EPA 2006
EPA | 10^-4^ Cancer risk | No data | EPA 2006
EPA | National primary drinking water standards | No data | EPA 2003
c. Food
EPA | Inert pesticide ingredients in pesticide products | | EPA 2004
EPA | Borax, boric oxide, boric acid, and sodium tetraborate | List 3^d^ | EPA 2004
EPA | Tolerances and exemptions from tolerances for pesticide chemicals in food | | EPA 2007c; 40 CFR 180.101
EPA | Borax, boron oxide, boric acid, and sodium tetraborate | Yes | EPA 2007c; 40 CFR 180.101
FDA | EAFUS | | FDA 2007
FDA | Borax, boric acid, and sodium tetraborate | Yes^e^ | FDA 2007
FDA | Indirect food additives: adhesives and components of coatings | | FDA 2006; 21 CFR 175.105
FDA | Borax and boric acid | Yes | FDA 2006; 21 CFR 175.105
d. Other
ACGIH | Carcinogenicity classification | | ACGIH 2006
ACGIH | Borate compounds, inorganic (borax, boric acid, and sodium tetraborate) | A4^f^ | ACGIH 2006
EPA | Carcinogenicity classification (boron and boron compounds) | No data^g^ | IRIS 2007
EPA | RfC (boron and boron compounds) | Not recommended | IRIS 2007
EPA | RfD (boron and boron compounds) | 0.2 mg/kg/day | IRIS 2007
EPA | Superfund, emergency planning, and community right-to-know; effective date of toxic chemical release reporting | | EPA 2007b; 40 CFR 372.65
EPA | Boron tribromide, boron trichloride, and boron trifluoride | 01/01/95 | EPA 2007b; 40 CFR 372.65
EPA | Extremely hazardous substances and their threshold planning quantities | | EPA 2008b; 40 CFR 355, Appendix A
EPA | Boron trichloride | 500 pounds | EPA 2008b; 40 CFR 355, Appendix A
EPA | Boron trifluoride | 500 pounds | EPA 2008b; 40 CFR 355, Appendix A
NTP | Carcinogenicity classification | No data | NTP 2005

a Provisional guideline value because calculated guideline value is below the level that can be achieved through practical treatment methods, source protection, etc.

b ERPG-1 is the maximum airborne concentration below which nearly all individuals could be exposed for up to 1 hour without experiencing other than mild, transient health effects; ERPG-2 is the maximum airborne concentration below which nearly all individuals could be exposed for up to 1 hour without experiencing irreversible or other serious adverse effects; and ERPG-3 is the maximum airborne concentration below which nearly all individuals could be exposed for up to 1 hour without life-threatening health effects (AIHA 1999).

c AEGL-1 is the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience notable discomfort, irritation, or certain asymptomatic nonsensory effects; AEGL-2 is the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience irreversible or other serious, long-lasting adverse health effects or an impaired ability to escape; and AEGL-3 is the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience life-threatening health effects or death (EPA 2007c).

d List 3: inerts of unknown toxicity

e The EAFUS list of substances contains ingredients added directly to food that FDA has either approved as food additives or listed or affirmed as GRAS.

f A4: not classifiable as a human carcinogen

g Data are inadequate for an assessment of human carcinogenic potential.

ACGIH = American Conference of Governmental Industrial Hygienists; AEGL = Acute Exposure Guideline Levels; AIHA = American Industrial Hygiene Association; CFR = Code of Federal Regulations; DWEL = drinking water equivalent level; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; ERPG = Emergency Response Planning Guidelines; FDA = Food and Drug Administration; FR = Federal Register; GRAS = Generally Recognized As Safe; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; STEL = short-term expsoure limit; TLV = threshold limit values; TWA = time-weighted average; WHO = World Health Organization