# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Boron appears in Group 13 (IIIA) of the periodic table and is the only nonmetal of this group (Jansen 2003). Table 4-1 lists common synonyms, trade names, and other pertinent information to identify boron and selected compounds.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Boron is a nonmetal and is typically found in nature bound to oxygen. It is never found as the free element (Cotton et al. 1999). Boron has two stable isotopes, ^10^B and ^11^B, which are naturally present at 19.10–20.31 and 79.69–80.90%, respectively (Jansen 2003). There are ten other known non-radioactive isotopes of boron (Lide 2008). Elemental boron exists in several allotropic forms (Jansen 2003). In addition to being an amphorous powder, boron has four crystalline forms: α-rhombohedral, β-rhombohedral, α-tetragonal, and β-tetragonal (Jansen 2003).

The chemical properties of boron are more similar to carbon and silicon than elements of its own group, although boron is more electron deficient. Boron has a high affinity for oxygen-forming borates, and reacts with water at temperatures above 100 °C to form boric acid and other boron compounds. The electron deficiency of boron does not allow conventional two-electron bonds, but rather multicenter bonds that are exclusively covalent (Jansen 2003; Schubert and Brotherton 2006). Boron hydrides consequently have structures quite different from hydrocarbons (Jansen 2003). The multi-center nature of boron allows the formation of a diverse array of covalent networks, rings, cages, and clusters. Boron forms strong covalent bonds with electronegative elements such as fluorine and oxygen (Schubert and Brotherton 2006).

Table 4-2 lists important physical and chemical properties of boron and selected compounds.

Table 4-1 Chemical Identity of Boron and Selected Boron Compounds^a^

Characteristic | Boron | Boron oxide | Boric acid
Synonym(s) | Boron, metallic | Boric anhydride; boric acid, anhydride; boron sesquioxide; boron trioxide; diboron trioxide; fused boric acid | Orthoboric acid; boron hydroxide; boron trihydroxide
Registered trade name(s) | No data | No data | Optibor^b^
Chemical formula | B | B_2_O_3_ | B(OH)_3_
Chemical structure | Amphorous powder, as well as four crystalline forms: α-rhombohedral, β-rhombohedral, α-tetragonal, and β-tetragonal^c^ | Randomly oriented B_3_O_3_ rings with bridging oxygen atoms^d^ | Planar BO_3_^3-^ units linked by asymmetrical hydrogen bonds^d^
Identification numbers:
CAS registry | 7440-42-8 | 1303-86-2 | 10043-35-3
NIOSH RTECS^e^ | ED7350000 | ED7900000 | ED4550000
EPA hazardous waste | No data | No data | No data
EPA/OPP pesticide Code | 128945 | 011002 | 011001
OHM/TADS | No data | No data | No data
DOT/UN/NA/IMDG shipping | No data | No data | No data
HSDB | 4482 | 1609 | 1432
EINECS | 231-151-2 | 215-125-8 | 233-139-2
NCI | No data | No data | C56417

Characteristic | Borax | Sodium tetraborate | Boron tribromide
Synonym(s) | Sodium borate; sodium tetraborate; borax decahydrate; disodium tetraborate decahydrate | Sodium borate; sodium borate anhydrous; disodium tetraborate; sodium biborate; sodium pyroborate; boric acid, disodium salt | Boron bromide; tribromo-borane; tribromoboron
Registered trade name(s) | Jaikin, Pyrobor, Three Elephant, V-Bor^b^ | Dehybor 65^b^ | No data
Chemical formula | B_4_Na_2_O_7_•10H_2_O | Na_2_B_4_O_7_ | BBr_3_
Chemical structure | [image]; Tetraborate anion in solution^d^ | Anhydrous borates have polymeric assemblies of planar BO_3_ and/or tetrahedral BO_4_ units linked by shared oxygen atoms^d^ | [image]
Identification numbers:
CAS registry | 1303-96-4 | 1330-43-4 | 10294-33-4
NIOSH RTECS^e^ | VZ2275000 | ED4588000 | ED7400000
EPA hazardous waste | No data | No data | No data
EPA/OPP Pesticide Code | 029601 | 011112 | No data
OHM/TADS | No data | No data | No data
DOT/UN/NA/IMDG shipping | No data | No data | UN 2692; IMDG 8.1
HSDB | 328 | 5025 | 327
EINECS | 233-139-2 | 215-540-4 | 233-657-9
NCI | No data | No data | No data

Characteristic | Boron trifluoride | Boron trichloride
Synonym(s) | Anca 1040; boron fluoride; trifluoroborane | Trichloroborane; trichloroboron
Registered trade name(s) | No data | No data
Chemical formula | BF_3_ | BCl_3_
Chemical structure | [image] | [image]
Identification numbers:
CAS registry | 7637-07-2 | 10294-34-5
NIOSH RTECS^e^ | ED2275000 | ED1925000
EPA hazardous waste | No data | No data
EPA/OPP Pesticide Code | No data | No data
OHM/TADS | No data | No data
DOT/UN/NA/IMDG shipping | UN 1008; IMDG 6.1 (boron trifluoride); UN 2851; IMDG 8.2 (boron trifluoride dihydrate) | UN 1741; IMDG 2.2
HSDB | 325 | 326
EINECS | 231-569-5 | 233-658-4
NCI | No data | No data

a All information obtained from HSDB 2009 and ChemIDplus 2009, except where noted.

b NIOSH 2005

c Jansen 2003

d Cotton et al. 1999

e RTECS 2007

CAS = Chemical Abstracts Service; DOT/UN/NA/IMDG = Department of Transportation/United Nations/North America/Intergovernmental Maritime Dangerous Goods Code; EINECS = European Inventory of Existing Chemical Substances; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of Boron and Selected Boron Compounds^a^

Property | Boron | Boron oxide | Boric acid
Molecular weight | 10.811 | 69.620 | 61.833
Physical description | Black or dark brown powder (amorphous form); clear red crystals (α-rhombohedral form); black, opaque crystals with metallic luster (α-tetragonal form); black (β-rhombohedral form) | Colorless, glassy or hexagonal crystals, hygroscopic | Colorless, transparent crystals; white granules or powder
Melting point | 2,075 °C | 450 °C (crystal) | 170.9 °C
Boiling point | 4,000 °C | 1,500 °C (crystal) | No data
Density | 2.350 g/cm^3^ (amorphous); 2.46 g/cm^3^ (α-rhombohedral); 2.31 g/cm^3^ (α-tetragonal); 2.35 g/cm^3^ (β-rhombohedral) | 1.8 g/cm^3^ (amorphous); 2.46 g/cm^3^ (crystal) | 1.435 g/cm^3^ at 15 °C
Odor | No data | Odorless | Odorless
Solubility:
Water | Insoluble | 4.0% at 20 °C | 50 g/L at 25 °C
Organic solvent(s) | Insoluble alcohol, ether | Soluble in alcohol, glycerol | 17.5% in glycerol; 18.5% in ethylene glycol; 173.9 g/L in methanol; 94.4 g/L in ethanol; 0.6% in acetone; 1.5% in ethyl acetate (all at 25 °C)
Other | Soluble in concentrated nitric and sulfuric acids | No data | No data
pK_a_ | No data | No data | 9.42
Log K_ow_ | No data | No data | 0.175
Vapor pressure | 0.0119 mm Hg at 2,140 °C | Negligible at 20 °C | Negligible at 20 °C
Autoignition temperature | 580 °C | No data | No data
Flashpoint | No data | No data | No data
Flammability limits in air | Dust ignites spontaneously in air | Noncombustible | Not flammable
Conversion factors | No data | No data | No data
Explosive limits | No data | No data | No data

Property | Borax | Sodium tetraborate | Boron tribromide
Molecular weight | 381.373 | 201.220 | 250.52
Physical Description | White, monoclinic crystals | Colorless glassy solid; hygroscopic | Colorless, fuming liquid
Melting point | 75 °C (decomposes) | 743 °C | -46.0 °C
Boiling point | No data | 1,575 °C (decomposes) | 90 °C
Density | 1.73 g/cm^3^ | 2.367 g/cm^3^ | 2.698 g/cm^3^ at 0 °C
Odor | Odorless | Odorless | Sharp, irritating odor, pungent
Solubility:
Water | 59.3 g/L at 25 °C | 3.1% at 25 °C | Decomposes in water
Organic solvents | 1 g/1 mL in glycerol; insoluble in alcohol | 16.7% in methanol; 30% in ethylene glycol; 40.6 g/L in formamide (all at 25 °C) | Decomposes in alcohol; soluble in carbon tetrachloride, sulfur dioxide (liquid), carbon disulfide
Other | Insoluble in acid | No data | No data
pK_a_ | No data | No data | No data
Log K_ow_ | No data | No data | No data
Vapor pressure | Negligible | Negligible at 20 °C | 100 mm Hg at 33.5 °C
Autoignition temperature | No data | No data | No data
Flashpoint | No data | No data | No data
Flammability limits in air | Not flammable | Noncombustible | Nonflammable
Conversion factors | No data | No data | 1 ppm=10.25 mg/m^3b^
Explosive limits | No data | No data | No data

Property | Boron trifluoride | Boron trichloride
Molecular weight | 67.81 | 117.17
Physical Description | Colorless gas | Colorless fuming liquid at low temperature
Melting point | -126.8 °C | -107 °C
Boiling point | -101 °C | 12.5 °C
Density | 3.07666 g/L at 1 atm, 0 °C | 1.3728 g/cm^3^ at 0 °C
Odor | Pungent, suffocating odor, irritating^c^ | Pungent, suffocating odor, irritating, sharp
Solubility:
Water | 332 g/100 g water at 0 °C with some hydrolysis forming fluoboric and boric acids | Decomposes in water, hydrolyzed easily
Organic solvents | Soluble in benzene, dichlorobenzene, chloroform, carbon tetrachloride, carbon sulfide; soluble in most saturated and halogenated hydrocarbons and in aromatic compounds | Decomposes in alcohol
Other | 1.94 g/100 g in anhydrous sulfuric acid, soluble in concentrated nitric acid | No data
pK_a_ | No data | No data
Log K_ow_ | No data | No data
Vapor pressure | 3.656x10^4^ mm Hg at −13.2 °C | 1 mm Hg at 25 °C (extrapolated)
Autoignition temperature | No data | No data
Flashpoint | No data | No data
Flammability limits in air | Nonflammable | Nonflammable
Conversion factors | 1 ppm=2.77 mg/m^3b^ | No data
Explosive limits | No data | No data

a All information from HSDB 2009, except where noted.

b NIOSH 2009

c Odor threshold 4.50 mg/m^3^ (Ruth 1986)