# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology and Environmental Medicine, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-62, Atlanta, Georgia 30333.

## Boron and Compounds Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Boron and Compounds
CAS Number: | 7440-42-8
Date: | August 2009
Profile Status: | Final Draft Post-Public Comment
Route: | [X] Inhalation [ ] Oral
Duration: | [X] Acute [ ] Intermediate [ ] Chronic
Graph Key: | 2
Species: | Human

[underlined: Minimal Risk Level]: 0.3 [X] mg/m^3^ [ ] ppm

[underlined: Reference]: Cain WS, Jalowayski AA, Kleinman M, . 2004. Sensory and associated reactions to mineral dusts: Sodium borate, calcium oxide, and calcium sulfate. J Occup Environ Hyg 1:222–236 15204861 .

Cain WS, Jalowayski AA, Schmidt R, . 2008. Chemesthetic responses to airborne mineral dusts: boric acid compared to alkaline materials. Int Arch Occup Environ Health 81:337–345 17609973 .

[underlined: Experimental design]: Male and female volunteers were trained to recognize the difference in chemesthetic feel (pungency or irritancy) of various levels of CO_2_ offered to the eyes, nose, and throat. Exposures of ≥17.7% CO_2_ resulted in a “feel” described by the volunteers as irritating. Twelve male volunteers were exposed to 0, 0.8, 1.5, 3.0, 4.5, or 6.0 mg boron/m^3^ (0, 5, 10, 20, 30, or 40 mg sodium borate pentahydrate/m^3^) for 20 minutes while performing light exercise (Cain et al. 2004). At 5-minute intervals, they reported the magnitude of “feel” of borate dust in terms of equivalent CO_2_ irritancy. They were also observed for changes in nasal secretions (by mass) and nasal airway resistance relative to pre-exposure measurements. Data were reported as means of all responses at each concentration and time point.

In a similar fashion, six male and six female volunteers were exposed to 1.5 mg boron/m^3^ (10 mg sodium borate/m^3^) or 1.8 mg boron/m^3^ (10 mg boric acid/m^3^) for 47 minutes while exercising. They reported the magnitude of “feel” of boric acid and borate dusts in terms of equivalent CO_2_ irritancy. They were also observed for changes in nasal secretions (by mass), nasal airway resistance, and respiration frequency.

[underlined: Effects noted in study and corresponding doses]: Male volunteers exposed to ≤3.0 mg boron/m^3^ (≤20 mg sodium borate/m^3^) for 20 minutes reported increasingly higher magnitude of feel of the dust in eyes, nose, and throat. However, the mean reported level of feel, compared to equivalent CO_2_ levels, was not considered irritating by the study subjects. The mean reported perception of feel at ≥4.5 mg boron/m^3^ (≥30 sodium borate/m^3^) was reported to feel irritating to the nose (Cain et al. 2004). Significantly increased nasal secretions (by mass) occurred at 1.5 mg boron/m^3^ (10 mg sodium borate/m^3^), but not 0.8 mg boron/m^3^ (5 mg sodium borate/m^3^) (Cain et al. 2004). Similarly, male and female volunteers exposed to 1.5 mg boron/m^3^ (10 mg sodium borate/m^3^) or 1.8 mg boron/m^3^ (10 mg boric acid/m^3^) for 47 minutes while exercising reported a mean sense of feel that initially increased and peaked at the equivalent of slightly <17.7% CO_2_. Boron exposures with a mean reported feel equivalent to less than 17.7% CO_2_ are considered non-irritating, although increases in nasal secretions were observed at 1.8 mg boron/mg^3^ (10 mg boric acid/m^3^), but not at 0.9 mg boron/mg^3^ (5 mg boric acid/m^3^) (Cain et al. 2008). Nasal airway resistance decreased, then increased, as a result of exercise, but did not change in a dose-related manner.

[underlined: Dose and end point used for MRL derivation]: A NOAEL of 0.8 mg/m^3^ associated with a minimal LOAEL of 1.5 mg/m^3^ for significantly increased volume of nasal secretions.

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [ ] 10 for extrapolation from animals to humans
- [X] 3 for human variability

[underlined: Was a conversion used from ppm in food or water to a mg/body weight dose?] No.

[underlined: If an inhalation study in animals, list the conversion factors used in determining human equivalent dose:] Not applicable.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: In an early cross-sectional study of sodium borate workers, past occurrence of symptoms of respiratory irritation such as dryness of the mouth, nose, or throat, dry cough, nose bleeds, and sore throat were reported at elevated frequencies in workers in areas with mean dust concentrations of 8.4 and 14.6 mg particulates/m^3^ (1.8 and 3.1 mg boron/m^3^, respectively), compared with workers in areas with lower mean dust levels of 4.0 and 1.1 mg particulate/m^3^ (0.9 and 0.2 mg boron/m^3^) (Garabrant et al. 1984, 1985). In addition, a reduction in forced expiratory volume in 1 second (FEV_1_) was measured in a subgroup of smoking workers with estimated high cumulative exposure (≥80 mg particulate/m^3^, ≥9 mg boron/m^3^) to sodium borate dusts, but not in groups of less-exposed smoking workers or in nonsmoking workers. However, a subsequent survey of FEV_1_ in 303 of the original 629 borax workers, 7 years after the original survey, found no exposure-related changes in FEV_1_ over this period, when adjustments were made for the effects of age, height, and smoking on FEV_1_ (Wegman et al. 1994). Acute-duration laboratory exposures of volunteers to sodium borate dust support the findings of respiratory irritation reported in the occupational studies.

The occurrence of acute respiratory symptoms as a possible consequence of acute exposure to dusts of sodium borate (the decahydrate, pentahydrate, and anhydrous tetraborates) was studied in a later study by interviewing workers about acute irritation symptoms before the work shift began and at regular hourly intervals during the work shift, and by measuring personal air concentrations of particulates at concurrent intervals for 4 consecutive days (Hu et al. 1992; Wegman et al. 1991, 1994). Seventy-nine exposed production workers and 27 nonexposed workers were included in the study. In the latest analysis of the collected data, the incidence rates for irritation symptoms in exposed workers were statistically significantly higher than those in nonexposed workers, with exposed workers 9-, 5-, and 3-fold more likely to report incidents of nasal, eye, and throat irritation, respectively, than comparison workers (Hu et al. 1992; Wegman et al. 1991, 1994). For the unexposed groups, the arithmetic means of the 6-hour TWA daily dust concentration was 0.45 mg particulates/m^3^ (0.02 mg boron/m^3^), with 100% of samples ≤1.0 mg particulates/m^3^ and about 90% of samples ≤0.5 mg particulates/m^3^. The arithmetic mean of the 6-hour TWA daily dust concentrations for the exposed group was 5.72 mg particulates/m^3^ (0.44 mg boron/m^3^), with a majority of air concentrations between 1.0 and 10.0 mg particulates/m^3^ (Wegman et al. 1991, 1994). Several factors make it difficult to identify a NOAEL or LOAEL for this study, precluding inclusion of this study in Figure and Table 3-1. Study participants rated their perception of individual episodes of eye, throat, and nasal irritancy on a scale of 0 (not at all) to 10 (very, very much), with ratings of 1, 2, and 3 representing “very little”, “fairly little”, and “moderate” irritation, respectively. Unexposed responders to the pre-shift survey reported a mean rating of 1.9 for all symptoms, while the mean rating for nasal irritation (the most commonly reported effect) among exposed workers was just slightly higher at 2.2. Thus, the cutoff for boron dust-induced effects is likely to be for ratings of ≥3. In the exposed group, 91% of reported symptoms were rated with severity scores ≤3 and 96% of symptoms were rated with severity scores of ≤4 (“pretty much”). For incidences in which the workers depressed a counter button to record time of symptom onset, and the study surveyor recorded an occurrence of effect, the probability of reporting an effect did not change markedly until 0.25-hour TWA exposure levels reached 0.8–1.2 mg boron/m^3^ (Wegman et al. 1991). There was no significant difference in reporting of symptoms based on the type of borate dust, which differ in boron content by almost a factor of two (i.e., 4.7 mg anhydrous borax/m^3^ and 8.8 mg/m^3^ of the decahydrate provide 1 mg boron/m^3^). Finally, the data do not indicate a temporal increase in effect intensity, as would be expected for a local irritant.

An uncertainty factor of 3 for human variability was based on the fact that inhaled borates and boric acid exert their adverse effects on respiratory tract tissues as portal-of-entry irritants. For portal-of-entry inhalation toxicants, the variability between humans in pharmacokinetics (i.e., toxicant deposition in the respiratory tract) is minimal. Thus, half (10^0.5^, or 3) of the composite uncertainty factor for pharmacokinetic and pharmacodynamic variability in humans should be applied to the identified NOAEL.

[underlined: Agency Contacts (Chemical Managers)]: Malcolm Williams

## Boron and Compounds Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Boron and Compounds
CAS Number: | 7440-42-8
Date: | August 2009
Profile Status: | Final Draft Post-Public Comment
Route: | [ ] Inhalation [X] Oral
Duration: | [X] Acute [ ] Intermediate [ ] Chronic
Graph Key: | 22
Species: | Rabbit

[underlined: Minimal Risk Level]: 0.2 [X] mg/kg/day [ ] ppm

[underlined: Reference]: Price CJ, Marr MC, Myers CB, . 1996b. The developmental toxicity of boric acid in rabbits. Fundam Appl Toxicol 34:176–187 8954748 .

The results of this study have also been reported in the following references:

Heindel JJ, Price CJ, Schwetz BA. 1994. The developmental toxicity of boric acid in mice, rats, and rabbits. Environ Health Perspect Suppl 102(7):107–112.

NTP. 1991. Final report on the developmental toxicity of boric acid (CAS No. 10043-35-3) in New Zealand white rabbits. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. PB92129550.

[underlined: Experimental design]: Groups of 30 pregnant New Zealand white rabbits were given gavage doses of 0, 62.5, 125, or 250 mg boric acid/kg/day (0, 11, 22, or 44 mg boron/kg/day) on gestation days 6–19. Observations were made for clinical signs, maternal and fetal body weight, number of implantations, resorptions, number of live and dead fetuses, and fetal external, visceral, and skeletal defects.

[underlined: Effects noted in study and corresponding doses]: No adverse maternal effects were observed in the 11 or 22 mg boron/kg/day groups. At 44 mg boron/kg/day, decreases in maternal body weight, relative kidney weight, and food consumption were observed. During the treatment period, the rabbits lost 137 g body weight compared to a weight gain of 93 g in controls. No differences in the number of implantation sites per litter were observed; however, there were significant increases in the percent resorptions per litter (6.3, 5.9, 7.7, and 89.9% in the 0, 11, 22, and 44 mg boron/kg/day groups, respectively), percent of litters with one or more resorptions (39, 39, 45, and 95%), and percent of litters with 100% resorption (0, 0, 0, and 73%). The number of live litters was 18, 23, 20, and 6 in the 0, 11, 22, and 44 mg boron/kg/day groups, respectively, and the number of live fetuses was 159, 175, 153, and 14, respectively. A decrease in fetal body weights (92% of controls) was observed at 44 mg boron/kg/day; although the body weight was not significantly different from controls, the effect was considered biologically significant. Significant increases in the percent of fetuses per litter with external (0.8, 1.4, 1.0, and 11.1% in the 0, 11, 22, and 44 mg boron/kg/day groups, respectively), visceral (7.3, 5.9, 7.4, and 80.6%), cardiovascular malformations (2.7, 3.1, 4.2, and 72.2%) and cardiovascular variations (10.6, 5.7, 7.2, and 63.9%) were observed. Although the overall incidence of external malformations was increased at 44 mg boron/kg/day, there were no increases in a specific malformation. The visceral malformations primarily consisted of cardiovascular malformations, particularly interventricular septal defect, enlarged aorta, papillary muscle malformation, and double outlet right ventricle. The cardiovascular variations consisted of abnormal number of cardiac papillary muscles.

[underlined: Dose and end point used for MRL derivation]: NOAEL of 22 mg boron/kg/day as boric acid associated with a LOAEL of 44 mg boron/kg/day as boric acid for developmental effects

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion used from ppm in food or water to a mg/body weight dose?] No.

[underlined: If an inhalation study in animals, list the conversion factors used in determining human equivalent dose:] Not applicable.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: A series of studies conducted by Cherrington and Chernoff (2002) also examined the developmental toxicity of boron. A variety of skeletal malformations (including rib agenesis, cervical rib, and fused ribs) were observed in the fetuses of mice receiving two gavage doses of 70 mg boron/kg on gestation day 8 or gestation days 6–8, once daily dose of 88 mg boron/kg/day on gestation days 6–10, or one dose of 131 mg boron/kg on gestation day 8. Multiple thoracic skeletal malformations were observed in the fetuses of mice receiving two doses of 131 mg boron/kg on gestation day 8. Decreases in fetal body weight were also observed in these studies and in studies of mice receiving two gavage doses of 70 mg boron/kg on gestation day 6, 7, 9, or 10.

Developmental effects have also been observed in intermediate-duration studies. Decreases in fetal body weight were observed in rats exposed to 13 or 13.6 mg boron/kg/day on gestation days 0–20 (Heindel et al. 1992; Price et al. 1996a), increases in skeletal abnormalities were observed in rats exposed to 13 mg boron/kg/day on gestation days 0–20 (Price et al. 1996a), and rib cage defects and enlargement of the brain lateral ventricles were observed in rats exposed to 28.4 mg boron/kg/day on gestation days 0–20 (Heindel et al. 1992). In mice exposed to boric acid on gestation days 0–17, reduced fetal body weight and increased skeletal defects were observed at 79 and 175.3 mg boron/kg/day, respectively.

[underlined: Agency Contacts (Chemical Managers)]: Malcolm Williams

## Boron and Compounds Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Boron and Compounds
CAS Number: | 7440-42-8
Date: | August 2009
Profile Status: | Final Draft Post-Public Comment
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 60, 61
Species: | Rat

[underlined: Minimal Risk Level]: 0.2 [X] mg/kg/day [ ] ppm

[underlined: Reference]: Heindel JJ, Price CJ, Field EA, . 1992. Developmental toxicity of boric acid in mice and rats. Fundam Appl Toxicol 18:266–277 1601227 .

[underlined: Experimental design]: Groups of 26–28 pregnant Sprague-Dawley rats and Swiss mice were exposed to 0, 0.1, 0.2, or 0.4% boric acid in the diet on gestation days 0–20. Estimated boron doses are 0, 13.6, 28.5, or 57.7 mg boron/kg/day (0, 78, 163, or 330 mg boric acid/kg/day) for rats and 0, 43, 79, or 176 mg boron/kg/day (0, 248, 452, or 1,003 mg boric acid/kg/day) for mice. Daily observations were made for clinical signs and food and water consumption. At death, body and organ weights were recorded. Maternal kidneys were examined microscopically. Live fetuses were excised, anesthetized, weighed, and examined for skeletal malformations.

[underlined: Effects noted in study and corresponding doses]: Decreased maternal weight gain was observed in the 57.7 mg boron /kg/day group of rats, but not when corrected for gravid uterine weight. Decreased relative kidney and liver weights were seen in the 28.4 mg boron/kg/day group. The incidence and severity of the minimal maternal nephropathy was not dose-related. Mean fetal body weight per litter was significantly reduced (7–15%) in all treated groups. Significant increases in the percentage of malformed fetuses/litter or litter with one or more malformed fetuses was observed at doses ≥28.5 mg boron/kg/day. Noted malformations included anomalies of the eye, central nervous system, cardiovascular system, and axial skeleton. Enlarged lateral ventricles of the brain and agenesis or shortening of the 13^th^ rib were seen in the 57.7 mg boron/kg/day group.

[underlined: Reference]: Price PJ, Strong PL, Marr MC, . 1996a. Developmental toxicity NOAEL and postnatal recovery in rats fed boric acid during gestation. Fundam Appl Toxicol 32:179–193 8921321 .

[underlined: Experimental design]: Groups of 60 female Sprague-Dawley rats were exposed to 0, 0.025, 0.050, 0.075, 0.100, or 0.200% boric acid in the diet on gestation days 0–20. Observations were made for body weight, clinical signs, and food and water consumption. The study was performed in two phases; offspring were evaluated in both phases for post-implantation mortality, body weight, and external, visceral, and skeletal morphology. Phase I was terminated on gestation day 20. The calculated average maternal dose of boron was 0, 3.3, 6.3, 10, 13, or 25 mg boron/kg/day (0, 19, 36, 55, 76, or 143 mg boric acid/kg/day). Phase II dams were allowed to litter and rear their pups until postnatal day (pnd) 21. For these dams, the calculated average doses of boron were 0, 0.2, 6.5, 9.7, 12.9, and 25.3 mg/kg/day (0, 19, 37, 56, 74, and 145 mg boric acid/kg/day). During this phase, the incidence of skeletal defects in control and exposed pups was evaluated at the end of the first 21 postnatal days.

[underlined: Effects noted in study and corresponding doses]: During Phase I of the study, no maternal deaths or clinical signs were associated with boric acid treatment. When corrected for gravid uterine weight, maternal weight gain was not affected. However, reduced gravid uterine weight resulted in significant trend tests for decreased maternal body weight (gestation days19 and 20) and decreased maternal body weight gain (gestation days 15–18 and 0–20). Dams in the 25 mg boron/kg/day group had a 10% reduction (statistically significant in the trend test, p<0.05) in gravid uterine weight compared with controls. Fetal body weights were significantly decreased in the 13 and 25 mg boron/kg/day groups (6 and 12% less than controls) on gestation day 20. Incidences of external or visceral malformations or variations were not treatment-related. However, a significant increase was observed for percentage of fetuses with skeletal malformations (short rib XIII) per litter and variations (wavy rib or wavy rib cartilage) in the 13 and 25 mg boron/kg/day groups. A significant trend test (p<0.05) resulted for decrease in rudimentary extra rib on lumbar I (a variation). The LOAEL for Phase I of this study was identified as 13 mg boron/kg/day, based on decreased fetal body weight and skeletal malformations. The NOAEL for this phase was identified as 10 mg boron/kg/day.

In the Phase II study, a significant trend for increased number and percent of dead pups was seen between pnd 0 and 4, but not between pnd 4 and 21. This appeared to be due to the non-significant early postnatal mortality in the 25.3 mg boron/kg/day group. There were no effects of boric acid on the pup body weight from pnd 0 to 21; therefore, fetal body weight deficits (identified in Phase I) did not continue into the postnatal period (Phase II). The percentage of pups per litter with short rib XIII was increased on pnd 21 in the 25.3 mg boron/kg/day group. A LOAEL of 25.3 mg boron/kg/day, with an associated NOAEL of 12.9 mg boron/kg/day, was identified for skeletal malformations in Phase II of this study.

[underlined: Dose and end point used for MRL derivation]: BMDL_05_ of 10.3 mg/kg/day for reduced fetal body weight

[ ] NOAEL [ ] LOAEL [X] BMDL_05_

Allen et al. (1996) performed multiple benchmark dose (BMD) analyses on single-study or combined data from Heindel et al. (1992) and Price et al. (1996a) for all statistically significant developmental end points (Table A-1). Fetal body weight changes were analyzed using the average fetal weight for each litter with live fetuses. The modeling of rib effects aimed to differentiate whether treatment-related differences in the lumbar rib were variations or malformations. Thus, a weighting scheme was applied to represent three possible interpretations of severity of this effect; that is, a missing rib is: (a) trivially different from “normal” (1/6 weighting), (b) intermediate between a trivial or frank malformation (1/2 weighting), or (c) considered a frank malformation (5/6 weighting). Rib count analysis involved adjusting up (if rudimentary or full lumbar ribs present) or down (shortened rib XIII or rib agenesis) the base count of 13 rib pairs for each fetus analyzed. Benchmark responses (BMRs) were chosen for each end point. The BMD expected to result in the BMR, while the BMDL_05_ was defined as the 95% lower bound on the BMD. The data were modeled with a continuous power model using an F-test evaluation of goodness of fit.

Table A-1 Benchmark Dose Modeling of Developmental Effects of Oral Boric Acid Exposure to Rats

End point | Study data | Goodness-of-fit p-value^a^ | BMD^b^ (mg boron/kg/day) | Lower bound on BMD^c^ (mg boron/kg/day)
Fetal body weight as continuous data (BMR=5% reduction) | Heindel et al. 1994 | 0.24 | 14.0 | 9.8
Fetal body weight as continuous data (BMR=5% reduction) | Price et al. 1996a | 0.89 | 11.9 | 8.2
Fetal body weight as continuous data (BMR=5% reduction) | Combined | 0.58 | 13.7 | 10.3
Fetal body weight as continuous data (BMR=1/2 standard deviation below control) | Heindel et al. 1994 | 0.24 | 12.8 | 8.4
Fetal body weight as continuous data (BMR=1/2 standard deviation below control) | Price et al. 1996a | 0.89 | 8.6 | 5.4
Fetal body weight as continuous data (BMR=1/2 standard deviation below control) | Combined | 0.58 | 11.4 | 8.4
Fetal body weight as dichotomous incidence data (BMR=5% reduction) | Heindel et al. 1994 | 0.44 | 22.6 | 20.1
Fetal body weight as dichotomous incidence data (BMR=5% reduction) | Price et al. 1996a | 0.01 | 8.2 | 5.4
Fetal body weight as dichotomous incidence data (BMR=5% reduction) | Combined | NA | NA | NA
Shortening or agenesis of rib XIII | Heindel et al. 1994 | 0.07 | 24.9 | 18.6
Shortening or agenesis of rib XIII | Price et al. 1996a | 0.64 | 29.9 | 21.5
Shortening or agenesis of rib XIII | Combined | 0.42 | 24.5 | 21.0
Missing lumbar ribs | Heindel et al. 1994 | 0.99 | 1.2 | 0.3
Missing lumbar ribs | Price et al. 1996a | 0.78 | 1.5 | 0.6
Missing lumbar ribs | Combined | 0.99 | 2.1 | 0.9
Rib effects analysis: 1/6 weighting for absence of lumbar rib | Heindel et al. 1994 | 0.27 | 21.2 | 16.5
Rib effects analysis: 1/6 weighting for absence of lumbar rib | Price et al. 1996a | 0.78 | 32.9 | 25.7
Rib effects analysis: 1/6 weighting for absence of lumbar rib | Combined | NA | NA | NA
Rib effects analysis: 1/2 weighting for absence of lumbar rib | Heindel et al. 1994 | 0.02 | 13.5 | 10.2
Rib effects analysis: 1/2 weighting for absence of lumbar rib | Price et al. 1996a | 0.64 | 45.3 | 30.3
Rib effects analysis: 1/2 weighting for absence of lumbar rib | Combined | NA | NA | NA
Rib effects analysis: 5/6 weighting for absence of lumbar rib | Heindel et al. 1994 | <0.001 | 24.9 | 20.5
Rib effects analysis: 5/6 weighting for absence of lumbar rib | Price et al. 1996a | 0.53 | 53.7 | 31.2
Rib effects analysis: 5/6 weighting for absence of lumbar rib | Combined | NA | NA | NA
Rib effects analysis: rib count for absence of lumbar rib | Heindel et al. 1994 | 0.002 | 16.5 | 12.8
Rib effects analysis: rib count for absence of lumbar rib | Price et al. 1996a | 0.08 | 25.6 | 16.5
Rib effects analysis: rib count for absence of lumbar rib | Combined | NA | NA | NA

a p-values for assessing adequacy of the models for predicting the observed data of Heindel et al. (1992) and Price et al. (1996a)

b Benchmark dose: model estimated dose expected to result in the BMR

c 95% lower bound on the BMD

BMR = benchmark response; NA = not applicable

Source: Heindel et al. 1992; Price et al. 1996a

A likelihood ratio test indicated that the response data from both studies could be modeled as a single dose-response function. Of the developmental end points modeled, the lowest resulting BMDL_05_ was 10.3 mg boron/kg/day for fetal body weight (litter weight averages), which was similar to the NOAEL of 10 mg boron/kg/day from the Price et al. (1996a) study.

[underlined: Uncertainty Factors used in MRL derivation]: A total uncertainty factor of 66 was used.

- [ ] 10 for use of a LOAEL
- [X] 3.3 for extrapolation of toxicokinetics from animals to humans
- [X] 3.16 for extrapolation of toxicodynamics from animals to humans
- [X] 2.0 for human toxicokinetic variability
- [X] 3.16 for human toxicodynamic variability

In deriving a reference dose (RfD) for chronic oral exposures to boron, the U.S. EPA applied chemical-specific uncertainty factors to the BMDL_05_ of 10.3 mg boron/kg/day reported by Allen et al. (1996) (EPA 2004). Rather than using the default uncertainty factors of 10 for interspecies extrapolation and 10 for interindividual human variability, each uncertainty factor was further delineated into toxicokinetic and toxicodynamic components specific to boron. Since the critical effect (reduced fetal body weight in animals) and point of departure (BMDL_05_ of 10.3 mg/kg/day) for intermediate oral exposure to boron are the same as those for chronic oral exposures, as identified by EPA (2004), the chemical-specific uncertainty factors derived by U.S. EPA to derive a chronic RfD are appropriate for use in deriving the intermediate-duration MRL.

Briefly, each uncertainty factor of 10 for extrapolation from animals to humans and human variability was initially separated into default toxicokinetic and toxicodynamic adjustment factors of 3.16 (10^0.5^) each to account for species differences in toxicokinetic disposition and toxicodymanic responses to orally-ingested boron. The same division was made for the uncertainty factor of 10 for human variability. Thus, the composite uncertainty factor (UF_TOTAL_) for the intermediate-duration oral MRL is defined as given by EPA (2004) as:

UF_TOTAL_ = ( AF_AK_ × AF_AD_ × AF_HK_ × AF_HD_ × UF )

where:

- AF_AK_ = interspecies toxicokinetic adjustment factor
- AF_AD_ = interspecies toxicodynamic adjustment factor
- AF_HK_ = interindividual toxicokinetic adjustment factor
- AF_HD_ = interindividual toxicodynamic adjustment factor
- UF = other uncertainty factors (e.g., use of a LOAEL instead of a NOAEL)

Since no data were available to adequately describe the mode(s) or mechanism(s) of action for boron toxicity in animals or humans, the default toxicodynamic adjustment factor of 3.16 was used to account for inter- and intraspecies uncertainties in toxicodynamics.

The pregnant female is considered to be a sensitive population for boron exposure, as fetal effects in rats are the most sensitive end point identified for boron toxicity. Since boron exhibits near first-order toxicokinetics, distributing freely between total body water and tissues (except for bone, in which it accumulates to approximately 4-fold that of plasma [Chapin et al. 1997]), variability between maternal and fetal kinetics should be essentially equal. Thus, maternal boron plasma concentration is an appropriate surrogate for fetal plasma levels. No data are available to relate rat and human plasma boron concentration. However, boron is not metabolized, but almost completely eliminated in the urine, making renal clearance an appropriate kinetic factor for comparison of toxicokinetic differences between rats and humans. Given the known distribution of boron to total body water and bone, two-compartment pharmacokinetic models for boron in rats and humans can describe plasma concentration in terms of renal clearance. Boron’s toxicity is likely to be related to a continuous exposure over an extended portion of fetal development in which a steady state of circulating boron is achieved. Under the assumption of steady-state plasma boron levels, and assuming approximately complete clearance of born to urine, the two-compartment model can be simplified to the following expression:

Css = ( D_e_ × f_a_ × BW ) / Cl

where:

- D_e_ = external dose of ingested boron (mg boron/kg body weight/day)
- f_a_ = fraction of ingested boron absorbed from the gut
- BW = body weight (kg)
- Cl = renal clearance (mL/minute)

Assuming that the ratio of 1 for internal, steady-state doses in rats and humans results in equivalent responses, the expressions for the plasma boron concentration in rats and humans can be expressed as the following ratio, which serves as the AF_AK_:

AF_AK_ = ( Cl_R_ × f_AH_ × BW_H_ ) / ( Cl_H_ × f_AR_ × BW_R_ )

where the subscripts R and H represent rats and humans. Values for mean renal clearance of 1.0 and 66.1 mL/minute in pregnant rats and humans, respectively, were derived from the studies of Vaziri et al. (2001), and Pahl et al. (2001), which also provided pregnant rat and human body weights of 0.303 and 67.6 kg, respectively. Using gastrointestinal absorption fractions of 0.92 (Schou et al. 1984) and 0.95 (Vanderpool et al. 1994) for f_AH_ and f_AR_, respectively, AF_AK_ is derived as follows:

AF_AK_ = ( 1.00 × 0.92 × 67.6 ) / ( 66.1 × 0.95 × 0.303 ) = 62.2 / 19.0 = 3.3

The assessment of human variability in boron toxicokinetics utilized glomerular filtration rate (GFR) as a surrogate for renal clearance. Pregnant women were considered the sensitive population, particularly those women with compromised renal function (3–5% preeclamptic women in the U.S. population). Using a modification of Dourson et al. (1998), data from women with normal renal function were used to define an AF_HK_ as:

AF_HK_ = GFR_AVG_ / ( GFR_AVG_ − ( 3 × SD_GFR_ ) )

where GFR_AVG_ and SD_GFR_ are mean and standard deviation of the GFR for healthy women. Three standard deviations below the mean GFR was chosen to account for the women with very low GFR. From the studies of Dunlop (1981), Krutzen et al. (1992), and Sturgiss et al. (1996), a mean GFR of 161.5 mL/minute and a mean GFR-3SD_GFR_ of 85.8 mL/minute resulted in an AF_HK_ of 1.93. This number was rounded to 2.0 to account for uncertainties in human GFR.

Based on these analyses, the total uncertainty factor applied to the BMDL_05_ of 10.3 mg boron/kg is derived as:

UF_TOTAL_ = ( AF_AK_ × AF_AD_ × AF_HK_ × AF_HD_ × UF ) = ( 3.3 × 3.16 × 2.0 × 3.16 × 1 ) = 66

[underlined: Was a conversion used from ppm in food or water to a mg/body weight dose]? No.

[underlined: If an inhalation study in animals, list the conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Reproductive effects, including testicular atrophy and histopathology, sperm abnormalities, and reduced sperm production have been observed in mice, rats, and dogs after intermediate-duration ingestion of doses of 26 mg boron/kg/day (as boric acid or borax) and higher (Dixon et al. 1979; Fukuda et al. 2000; Harris et al. 1992; Ku et al. 1993a; Kudo et al. 2000; Seal and Weeth 1980; Treinen and Chapin 1991; Weir and Fisher 1972; Yoshizaki et al. 1999). Systemic effects have been observed in rats and dogs at higher doses. Hematological alterations (splenic extramedullary hematopoiesis and decreased hemoglobin levels) have been observed at 60.5 or 72 mg boron/kg/day (NTP 1987; Weir and Fisher 1972), desquamation of skin on paws and tail and inflamed eyes have been observed in rats exposed to 150 mg boron/kg/day (Weir and Fisher 1972), and hyperkeratosis and/or acanthosis of the stomach has been observed at 577 mg boron/kg/day (NTP 1987).

[underlined: Agency Contacts (Chemical Managers)]: Malcolm Williams