# CHAPTER 8 REFERENCES

Abraham JL, Chandra S, Agrawal A. 2014. Quantification and micron-scale imaging of spatial distribution of trace beryllium in shrapnel fragments and metallurgic samples with correlative fluorescence detection method and secondary ion mass spectrometry (SIMS). J Microsc 256(2):145–152. 10.1111/jmi.12170.25146877
ACAA. 2017a. Fly ash production and use with percent. American Coal Ash Association. https://www.acaa-usa.org/Portals/9/Files/PDFs/2017-Charts.pdf. December 15, 2022.
ACAA. 2017b. 2017 Coal combustion product (CCP) production & use survey report. American Coal Ash Association. https://www.acaa-usa.org/Portals/9/Files/PDFs/2017-Survey-Results.pdf. December 15, 2022.
Aldahan A, Haiping Y, Possnert G. 1999. Distribution of beryllium between solution and minerals (biotite and albite) under atmospheric conditions and variable pH. Chem Geol 156(1):209–229. 10.1016/S0009-2541(98)00186-7.
Allen GT, Blackford SH, Tabor VM, . 2001. Metals, boron, and selenium in Neosho Madtom habitats in the Neosho River in Kansas, U.S.A. Environ Monit Assess 66(1):1–21. 10.1023/A:1026433229820.11214445
American College of Chest Physicians. 1965. Beryllium disease: Report of the section on nature and prevalence committee on occupational diseases of the chest American College of Chest Physicians. Dis Chest 48(5):550–558. 10.1378/chest.48.5.550.4221354
Amicosante M, Fontenot AP. 2006. T cell recognition in chronic beryllium disease. Clin Immunol 121(2):134–143. 10.1016/j.clim.2006.03.012.16697706
Amicosante M, Sanarico N, Berretta F, . 2001. Beryllium binding to HLA-DP molecule carrying the marker of susceptibility to berylliosis glutamate β69. Hum Immunol 62(7):686–693. 10.1016/S0198-8859(01)00261-0.11423174
Amicosante M, Berretta F, Franchi A, . 2002. HLA-DP-unrestricted TNF-α release in beryllium-stimulated peripheral blood mononuclear cells. Eur Respir J 20(5):1174–1178. 10.1183/09031936.02.02232001.12449171
Amicosante M, Berretta F, Rossman M, . 2005. Identification of HLA-DRPheβ47 as the susceptibility marker of hypersensitivity to beryllium in individuals lacking the berylliosis-associated supratypic marker HLA-DPGluβ69. Respir Res 6(1):94. 10.1186/1465-9921-6-94.16098233
Amicosante M, Berretta F, Dweik R, . 2009. Role of high-affinity HLA-DP specific CLIP-derived peptides in beryllium binding to the HLA-DPGlu69 berylliosis-associated molecules and presentation to beryllium-sensitized T cells. Immunology 128(1 Suppl):e462–e470. 10.1111/j.1365-2567.2008.03000.x.19191908
Andersen O. 1983. Effects of coal combustion products and metal compounds on sister chromatid exchange (SCE) in a macrophagelike cell line. Environ Health Perspect 47(7):239–253. 10.2307/3429513.6337826
Anderson SE, Meade BJ. 2014. Potential health effects associated with dermal exposure to occupational chemicals. Environ Health Insights 8(Suppl 1):51–62. 10.4137/ehi.S15258.25574139
Andrews JL, Kazemi H, Hardy HL. 1969. Patterns of lung dysfunction in chronic beryllium disease. Am Rev Respir Dis 100(6):791–800. 10.1164/arrd.1969.100.6.791.5353854
Apostoli P, Schaller KH. 2001. Urinary beryllium-a suitable tool for assessing occupational and environmental beryllium exposure? Int Arch Occup Environ Health 74(3):162–166. 10.1007/s004200000204.11355289
Arjomandi M, Seward J, Gotway MB, . 2010. Low prevalence of chronic beryllium disease among workers at a nuclear weapons research and development facility. J Occup Environ Med 52(6):647–652. 10.1097/JOM.0b013e3181e36439.20523233
Arlauskas A, Baker RSU, Bonin AM, . 1985. Mutagenicity of metal ions in bacteria. Environ Res 36(2):379–388. 10.1016/0013-9351(85)90032-5.3884331
Aronchick JM, Rossman MD, Miller WT. 1987. Chronic beryllium disease: diagnosis, radiographic findings, and correlation with pulmonary function tests. Radiology 163(3):677–682. 10.1148/radiology.163.3.3575713.3575713
Ashby J, Ishidate M, Stoner GD, . 1990. Studies on the genotoxicity of beryllium sulphate in vitro and in vivo. Mutat Res 240(3):217–225. 10.1016/0165-1218(90)90061-6.2179717
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634.
ATSDR. 2000. Health consultation: Brush Wellman Incorporated. Tucson, Pima County, Arizona. Agency for Toxic Substances and Disease Registry. CERCLIS No. AZD037612702. https://webcms.pima.gov/UserFiles/Servers/Server_6/File/Government/Environmental%20Quality/Air/Materion-Ceramics-Inc-Air-Quality-Information/May2000HealthConsultation.pdf. December 15, 2022.
ATSDR. 2005a. Health consultation: Brush Ceramic Products. Evaluation of beryllium exposure. Tucson, Pima County, Arizona. EPA Facility ID: AZD037612702. Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://webcms.pima.gov/UserFiles/Servers/Server_6/File/Government/Environmental%20Quality/Air/Materion-Ceramics-Inc-Air-Quality-Information/05-08-08_health_consultation_brush_final.pdf. December 15, 2022.
ATSDR. 2005b. Health consultation. Exposure investigation report. Beryllium sensitivity testing. Former American Beryllium site. Tallevast, Manatee County, Florida. EPA facility ID: FLD004100731 Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.floridahealth.gov/environmental-health/hazardous-waste-sites/_documents/a/americanberyllium120505.pdf. December 23, 2022.
ATSDR. 2006. Health consultation: Brush Wellman Elmore Plant (a/k/a Brush Wellman Incorporated). Elmore, Ottawa County, Ohio. EPA facility ID: OHD004212999 Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/hac/pha/2002brushwellmanrevised/brushwellmanhcrevised120106.pdf. December 15, 2022.
ATSDR. 2022. Beryllium. SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/SPL/resources/. June 14, 2023.
Attia SM, Harisa GI, Hassan MH, . 2013. Beryllium chloride-induced oxidative DNA damage and alteration in the expression patterns of DNA repair-related genes. Mutagenesis 28(5):555–559. 10.1093/mutage/get032.23793613
Awadallah RM, Sherif MK, Amrallah AH, . 1986. Determination of trace elements of some Egyptian crops by instrumental neutron activation, inductively coupled plasma-atomic emission spectrometric and flameless atomic absorption spectrophotometric analysis. J Radioanal Nucl Chem 98(2):235–246. 10.1007/BF02037086.
Badea M, Luzardo OP, González-Antuña A, . 2018. Body burden of toxic metals and rare earth elements in non-smokers, cigarette smokers and electronic cigarette users. Environ Res 166:269–275. 10.1016/j.envres.2018.06.007.29908458
Bailey RL, Thomas CA, Deubner DC, . 2010. Evaluation of a preventive program to reduce sensitization at a beryllium metal, oxide, and alloy production plant. J Occup Environ Med 52(5):505–512. 10.1097/JOM.0b013e3181d6c338.20431418
Ballance J, Stonehouse AJ, Sweeney R, . 1978. Beryllium and beryllium alloys. In: Grayson M, Eckroth D, eds. Kirk-Othmer encyclopedia of chemical technology. Vol. 3. 3^rd^ ed. New York: John Wiley & Sons, Inc., 803–823.
Balmes JR, Abraham JL, Dweik RA, . 2014. An official American Thoracic Society statement: diagnosis and management of beryllium sensitivity and chronic beryllium disease. Am J Respir Crit Care Med 190(10):e34–e59. 10.1164/rccm.201409-1722ST.25398119
Barna BP, Chiang T, Pillarisetti SG, . 1981. Immunologic studies of experimental beryllium lung disease in the guinea pig. Clin Immunol Immunopathol 20(3):402–411. 10.1016/0090-1229(81)90150-1.7341034
Barna BP, Deodhar SD, Chiang T, . 1984. Experimental beryllium-induced lung disease. I. Differences in immunologic responses to beryllium compounds in strains 2 and 13 guinea pigs. Int Arch Allergy Appl Immunol 73(1):42–48. 10.1159/000233436.6693180
Barna BP, Dweik RA, Farver CF, . 2002. Nitric oxide attenuates beryllium-induced IFNγ responses in chronic beryllium disease: evidence for mechanisms independent of IL-18. Clin Immunol 103(2):169–175. 10.1006/clim.2002.5211.12027422
Barnes KW. 1997. Trace metal determinations in fruit, juice, and juice products using an axially viewed plasma. Atom Spectrosc 18(3):84–101.
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486. 10.1016/0273-2300(88)90047-5.3222488
Basketter DA, Lea LJ, Cooper KJ, . 1999. Identification of metal allergens in the local lymph node assay. Am J Contact Dermat 10(4):207–212. 10.1016/S1046-199X(99)90070-2.10594296
Bayliss DL, Lainhart WS, Crally LJ, . 1971. Mortality patterns in a group of former beryllium workers. In: Transactions of the 33^rd^ annual meeting of the American Conference of Governmental Industrial Hygienists, May 24-28, 1971, Toronto, Ontario, Canada. Cincinnati, OH: American Conference of Governmental Industrial Hygienists, 94–107.
Bekris LM, Viernes H-MA, Farin FM, . 2006. Chronic beryllium disease and glutathione biosynthesis genes. J Occup Environ Med 48(6):599–606.16766924
Belinsky SA, Snow SS, Nikula KJ, . 2002. Aberrant CpG island methylation of the p16^INK4a^ and estrogen receptor genes in rat lung tumors induced by particulate carcinogens. Carcinogenesis 23(2):335–339. 10.1093/carcin/23.2.335.11872642
Belman S. 1969. Beryllium binding of epidermal constituents. J Occup Med 11(4):175–183. 10.1097/00043764-196904000-00003.5769709
Bencko V, Brezina M, Benes B, . 1979. Penetration of beryllium through the placenta and its distribution in the mouse. J Hyg Epidemiol Microbiol Immunol 23(4):361–367.
Benson JM, Holmes AM, Barr EB, . 2000. Particle clearance and histopathology in lungs of C3H/HeJ mice administered beryllium/copper alloy by intratracheal instillation. Inhal Toxicol 12(8):733–749. 10.1080/08958370050085165.10880154
Bettinelli M, Baroni U, Spezia S, . 2000. Determination of trace elements in honey using ETV-ICP-MS. Atom Spectrosc 21:195–204.
Bhat PN, Ghosh DK, Desai MVM. 2002. Beryllium: an easily scavenged metal ion in the environment. Sci Total Environ 297(1–3):119–125. 10.1016/S0048-9697(02)00086-4.12389784
Bibak A, Stümp S, Knudsen L, . 1999. Concentrations of 63 elements in cabbage and sprouts in Denmark. Commun Soil Sci Plant Anal 30(17–18):2409–2418. 10.1080/00103629909370382.
Bill JR, Mack DG, Falta MT, . 2005. Beryllium presentation to CD4+ T cells is dependent on a single amino acid residue of the MHC class II β-chain. J Immunol 175(10):7029–7037. 10.4049/jimmunol.175.10.7029.16272364
Bilski J, Kraft C, Jacob D, . 2013. Leaching of selected trace elements from plant growth media composed of coal fly ash (FA), and of FA amended with sphagnum peat moss and soil. Part 1: Leaching of trace elements from group 1: cesium (Cs) and lithium (Li), and from group 2: beryllium (Be), strontium (Sr), and barium (Ba). Res J Chem Environ Sci 1(1):7–18.30148176
Bircher AJ. 2011. Patch tests with beryllium salts. Contact Derm 64(6):363–364. 10.1111/j.1600-0536.2011.01906.x.
Björklund KL, Vahter M, Palm B, . 2012. Metals and trace element concentrations in breast milk of first time healthy mothers: a biological monitoring study. Environ Health 11(1):92. 10.1186/1476-069X-11-92.23241426
Bocca B, Mattei D, Pino A, . 2010. Italian network for human biomonitoring of metals: preliminary results from two Regions. Ann Ist Super Sanita 46(3):259–265. 10.4415/ANN_10_03_06.20847458
Bocio A, Nadal M, Domingo JL. 2005a. Human exposure to metals through the diet in Tarragona, Spain: temporal trend. Biol Trace Elem Res 104(3):193–201. 10.1385/BTER:104:3:193.15930589
Bocio A, Nadal M, Garcia F, . 2005b. Monitoring metals in the population living in the vicinity of a hazardous waste incinerator: concentrations in autopsy tissues. Biol Trace Elem Res 106(1):41–50. 10.1385/BTER:106:1:041.16037609
Boffetta P, Fordyce T, Mandel JS. 2014. A mortality study of workers exposed to insoluble forms of beryllium. Eur J Cancer Prev 23(6):587–593. 10.1097/CEJ.0000000000000013.24589746
Boffetta P, Fordyce TA, Mandel JS. 2016. A mortality study of beryllium workers. Cancer Med 5(12):3596–3605. 10.1002/cam4.918.27766788
Bohdalkova L, Novak M, Voldrichova P, . 2012. Atmospheric deposition of beryllium in Central Europe: comparison of soluble and insoluble fractions in rime and snow across a pollution gradient. Sci Total Environ 439:26–34. 10.1016/j.scitotenv.2012.08.089.23063635
Borges de Olival AR, Penha NL, Câmara JVF, . 2018. Analysis of chemical composition of different irreversible hydrocolloids. Dent J 6(3):37. 10.3390/dj6030037.
Bost TW, Riches DW, Schumacher B, . 1994. Alveolar macrophages from patients with beryllium disease and sarcoidosis express increased levels of mRNA for tumor necrosis factor-α and interleukin-6 but not interleukin-1β. Am J Respir Cell Mol Biol 10(5):506–513. 10.1165/ajrcmb.10.5.8179912.8179912
Brancaleone P, Weynand B, De Vuyst P, . 1998. Lung granulomatosis in a dental technician. Am J Ind Med 34(6):628–631. 10.1002/(sici)1097-0274(199812)34:6%3C628::aid-ajim12%3E3.0.co;2-9.9816422
Brooks AL, Griffith WC, Johnson NF, . 1989. The induction of chromosome damage in CHO cells by beryllium and radiation given alone and in combination. Radiat Res 120(3):494–507. 10.2307/3577799.2594970
Burger J, Campbell KR. 2004. Species differences in contaminants in fish on and adjacent to the Oak Ridge Reservation, Tennessee. Environ Res 96(2):145–155. 10.1016/j.envres.2003.12.003.15325875
Byrne CJ, DeLeon IR. 1986. Trace metal residues in biota and sediments from Lake Pontchartrain, Louisiana. Bull Environ Contam Toxicol 37(1):151–158. 10.1007/bf01607742.3719140
Caicedo M, Jacobs JJ, Reddy A, . 2008. Analysis of metal ion-induced DNA damage, apoptosis, and necrosis in human (Jurkat) T-cells demonstrates Ni^2+^ and V^3+^ are more toxic than other metals: Al^3+^, Be^2+^, Co^2+^, Cr^3+^, Cu^2+^, Fe^3+^, Mo^5+^, Nb^5+^, Zr^2+^. J Biomed Mater Res A 86(4):905–913. 10.1002/jbm.a.31789.18050301
Caldwell K, Hartel J, Jarrett J, . 2005. Inductively coupled plasma mass spectrometry to measure multiple toxic elements in urine in NHANES 1999-2000. Atom Spectrosc 26:1–7.
Capar SG, Yess NJ. 1996. US Food and Drug Administration survey of cadmium, lead and other elements in clams and oysters. Food Addit Contam 13(5):553–560. 10.1080/02652039609374440.8799717
Casto BC. 1981. Chemical-viral interactions: Enhancement of viral transformation by chemical carcinogens. In: Stich HF, San RHC, eds. Topics in environmental physiology and medicine: Short-term tests for chemical carcinogens. New York, NY: Springer-Verlag, 350–361.
Casto BC, Meyers J, Dipaolo JA. 1979. Enhancement of viral transformation for evaluation of the carcinogenic or mutagenic potential of inorganic metal salts. Cancer Res 39:193–198.570089
CDC. 1983. Beryllium disease among workers in a spacecraft-manufacturing plant-California. MMWR Morb Mortal Wkly Rep 32(32):419–420, 425.6410175
CDC. 2011. National Health and Nutrition Examination Survey: 2009-2010 data documentation, codebook, and frequencies: metals - urine (UHM_F). Centers for Disease Control and Prevention. https://wwwn.cdc.gov/Nchs/Nhanes/2009-2010/UHM_F.htm. December 15, 2022.
Cesbron A, Saussereau E, Mahieu L, . 2013. Metallic profile of whole blood and plasma in a series of 106 healthy volunteers. J Anal Toxicol 37(7):401–405. 10.1093/jat/bkt046.23794607
Chain JL, Martin AK, Mack DG, . 2013. Impaired function of CTLA-4 in the lungs of patients with chronic beryllium disease contributes to persistent inflammation. J Immunol 191(4):1648–1656. 10.4049/jimmunol.1300282.23851684
Chaudhary A, Sauer NN, Gupta G. 2004. Beryllium-specific immune response in primary cells from healthy individuals. Toxicology 201(1–3):9–19. 10.1016/j.tox.2004.03.025.15297015
Chaudhry HM, Drage LA, El-Azhary RA, . 2017. Delayed patch-test reading after 5 days: An update from the Mayo Clinic Contact Dermatitis Group. Dermatitis 28(4):253–260.28719473
Chen M, Ma LQ, Harris WG. 1999. Baseline concentrations of 15 trace elements in Florida surface soils. J Environ Qual 28(4):1173–1181. 10.2134/jeq1999.00472425002800040018x.
Chen QY, DesMarais T, Costa M. 2019. Metals and mechanisms of carcinogenesis. Annu Rev Pharmacol Toxicol 59:537–554. 10.1146/annurev-pharmtox-010818-021031.30625284
Chesner C. 1950. Chronic pulmonary granulomatosis in residents of a community near a beryllium plant; 3 autopsied cases. Ann Intern Med 32(6):1028–1048. 10.7326/0003-4819-32-6-1028.15419598
Clarke SM. 1991. A novel enzyme-linked immunosorbent assay (ELISA) for the detection of beryllium antibodies. J Immunol Methods 137(1):65–72. 10.1016/0022-1759(91)90394-u.2010619
Clary JJ, Hopper CR, Stokinger HE. 1972. Altered adrenal function as an inducer of latent chronic beryllium disease. Toxicol Appl Pharmacol 23(3):365–375. 10.1016/0041-008x(72)90038-5.5085451
Clary JJ, Bland LS, Stokinger HE. 1975. The effect of reproduction and lactation on the onset of latent chronic beryllium disease. Toxicol Appl Pharmacol 33(2):214–221. 10.1016/0041-008x(75)90088-5.1179428
Clayton GM, Wang Y, Crawford F, . 2014. Structural basis of chronic beryllium disease: linking allergic hypersensitivity and autoimmunity. Cell 158(1):132–142. 10.1016/j.cell.2014.04.048.24995984
Cleverly DH, Morrison RM, Riddle BL, . 1989. Regulatory analysis of pollutant emissions, including polychlorinated dibenzo-p-dioxins (CDDs) and dibenzofurans (CDFs), from the stacks of municipal waste combustors. Chemosphere 18(1):1143–1153. 10.1016/0045-6535(89)90248-8.
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131. 10.1177/074823378500100408.3843496
Cloeren M, Dement J, Gaitens J, . 2022. Beryllium disease among construction trade workers at Department of Energy nuclear sites: A follow-up. Am J Ind Med 65(9):708–720. 10.1002/ajim.23411.35833586
Coates SSA, Lehnert BE, Sharma S, . 2007. Beryllium induces premature senescence in human fibroblasts. J Pharmacol Exp Ther 322(1):70–79.17395767
Conradi C, Burri PH, Kapanci Y, . 1971. Lung changes after beryllium inhalation: ultrastructural and morphometric study. Arch Environ Health 23(5):348–358. 10.1080/00039896.1971.10666020.5002497
Cotes JE, Gilson JC, McKerrow CB, . 1983. A long-term follow-up of workers exposed to beryllium. Br J Ind Med 40(1):13–21. 10.1136/oem.40.1.13.6824594
Cotton FA, Wilkinson G, eds. 1980. Beryllium and the group II elements: Mg, Ca, Sr, Ba, Ra. In: Advanced inorganic chemistry: A comprehensive text. New York: John Wiley & Sons, Inc., 271–280.
Cowgill UM. 1981. The chemical composition of bananas market based values, 1968-1980. Biol Trace Elem Res 3(1):33–54. 10.1007/BF02789122.24271560
Crane JL. 2019. Distribution, toxic potential, and influence of land use on conventional and emerging contaminants in urban stormwater pond sediments. Arch Environ Contam Toxicol 76(2):265–294. 10.1007/s00244-019-00598-w.30637461
Crinnion WJ, Tran JQ. 2010. Case report: Heavy metal burden presenting as Bartter Syndrome. Altern Med Rev 15(4):303–310.21194246
Crooks J, Mroz MM, VanDyke M, . 2022. HLA-DPB1 E69 genotype and exposure in beryllium sensitisation and disease. Occup Environ Med 79(2):120–126. 10.1136/oemed-2021-107736.34535537
Cullen MR, Kominsky JR, Rossman MD, . 1987. Chronic beryllium disease in a precious metal refinery. Clinical epidemiologic and immunologic evidence for continuing risk from exposure to low level beryllium fume. Am Rev Respir Dis 135(1):201–208. 10.1164/arrd.1987.135.1.201.3492158
Cullinan P, Muñoz X, Suojalehto H, . 2017. Occupational lung diseases: from old and novel exposures to effective preventive strategies. Lancet Respir Med 5(5):445–455. 10.1016/S2213-2600(16)30424-6.28089118
Cummings KJ, Stefaniak AB, Virji MA, . 2009. A reconsideration of acute beryllium disease. Environ Health Perspect 117(8):1250–1256. 10.1289/ehp.0800455.19672405
Curtis GH. 1951. Cutaneous hypersensitivity due to beryllium; a study of thirteen cases. AMA Arch Derm Syphilol 64(4):470–482. 10.1001/archderm.1951.01570100087014.14867858
Curtis GH. 1959. The diagnosis of beryllium disease, with special reference to the patch test. AMA Arch Ind Health 19(2):150–153.13616733
Dai S, Murphy GA, Crawford F, . 2010. Crystal structure of HLA-DP2 and implications for chronic beryllium disease. Proc Natl Acad Sci USA 107(16):7425–7430. 10.1073/pnas.1001772107.20356827
Dai S, Falta MT, Bowerman NA, . 2013. T cell recognition of beryllium. Curr Opin Immunol 25(6):775–780. 10.1016/j.coi.2013.07.012.23978481
Damian P. 2011. Development of a health risk-based surface contamination cleanup standard for occupational exposure to beryllium. Toxicol Mech Methods 21(2):97–102. 10.3109/15376516.2010.499257.20649413
Dattoli JA, Lieben J, Bisbing J. 1964. Chronic beryllium disease. A follow-up study. J Occup Med 6:189–194.14136859
Day GA, Hoover MD, Stefaniak AB, . 2005. Bioavailability of beryllium oxide particles: An in vitro study in the murine J774A.1 macrophage cell line model. Exp Lung Res 31(3):341–360. 10.1080/01902140590918731.15962713
Day GA, Stefaniak AB, Weston A, . 2006a. Beryllium exposure: dermal and immunological considerations. Int Arch Occup Environ Health 79(2):161–164. 10.1007/s00420-005-0024-0.16231190
Day GA, Dufresne A, Stefaniak AB, . 2006b. Exposure pathway assessment at a copper-beryllium alloy facility. Ann Work Expo Health 51(1):67–80. 10.1093/annhyg/mel041.
DeNardi JM, Van Ordstrand HS, Curtis GH, . 1953. Berylliosis: summary and survey of all clinical types observed in a twelve-year period. AMA Arch Ind Hyg Occup Med 8:1–24.13057385
Deubner D, Kent M. 2007. Keeping beryllium workers safe: an enhanced preventive model. J Occup Environ Hyg 4(3):D23–D30. 10.1080/15459620601160202.17237019
Deubner DC, Lockey JL, Kotin P, . 2001a. Re: Lung cancer case-control study of beryllium workers. Sanderson WT, Ward EM, Steenland K, Petersen MR. Am. J. Ind. Med. 2001. 39:133–144. Am J Ind Med 40(3):284–288. 10.1002/ajim.1101.11170156
Deubner D, Kelsh M, Shum M, . 2001b. Beryllium sensitization, chronic beryllium disease, and exposures at a beryllium mining and extraction facility. Appl Occup Environ Hyg 16(5):579–592. 10.1080/104732201750169697.11370937
Deubner DC, Lowney YW, Paustenbach DJ, . 2001c. Contribution of incidental exposure pathways to total beryllium exposures. Appl Occup Environ Hyg 16(5):568–578. 10.1080/10473220120136.11370936
Devoy J, Melczer M, Antoine G, . 2013. Validation of a standardised method for determining beryllium in human urine at nanogram level. Anal Bioanal Chem 405(25):8327–8336. 10.1007/s00216-013-7220-7.23892880
Ding J, Lin L, Hang W, . 2009. Beryllium uptake and related biological effects studied in THP-1 differentiated macrophages. Metallomics 1(6):471–478. 10.1039/b913265a.21305155
DiPaolo JA, Casto BC. 1979. Quantitative studies of in vitro morphological transformation of Syrian hamster cells by inorganic metal salts. Cancer Res 39:1008–1013.427740
Dobis DR, Sawyer RT, Gillespie MM, . 2008. Modulation of lymphocyte proliferation by antioxidants in chronic beryllium disease. Am J Respir Crit Care Med 177(9):1002–1011. 10.1164/rccm.200707-1021OC.18218990
DOE. 1996. A comprehensive assessment of toxic emissions from coal-fired power plants-topical report. Morgantown, WV: U.S. Department of Energy. DOE/MC/30097-5321. https://digital.library.unt.edu/ark:/67531/metadc691780/. December 15, 2022.
DOE. 2009. Medical surveillance for former workers. Final technical report for the period October 1, 1996-September 30, 2006. Washington, DC: Department of Energy. DOE/SF21258-1. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/DE2010953494.xhtml. December 23, 2022.
DOE. 2018a. Table 3: Protective action criteria (PAC) rev. 29a based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. June 2018. U.S. Department of Energy. https://edms3.energy.gov/pac/docs/Revision_29A_Table3.pdf. July 6, 2022.
DOE. 2018b. Protective action criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29A, June 2018. U.S. Department of Energy. https://edms3.energy.gov/pac/. July 6, 2022.
DOI. 2018. Final list of critical minerals 2018. U.S. Department of the Interior. Fed Regist 83(97):23295–23296.
Donovan EP, Kolanz ME, Galbraith DA, . 2007. Performance of the beryllium blood lymphocyte proliferation test based on a long-term occupational surveillance program. Int Arch Occup Environ Health 81(2):165–178. 10.1007/s00420-007-0202-3.17483959
Dotti C, D’Apice MR, Rogliani P, . 2004. Analysis of TNF-α promoter polymorphisms in the susceptibility to beryllium hypersensitivity. Sarcoidosis Vasc Diffuse Lung Dis 21(1):29–34. 10.1007/s11083-004-9308-3 15127972
Drobyshev E, Kybarskaya L, Dagaev S, . 2019. New insight in beryllium toxicity excluding exposure to beryllium-containing dust: accumulation patterns, target organs, and elimination. Arch Toxicol 93(4):859–869. 10.1007/s00204-019-02432-7.30891623
Drolet-Vives K, Zayed J, Sauvé S. 2009. Assessment of hair and bone accumulation of beryllium by mice exposed to contaminated dusts. J Appl Toxicol 29(7):638–642. 10.1002/jat.1448.19484702
Duckett S, Kradin R, Galle P. 2000. The pathogenesis of beryllium-induced pulmonary granulomatosis. A scanning secondary ion analytical microscopy study. C R Acad Sci III 323(9):769–774. 10.1016/S0764-4469(00)01218-X.11072622
Duggal M, Deubner DC, Curtis AM, . 2010. Long-term follow-up of beryllium sensitized workers from a single employer. BMC Public Health 10:5. 10.1186/1471-2458-10-5.20047684
Dunkel VC, Pienta RJ, Sivak A, . 1981. Comparative neoplastic transformation responses of Balb/3T3 cells, Syrian hamster embryo cells, and Rauscher murine leukemia virus-infected Fischer 344 rat embryo cells to chemical carcinogens. J Natl Cancer Inst 67:1303–1307. 10.1093/jnci/67.6.1303.6947113
EIA. 2017. Today in energy. U.S. Energy Information Administration. https://www.eia.gov/todayinenergy/detail.php?id=30812#tab1. August 26, 2020.
EIA. 2018. Biomass explained: waste-to-energy (municipal solid waste). U.S. Energy Information Administration. https://www.eia.gov/energyexplained/biomass/waste-to-energy.php. October 7, 2019.
Eidson AF, Taya A, Finch GL, . 1991. Dosimetry of beryllium in cultured canine pulmonary alveolar macrophages. J Toxicol Environ Health 34(4):433–448. 10.1080/15287399109531581.1960761
Eisenbud M, Lisson J. 1983. Epidemiological aspects of beryllium-induced nonmalignant lung disease: a 30-year update. J Occup Med 25(3):196–202.6842310
Eisenbud M, Berghout CF, Steadman LT. 1948. Environmental studies in plants and laboratories using beryllium; the acute disease. J Ind Hyg Toxicol 30(5):281–285.18881082
Eisenbud M, Wanta RC, Dustan C, . 1949. Non-occupational berylliosis. J Ind Hyg Toxicol 31(5):282–294.18141686
El-Beshbishy HA, Hassan MH, Aly HA, . 2012. Crocin “saffron” protects against beryllium chloride toxicity in rats through diminution of oxidative stress and enhancing gene expression of antioxidant enzymes. Ecotoxicol Environ Saf 83:47–54. 10.1016/j.ecoenv.2012.06.003.22766413
Elshahawy WM, Watanabe I, Kramer P. 2009. In vitro cytotoxicity evaluation of elemental ions released from different prosthodontic materials. Dent Mater 25(12):1551–1555. 10.1016/j.dental.2009.07.008.19682734
Endo G, Kuroda K, Okamoto A, . 1991. Genotoxicity of Be, Ga, Sb and As compounds. Mutat Res 252:84–85.
EPA. 1978. Reviews of the environmental effects of pollutants: VI. Beryllium. Cincinnati, OH: U.S. Environmental Protection Agency. EPA600178028. ORNL/EIS-87. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9101PYXG.txt. April 4, 2023.
EPA. 1979. Water-related environmental fate of 129 priority pollutants. Washington, DC: U.S. Environmental Protection Agency. PB80204373. EPA440479029a. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB80204373.xhtml. April 4, 2023.
EPA. 1980. Ambient water quality criteria for beryllium. Washington, DC: U.S. Environmental Protection Agency. PB81117350. EPA440580024. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB81117350.xhtml. April 4, 2023.
EPA. 1982. Beryllium. National emission standards for hazardous air pollutants. Washington, DC: U.S. Environmental Protection Agency. II–3, III–12, III–13. EPA340182006. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9100YYD4.txt. December 23, 2022.
EPA. 1983. Treatability manual. Vol. 1. Treatability data. U.S. Environmental Protection Agency. EPA600880042A. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=20008BPO.txt. December 16, 2022.
EPA. 1987. Health assessment document for beryllium. Washington DC: U.S. Environmental Protection Agency. PB88179205. EPA600884026F. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB88179205.xhtml. April 4, 2023.
EPA. 1988a. Nonferrous metals manufacturing point source category. Code of Federal Regulations. U.S. Environmental Protection Agency. 40 CFR Part 421.152 to 421.156. https://www.ecfr.gov/current/title-40/chapter-I/subchapter-N/part-421. January 19, 2023.
EPA. 1988b. Method 6010D: Inductively coupled plasma atomic emissions spectroscopy. In: Test methods for evaluating solid waste. Washington, DC: U.S. Environmental Protection Agency. SW846. https://www.epa.gov/sites/default/files/2015-12/documents/6010d.pdf. April 4, 2023.
EPA. 1988c. Recommendations for and documentation of biological values for use in risk assessment. Cincinnati, OH: U.S. Environmental Protection Agency. PB88179874. EPA600687008. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB88179874.xhtml. December 15, 2022.
EPA. 1994. Method 200.8. Determination of trace elements in waters and wastes by inductively coupled plasma - mass spectrometry. Cincinnati, OH: U.S. Environmental Protection Agency. https://www.epa.gov/sites/default/files/2015-06/documents/epa-200.8.pdf. December 22, 2022.
EPA. 1996. Proposed guidelines for carcinogen risk assessment. Washington, DC: U.S. Environmental Protection Agency. EPA600P92003C. https://cfpub.epa.gov/ncea/raf/pdfs/propcra_1996.pdf. December 10, 2022.
EPA. 1998. Toxicological review of beryllium and compounds. Washington, DC: U.S. Environmental Protection Agency. https://iris.epa.gov/static/pdfs/0012tr.pdf. December 22, 2022.
EPA. 2002. Occurrence summary and use support document for the six-year review of national primary drinking water regulation. U.S. Environmental Protection Agency. EPA815D02006. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=20001X16.txt. April 4, 2023.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. EPA260B05001. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P100EI4V.txt. April 4, 2023.
EPA. 2009. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency. EPA816F09004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. August 2, 2019.
EPA. 2014. Method 6020B. Inductively coupled plasma - mass spectroscopy. U.S. Environmental Protection Agency. https://www.epa.gov/sites/default/files/2015-12/documents/6020b.pdf. December 22, 2022.
EPA. 2016. National contaminant occurrence database (NCOD): Six-year review of national drinking water regulations. Six-year review 3 occurrence data. U.S. Environmental Protection Agency. https://www.epa.gov/sdwa/national-contaminant-occurrence-database-ncod. April 3, 2020.
EPA. 2017. NEI data: Beryllium. U.S. Environmental Protection Agency. https://www.epa.gov/air-emissions-inventories/2017-national-emissions-inventory-nei-data. October 24, 2022.
EPA. 2018a. 2018 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA822F18001. https://www.epa.gov/system/files/documents/2022-01/dwtable2018.pdf. June 15, 2022.
EPA. 2018b. Compiled AEGL values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-08/documents/compiled_aegls_update_27jul2018.pdf. April 12, 2020.
EPA. 2019. Defining hazardous waste: Listed, characteristic and mixed radiological wastes. U.S. Environmental Protection Agency. https://www.epa.gov/hw/defining-hazardous-waste-listed-characteristic-and-mixed-radiological-wastes#PandU.
EPA. 2020. Sampling methods for HAPS (core HAPS and VOCs). AQS reference table. U.S. Environmental Protection Agency. https://aqs.epa.gov/aqsweb/documents/codetables/methods_haps.html. December 15, 2022.
EPA. 2022a. AQS data. U.S. Environmental Protection Agency. https://www.epa.gov/aqs. December 5, 2022.
EPA. 2022b. 2020 CDR data. U.S. Environmental Protection Agency. https://www.epa.gov/chemical-data-reporting/access-cdr-data#2020. October 26, 2022.
EPA. 2022c. Superfund site: Bonita Peak Mining District, Unincorporated, CO: Cleanup activities. U.S. Environmental Protection Agency. https://cumulis.epa.gov/supercpad/siteprofiles/index.cfm?fuseaction=second.cleanup&id=0802497. December 27, 2022.
EPA. 2022d. Superfund site: Midnite Mine, Wellpinit, WA: Cleanup activities. U.S. Environmental Protection Agency. https://cumulis.epa.gov/supercpad/siteprofiles/index.cfm?fuseaction=second.cleanup&id=1001070. December 27, 2022.
EPA. 2022e. Superfund site: Gay Mine site, Fort Hall, ID: Cleanup activities. U.S. Environmental Protection Agency. https://cumulis.epa.gov/supercpad/siteprofiles/index.cfm?fuseaction=second.cleanup&id=1002730. December 27, 2022.
Epstein WL. 1983. Commentary and update: beryllium granulomas of the skin: a small window to understanding. Cleve Clin Q 50(2):73–75. 10.3949/ccjm.50.2.73.6640943
Esteves da Silva JCG, Machado AASC, Ramos MA, . 1996. Quantitative study of Be(II) complexation by soil fulvic acids by molecular fluorescence spectroscopy. Environ Sci Technol 30(11):3155–3160. 10.1021/es9507022.
Fahmy MA, Hassan NHA, Farghaly AA, . 2008. Studies on the genotoxic effect of beryllium chloride and the possible protective role of selenium/vitamins A, C and E. Mutat Res 652(2):103–111. 10.1016/j.mrgentox.2007.12.009.18373946
Falta MT, Bowerman NA, Dai S, . 2010. Linking genetic susceptibility and T cell activation in beryllium-induced disease. Proc Am Thorac Soc 7(2):126–129. 10.1513/pats.201002-022RM.20427584
Falta MT, Pinilla C, Mack DG, . 2013. Identification of beryllium-dependent peptides recognized by CD4+ T cells in chronic beryllium disease. J Exp Med 210(7):1403–1418. 10.1084/jem.20122426.23797096
Falta MT, Crawford JC, Tinega AN, . 2021. Beryllium-specific CD4+ T cells induced by chemokine neoantigens perpetuate inflammation. J Clin Invest 131(9):e144864. 10.1172/jci144864.33630763
FDA. 2017. Subpart B - Requirements for specific standardized beverages. Bottled water. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 165.110. https://www.gpo.gov/fdsys/pkg/CFR-2017-title21-vol2/pdf/CFR-2017-title21-vol2-sec165-110.pdf. September 7, 2017.
FDA. 2022a. FDA total diet study (TDS): results. U.S. Food and Drug Administration. https://www.fda.gov/food/fda-total-diet-study-tds/fda-total-diet-study-tds-results. December 14, 2022.
FDA. 2022b. Substances added to food. U.S. Food and Drug Administration. https://www.cfsanappsexternal.fda.gov/scripts/fdcc/?set=FoodSubstances. January 24, 2022.
Figgs LW, Holsinger H, Freitas SJ, . 2011. Increased suicide risk among workers following toxic metal exposure at the Paducah gaseous diffusion plant from 1952 to 2003: a cohort study. Int J Occup Environ Med 2(4):199–214.23022839
Finch GL, Nikula KJ, Hoover MD. 1998. Dose-response relationships between inhaled beryllium metal and lung toxicity in C3H mice. Toxicol Sci 42(1):36–48. 10.1093/toxsci/42.1.36.9538046
Finch GL, Haley PJ, Hoover MD, . 1988. Toxicokinetics of beryllium following inhalation of beryllium oxide by beagle dogs III. In: Inhalation Toxicology Research Institute annual report 1987-1988. International Atomic Energy Agency, 118–122. http://inis.iaea.org/search/search.aspx?orig_q=RN:36003606. December 23, 2022.
Finch GL, Mewhinney JA, Hoover MD, . 1990. Clearance, translocation, and excretion of beryllium following acute inhalation of beryllium oxide by beagle dogs. Fundam Appl Toxicol 15(2):231–241. 10.1016/0272-0590(90)90050-t.2227151
Finch GL, Hoover MD, Hahn FF, . 1996. Animal models of beryllium-induced lung disease. Environ Health Perspect 104(5):973–979. 10.1289/ehp.96104s5973.8933044
Fireman E, Kramer MR, Kaufman N, . 2001. Beryllium disease: first case reported in Israel. Isr Med Assoc J 3(3):224–225.11303384
Fireman E, Kramer MR, Priel I, . 2006. Chronic beryllium disease among dental technicians in Israel. Sarcoidosis Vasc Diffuse Lung Dis 23(3):215–221.18038921
Fishbein L. 1981. Sources, transport and alterations of metal compounds: an overview. I. Arsenic, beryllium, cadmium, chromium, and nickel. Environ Health Perspect 40:43–64. 10.1289/ehp.814043.7023934
Flora SJS, Mathur S, Mathur R. 1995. Effects of meso-2,3-dimercaptosuccinic acid or 2,3-dimercaptopropane 1-sulfonate on beryllium-induced biochemical alterations and metal concentration in male rats. Toxicology 95(1–3):1–3. 10.1016/0300-483X(94)02903-8.7825176
Fontenot AP. 2018. Immunologic effects of beryllium exposure. Ann Am Thorac Soc 15(Suppl 2):S81–S85. 10.1513/AnnalsATS.201707-573MG.29676647
Fontenot AP, Kotzin BL. 2003. Chronic beryllium disease: immune-mediated destruction with implications for organ-specific autoimmunity. Tissue Antigens 62(6):449–458. 10.1046/j.1399-0039.2003.00160.x.14617028
Fontenot AP, Falta MT, Freed BM, . 1999. Identification of pathogenic T cells in patients with beryllium-induced lung disease. J Immunol 163(2):1019. 10.4049/jimmunol.163.2.1019.10395700
Fontenot AP, Torres M, Marshall WH, . 2000. Beryllium presentation to CD4+ T cells underlies disease-susceptibility HLA-DP alleles in chronic beryllium disease. Proc Natl Acad Sci USA 97(23):12717–12722. 10.1073/pnas.220430797.11050177
Fontenot AP, Maier LA, Canavera SJ, . 2002. Beryllium skin patch testing to analyze T cell stimulation and granulomatous inflammation in the lung. J Immunol 168(7):3627–3634. 10.4049/jimmunol.168.7.3627.11907128
Fontenot AP, Palmer BE, Sullivan AK, . 2005. Frequency of beryllium-specific, central memory CD4+ T cells in blood determines proliferative response. J Clin Invest 115(10):2886–2893.16151531
Fontenot AP, Keizer TS, McCleskey M, . 2006. Recombinant HLA-DP2 binds beryllium and tolerizes beryllium-specific pathogenic CD4+ T cells. J Immunol 177(6):3874–3883. 10.4049/jimmunol.177.6.3874.16951350
Fontenot AP, Falta MT, Kappler JW, . 2016. Beryllium-induced hypersensitivity: Genetic susceptibility and neoantigen generation. J Immunol 196(1):22–27. 10.4049/jimmunol.1502011.26685315
Foreman JK, Gough TA, Walker EA. 1970. The determination of traces of beryllium in human and rat urine samples by gas chromatography. Analyst 95(134):797–804. 10.1039/an9709500797.4989808
Frame GM, Ford RE, Scribner WG, . 1974. Trace determination of beryllium oxide in biological samples by electron-capture gas chromatography. Anal Chem 46(4):534–539. 10.1021/ac60340a035.4819082
Freiman DG, Hardy HL. 1970. Beryllium disease. The relation of pulmonary pathology to clinical course and prognosis based on a study of 130 cases from the U.S. beryllium case registry. Hum Pathol 1(1):25–44. 10.1016/s0046-8177(70)80003-x.5521721
Fresquez MR, Pappas RS, Watson CH. 2013. Establishment of toxic metal reference range in tobacco from US cigarettes. J Anal Toxicol 37(5):298–304. 10.1093/jat/bkt021.23548667
Freundt KJ, Ibrahim HA. 1990. Growth of rats during a subchronic intake of the heavy metals Pb, Cd, Zn, Mn, Cu, Hg, and Be. Pol J Occup Med 3(2):227–232.2130877
Frink CR. 1996. A perspective on metals in soils. J Soil Contam 5(4):329–359. 10.1080/15320389609383534.
Fritzenschaf H, Kohlpoth M, Rusche B, . 1993. Testing of known carcinogens and noncarcinogens in the Syrian hamster embryo (SHE) micronucleus test in vitro; correlations with in vivo micronucleus formation and cell transformation. Mutat Res 319(1):47–53. 10.1016/0165-1218(93)90029-d.7690458
Frye BC, Gaede KI, Saltini C, . 2021. Analysis of single nucleotide polymorphisms in chronic beryllium disease. Respir Res 22(1):107. 10.1186/s12931-021-01691-2.33863318
Furchner JE, Richmond CR, London JE. 1973. Comparative metabolism of radionuclides in mammals. VIII. Retention of beryllium in the mouse, rat, monkey and dog. Health Phys 24(3):293–300. 10.1097/00004032-197303000-00004.4632433
Gaede KI, Amicosante M, Schürmann M, . 2005. Function associated transforming growth factor-β gene polymorphism in chronic beryllium disease. J Mol Med (Berl) 83(5):397–405. 10.1007/s00109-004-0626-0.15750822
Garrison DM, Pendela VS, Memon J. 2020. Cor pulmonale. In: StatPearls. Treasure Island, FL: StatPearls Publishing. https://www.ncbi.nlm.nih.gov/books/NBK430739/. May 15, 2020.
Gladney ES, Owens JW. 1976. Beryllium emissions from a coal-fired power plant. J Environ Sci Health A Environ Sci Eng 11(4–5):297–311. 10.1080/10934527609385772.
Godderis L, Vanderheyden W, Van Geel J, . 2005. Exposure and inhalation risk assessment in an aluminium cast-house. J Environ Monit 7(12):1359–1363. 10.1039/b508247a.16307097
Goel KA, Agrawal VP, Garg V. 1980. Pulmonary toxicity of beryllium in albino rat. Bull Environ Contam Toxicol 24(1):59–64. 10.1007/bf01608076.6244019
Gorjala P, Gary RK. 2010. Beryllium sulfate induces p21^CDKN1A^ expression and a senescence-like cell cycle arrest in susceptible cancer cell types. Biometals 23(6):1061–1073. 10.1007/s10534-010-9352-y.20549306
Gorjala P, Cairncross JG, Gary RK. 2016. P53-dependent up-regulation of CDKN1A and downregulation of CCNE2 in response to beryllium. Cell Prolif 49(6):698–709. 10.1111/cpr.12291.27611480
Gorlin RJ. 1951. Beryllium rickets: its effect on the teeth, the mandibular joint, and the bones of the skull of the albino rat. Oral Surg Oral Med Oral Pathol 4(2):177–197. 10.1016/0030-4220(51)90433-1.14807486
Goullé JP, Mahieu L, Castermant J, . 2005. Metal and metalloid multi-elementary ICP-MS validation in whole blood, plasma, urine and hair. Reference values. Forensic Sci Int 153(1):39–44. 10.1016/j.forsciint.2005.04.020.15979835
Granero S, Domingo JL. 2002. Levels of metals in soils of Alcala de Henares, Spain: human health risks. Environ Int 28(3):159–164. 10.1016/s0160-4120(02)00024-7.12222612
Griffitts WR, Skilleter DN. 1990. Beryllium. In: Merian E, ed. Metals and their compounds in the environment. New York: VCH, 775–787.
Guan H, Piao FY, Li XW, . 2010. Maternal and fetal exposure to four carcinogenic environmental metals. Biomed Environ Sci 23(6):458–465. 10.1016/S0895-3988(11)60008-1.21315244
Guyatt BL, Kay HD, Branion HD. 1933. Beryllium “rickets”. J Nutr 6(4):313–324. 10.1093/jn/6.4.313.
Haberman AL, Pratt M, Storrs FJ. 1993. Contact dermatitis from beryllium in dental alloys. Contact Derm 28(3):157–162. 10.1111/j.1600-0536.1993.tb03378.x.
Haley PJ, Finch GL, Hoover MD, . 1990. The acute toxicity of inhaled beryllium metal in rats. Fundam Appl Toxicol 15(4):767–778. 10.1016/0272-0590(90)90193-N.2086318
Haley PJ, Finch GL, Mewhinney JA, . 1989. A canine model of beryllium-induced granulomatous lung disease. Lab Invest 61(2):219–227.2755079
Hall RH, Scott JK, Laskin S, . 1950. Acute toxicity of inhaled beryllium. Arch Ind Hyg Occup Med 12:25–48.
Hall TC, Wood CH, Stoeckle JD, . 1959. Case data from the beryllium registry. AMA Arch Ind Health 19(2):100–103.13616726
Hamada H, Sawyer RT, Kittle LA, . 2000. Beryllium-stimulation does not activate transcription factors in a mouse hybrid macrophage cell line. Toxicology 143(3):249–261. 10.1016/S0300-483X(99)00183-3.10755711
Hamilton EI, Minski MJ. 1973. Abundance of the chemical elements in man’s diet and possible relations with environmental factors. Sci Total Environ 1(4):375–394. 10.1016/0048-9697(73)90025-9.
Harber P, Su J. 2014. Beryllium biobank 3: Considerations for improving chronic beryllium disease screening. J Occup Environ Med 56(8):861–866. 10.1097/jom.0000000000000200.25099414
Hardy HL, Tabershaw IR. 1946. Delayed chemical pneumonitis occurring in workers exposed to beryllium compounds. J Ind Hyg Toxicol 28:197–211.21000285
Hart BA, Bickford PC, Whatlen MC, . 1980. Distribution and retention of beryllium in guinea pigs after administration of a beryllium chloride aerosol. DOE Symp Ser 53:87–102.
Hart BA, Harmsen AG, Low RB, . 1984. Biochemical, cytological, and histological alterations in rat lung following acute beryllium aerosol exposure. Toxicol Appl Pharmacol 75(3):454–465. 10.1016/0041-008x(84)90182-0.6089376
Hasselriis F, Licata A. 1996. Analysis of heavy metal emission data from municipal waste combustion. J Hazard Mater 47(1):77–102. 10.1016/0304-3894(95)00107-7.
Hawley N, Robbins JA, Eadie BJ. 1986. The partitioning of ^7^beryllium in fresh water. Geochim Cosmochim Acta 50(6):1127–1131. 10.1016/0016-7037(86)90393-5.
Hayes KF, Traina SJ. 1998. Metal ion speciation and its significance in ecosystem health. In: Soil chemistry and ecosystem health. Special publication 52. Madison, WI: Soil Science Society of America, 45–84.
Henneberger PK, Cumro D, Deubner DD, . 2001. Beryllium sensitization and disease among long-term and short-term workers in a beryllium ceramics plant. Int Arch Occup Environ Health 74(3):167–176. 10.1007/s004200100237.11355290
Hibbert K, Ogunseitan OA. 2014. Risks of toxic ash from artisanal mining of discarded cellphones. J Hazard Mater 278:1–7. 10.1016/j.jhazmat.2014.05.089.24937657
Hiller J, Naglav-Hansen D, Drexler H, . 2023. Human urinary and blood toxicokinetics of beryllium after accidental exposure. J Trace Elem Med Biol 76:127125. 10.1016/j.jtemb.2023.127125.36623420
Hinwood AL, Stasinska A, Callan AC, . 2015. Maternal exposure to alkali, alkali earth, transition and other metals: Concentrations and predictors of exposure. Environ Pollut 204:256–263. 10.1016/j.envpol.2015.04.024.25984984
Hofele J, Sietz M, Grote M, . 1994. Investigations to the beryllium content of potatoes and soils. Agrobiol Res 47(3–4):273–279.
Hopkins WA, Mendonca MT, Rowe CL, . 1998. Elevated trace element concentrations in southern toads, Bufo terrestris, exposed to coal combustion waste. Arch Environ Contam Toxicol 35(2):325–329. 10.1007/s002449900383.9680525
Horng CJ, Horng PH, Lin SC, . 2002. Determination of urinary beryllium, arsenic, and selenium in steel production workers. Biol Trace Elem Res 88(3):235–246. 10.1385/BTER:88:3:235.12350133
Hsie AW, Johnson NP, Couch DB, . 1978. Quantitative mammalian cell mutagenesis and a preliminary study of the mutagenic potential of metallic compounds. Conference: Intra-science symposium on trace elements in health and disease: New roles of metals in biochemistry, the environment and clinical/nutrition, studies, Santa Monica, CA, USA, 29 Nov 1978. Oak Ridge National Laboratory. CONF-7811110-1. https://www.osti.gov/biblio/6201762. December 15, 2022.
Huang H, Meyer KC, Kubai L, . 1992. An immune model of beryllium-induced pulmonary granulomata in mice. Histopathology, immune reactivity, and flow-cytometric analysis of bronchoalveolar lavage-derived cells. Lab Invest 67(1):138–146.1625444
Hulo S, Radauceanu A, Chérot-Kornobis N, . 2016. Beryllium in exhaled breath condensate as a biomarker of occupational exposure in a primary aluminum production plant. Int J Hyg Environ Health 219(1):40–47. 10.1016/j.ijheh.2015.08.003.26306830
IARC. 1980. Beryllium and beryllium compounds. In: IARC monographs on the evaluation of carcinogenic risk of chemicals to humans. Volume 23: Some metals and metallic compounds. Lyon, France: World Health Organization, 143–172.
IARC. 2012. Beryllium and beryllium compounds. In: IARC monographs on the evaluation of carcinogenic risks to humans. Volume 100C: Arsenic, metals, fibres, and dusts. Lyon, France: International Agency for Research on Cancer, World Health Organization, 95–120. https://monographs.iarc.fr/wp-content/uploads/2018/06/mono100C-7.pdf. December 10, 2022.
Infante PF, Wagoner JK, Sprince NL. 1980. Mortality patterns from lung cancer and nonneoplastic respiratory disease among white males in the beryllium case registry. Environ Res 21(1):35–43. 10.1016/0013-9351(80)90005-5.7389704
IRIS. 2002. Beryllium and compounds; CASRN 7440-41-7. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. https://iris.epa.gov/static/pdfs/0012_summary.pdf. December 10, 2022.
IRSST. 2012. Evaluation of beryllium toxicity according to chemical form and particle size. Chemical substances and biological agents: Studies and research projects. Report R-750. Institut de Recherche Robert-Sauvé et en Sécurité du Travail. https://www.irsst.qc.ca/media/documents/PubIRSST/R-750.pdf. September 18, 2019.
Islam MR, Sanderson P, Naidu R, . 2022. Beryllium in contaminated soils: Implication of beryllium bioaccessibility by different exposure pathways. J Hazard Mater 421:126757. 10.1016/j.jhazmat.2021.126757.34352522
Ivannikov AT, Popov BA, Parfenova IM. 1982. [Resorption of soluble beryllium compounds through the injured skin]. Gig Tr Prof Zabol (9):50–52. (Russian)
Jacobson SA. 1933. Bone lesions in rats produced by the substitution of beryllium for calcium in the diet. Arch Pathol 15:18–26.
Jagoe CH, Matey VE, Haines TA, . 1993. Effect of beryllium on fish in acid water is analogous to aluminum toxicity. Aquat Toxicol 24(3):241–256. 10.1016/0166-445X(93)90074-B.
Jamoussi A, Merhabene T, Mlika M, . 2018. Interstitial pneumonia in a glassblower: think to chronic beryllium disease! Pan Afr Med J 31:95.31011396
Johnson JS, Foote K, McClean M, . 2001. Beryllium exposure control program at the Cardiff Atomic Weapons Establishment in the United Kingdom. Appl Occup Environ Hyg 16(5):619–630. 10.1080/10473220118634.11370940
Jonth AC, Silveira L, Fingerlin TE, . 2007. TGF-β1 variants in chronic beryllium disease and sarcoidosis. J Immunol 179(6):4255–4262. 10.4049/jimmunol.179.6.4255.17785866
Joseph P, Muchnok T, Ong T. 2001. Gene expression profile in BALB/c-3T3 cells transformed with beryllium sulfate. Mol Carcinog 32(1):28–35. 10.1002/mc.1061.11568973
Joshi JG, Price DJ, Fleming J. 1984. Ferritin and metal toxicity. In: Peeters H, ed. Protides of the biological fluids. Vol. 31. Elsevier, 183–186. 10.1016/B978-0-08-030764-0.50044-6.
Kaiser G, Grallath E, Tschopel P, . 1972. [Contribution to the optimization of the chelate gas-chromatographic determination of beryllium in limited amounts of organic materials]. Fresenius Z Anal Chem 259(4):257–264. 10.1007/bf01204798. (German)
Kanarek DJ, Wainer RA, Chamberlin RI, . 1973. Respiratory illness in a population exposed to beryllium. Am Rev Respir Dis 108(6):1295–1302. 10.1164/arrd.1973.108.6.1295.4751716
Kanematsu N, Hara M, Kada T. 1980. Rec assay and mutagenicity studies on metal compounds. Mutat Res 77(2):109–116. 10.1016/0165-1218(80)90127-5.6769036
Kaplan DI, Sajwan KS, Adriano DC, . 1990. Phytoavailability and toxicity of beryllium and vanadium. Water Air Soil Pollut 53(3):203–212. 10.1007/bf00170737.
Kay HD, Skill DI. 1934. Beryllium rickets. II. The prevention and cure of beryllium rickets. Biochem J 28(4):1222–1227. 10.1042/bj0281222.16745509
Kelleher PC, Martyny JW, Mroz MM, . 2001. Beryllium particulate exposure and disease relations in a beryllium machining plant. J Occup Environ Med 43(3):238–249. 10.1097/00043764-200103000-00012.11285872
Kent MS, Robins TG, Madl AK. 2001. Is total mass or mass of alveolar-deposited airborne particles of beryllium a better predictor of the prevalence of disease? A preliminary study of a beryllium processing facility. Appl Occup Environ Hyg 16(5):539–558. 10.1080/104732201750169633.11370934
Keshava N, Zhou G, Spruill M, . 2001. Carcinogenic potential and genomic instability of beryllium sulphate in BALB/c-3T3 cells. Mol Cell Biochem 222(1–2):69–76. 10.1023/A:1017911306449.11678613
Kılınç E, Bakırdere S, Yaman M. 2011. Trace level determination of beryllium in natural and flavored mineral waters after pre-concentration using activated carbon. Food Addit Contam Part A Chem Anal Control Expo Risk Assess 28(4):455–460. 10.1080/19440049.2011.551946.21337236
Kim KW, Kim D, Won YL, . 2013. Effects of beryllium on human serum immunoglobulin and lymphocyte subpopulation. Toxicol Res 29(2):115–120. 10.5487/TR.2013.29.2.115.24278637
Kimmerle G. 1966. Beryllium. In: Eichler O, Farah A, Herken H, ., eds. Handbook of experimental pharmacology. Vol. XXI. Springer-Verlag Berlin Heidelberg, 1–93. (German)
Kittle LA, Sawyer RT, Fadok VA, . 2002. Beryllium induces apoptosis in human lung macrophages. Sarcoidosis Vasc Diffuse Lung Dis 19(2):101–113.12102605
Klemperer FW, Martin AP, Van Riper J. 1951. Beryllium excretion in humans. AMA Arch Ind Hyg Occup Med 4(3):251–256.14867937
Kotloff RM, Richman PS, Greenacre JK, . 1993. Chronic beryllium disease in a dental laboratory technician. Am Rev Respir Dis 147(1):205–207. 10.1164/ajrccm/147.1.205.8420418
Krachler M, Rossipal E, Micetic-Turk D. 1999a. Trace element transfer from the mother to the newborn-investigations on triplets of colostrum, maternal and umbilical cord sera. Eur J Clin Nutr 53(6):486–494. 10.1038/sj.ejcn.1600781.10403586
Krachler M, Rossipal E, Micetic-Turk D. 1999b. Concentrations of trace elements in arterial and venous umbilical cord sera. Trace Elem Electrolytes 16(1):46–52.
Krám P, Hruška J, Driscoll CT. 1998. Beryllium chemistry in the Lysina catchment, Czech Republic. Water Air Soil Pollut 105(1):409–415. 10.1023/A:1005091728272.
Kreiss K, Day GA, Schuler CR. 2007. Beryllium: a modern industrial hazard. Annu Rev Public Health 28:259–277. 10.1146/annurev.publhealth.28.021406.144011.17094767
Kreiss K, Newman LS, Mroz MM, . 1989. Screening blood test identifies subclinical beryllium disease. J Occup Med 31(7):603–608. 10.1097/00043764-198907000-00011.2788726
Kreiss K, Mroz MM, Zhen B, . 1993a. Epidemiology of beryllium sensitization and disease in nuclear workers. Am Rev Respir Dis 148(4 Pt 1):985–991. 10.1164/ajrccm/148.4_Pt_1.985.8214955
Kreiss K, Mroz MM, Newman LS, . 1996. Machining risk of beryllium disease and sensitization with median exposures below 2 ug/m^3^. Am J Ind Med 30(1):16–25. 10.1002/(sici)1097-0274(199607)30:1<16::Aid-ajim3>3.0.Co;2-q.8837677
Kreiss K, Mroz MM, Zhen B, . 1997. Risks of beryllium disease related to work processes at a metal, alloy, and oxide production plant. Occup Environ Med 54(8):605–612. 10.1136/oem.54.8.605.9326165
Kreiss K, Fechter-Leggett ED, McCanlies EC, . 2016. Research to practice implications of high-risk genotypes for beryllium sensitization and disease. J Occup Environ Med 58(9):855–860. 10.1097/JOM.0000000000000805.27414009
Kriebel D, Sprince NL, Eisen EA, . 1988a. Beryllium exposure and pulmonary function: a cross sectional study of beryllium workers. Br J Ind Med 45(3):167–173. 10.1136/oem.45.3.167.3258161
Kriebel D, Sprince NL, Eisen EA, . 1988b. Pulmonary function in beryllium workers: assessment of exposure. Br J Ind Med 45(2):83–92. 10.1136/oem.45.2.83.3342199
Krishnan K, Anderson ME, Clewell HJ, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kuroda K, Endo G, Okamoto A, . 1991. Genotoxicity of beryllium, gallium and antimony in short-term assays. Mutat Res 264(4):163–170. 10.1016/0165-7992(91)90072-C.1723493
Larramendy ML, Popescu NC, Dipaolo JA. 1981. Induction by inorganic metal salts of sister chromatid exchanges and chromosome aberrations in human and Syrian hamster cell strains. Environ Mutagen 3(6):597–606. 10.1002/em.2860030602.
LeFevre ME, Joel DD. 1986. Distribution of label after intragastric administration of ^7^Be-labeled carbon to weanling and aged mice. Proc Soc Exp Biol Med 182(1):112–119. 10.3181/00379727-182-42318.3960856
Levy PS, Roth HD, Deubner DC. 2007. Exposure to beryllium and occurrence of lung cancer: a reexamination of findings from a nested case-control study. J Occup Environ Med 49(1):96–101.17215718
Levy PS, Roth HD, Deubner DC. 2009. Exposure to beryllium and occurrence of lung cancer: findings from a cox proportional hazards analysis of data from a retrospective cohort mortality study. J Occup Environ Med 51(4):480–486.19322110
Levy PS, Roth HD, Hwang PMT, . 2002. Beryllium and lung cancer: a reanalysis of a NIOSH cohort mortality study. Inhal Toxicol 14(10):1003–1015. 10.1080/08958370290084755.12396408
Li L, Hamzeh N, Gillespie M, . 2015. Beryllium increases the CD14^dim^CD16+ subset in the lung of chronic beryllium disease. PLoS ONE 10(2):e0117276. 10.1371/journal.pone.0117276.25689051
Li L, Silveira LJ, Hamzeh N, . 2016. Beryllium-induced lung disease exhibits expression profiles similar to sarcoidosis. Eur Respir J 47(6):1797–1808. 10.1183/13993003.01469-2015.27103383
Lide DR. 2005. [Beryllium and compounds]. In: CRC handbook of chemistry and physics. Boca Raton, FL: CRC Press, 4–37, 34–38, 34–45, 34–46.
Lieben J, Metzner F. 1959. Epidemiological findings associated with beryllium extraction. Am Ind Hyg Assoc J 20:494–499. 10.1080/00028895909343757.14416822
Lieben J, Williams RR. 1969. Respiratory disease associated with beryllium refining and alloy fabrication: 1968 follow-up. J Occup Med 11(9):480–485.5350221
Lindenschmidt RC, Sendelbach LE, Witschi HP, . 1986. Ferritin and in vivo beryllium toxicity. Toxicol Appl Pharmacol 82(2):344–350. 10.1016/0041-008x(86)90211-5.3945960
Liu B, Maier LA, Hamzeh N, . 2019. Polymorphism of FCGR3A gene in chronic beryllium disease. Genes Immun 20(6):493–499. 10.1038/s41435-018-0046-8.30245507
Lombardi G, Germain C, Uren J, . 2001. HLA-DP allele-specific T cell responses to beryllium account for DP-associated susceptibility to chronic beryllium disease. J Immunol 166(5):3549–3555. 10.4049/jimmunol.166.5.3549.11207315
Luke MZ, Hamilton L, Hollocher TC. 1975. Beryllium-induced misincorporation by a DNA polymerase: A possible factor in beryllium toxicity. Biochem Biophys Res Commun 62(2):497–501. 10.1016/S0006-291X(75)80166-5.1111533
Lum KR, Gammon KL. 1985. Geochemical availability of some trace and major elements in surficial sediments of the Detroit River and Western Lake Erie. J Great Lakes Res 11(3):328–338. 10.1016/S0380-1330(85)71776-5.
Mack DG, Lanham AM, Falta MT, . 2010. Deficient and dysfunctional regulatory T cells in the lungs of chronic beryllium disease subjects. Am J Respir Crit Care Med 181(11):1241–1249. 10.1164/rccm.201001-0025OC.20299529
Mack DG, Falta MT, McKee AS, . 2014. Regulatory T cells modulate granulomatous inflammation in an HLA-DP2 transgenic murine model of beryllium-induced disease. Proc Natl Acad Sci USA 111(23):8553–8558. 10.1073/pnas.1408048111.24912188
MacMahon B. 1994. The epidemiological evidence on the carcinogenicity of beryllium in humans. J Occup Med 36(1):15–24; discussion 25-16.8138844
Madl AK, Unice K, Brown JL, . 2007. Exposure-response analysis for beryllium sensitization and chronic beryllium disease among workers in a beryllium metal machining plant. J Occup Environ Hyg 4(6):448–466. 10.1080/15459620701354747.17474035
Magos L. 1991. Epidemiological and experimental aspects of metal carcinogenesis: physicochemical properties, kinetics, and the active species. Environ Health Perspect 95:157–189. 10.1289/ehp.9195157.1821370
Maier LA. 2001. Beryllium health effects in the era of the beryllium lymphocyte proliferation test. Appl Occup Environ Hyg 16(5):514–520. 10.1080/104732201750169570.11370931
Maier LA. 2002. Genetic and exposure risks for chronic beryllium disease. Clin Chest Med 23(4):827–839. 10.1016/S0272-5231(02)00029-1.12516537
Maier LA, Raynolds MV, Young DA, . 1999. Angiotensin-1 converting enzyme polymorphisms in chronic beryllium disease. Am J Respir Crit Care Med 159(4 Pt 1):1342–1350. 10.1164/ajrccm.159.4.9806106.10194187
Maier LA, Sawyer RT, Bauer RA, . 2001. High beryllium-stimulated TNF-α is associated with the -308 TNF-α promoter polymorphism and with clinical severity in chronic beryllium disease. Am J Respir Crit Care Med 164(7):1192–1199. 10.1164/ajrccm.164.7.2012123.11673208
Maier LA, McGrath DS, Sato H, . 2003. Influence of MHC class II in susceptibility to beryllium sensitization and chronic beryllium disease. J Immunol 171(12):6910–6918. 10.4049/jimmunol.171.12.6910.14662898
Maier LA, Martyny JW, Liang J, . 2008. Recent chronic beryllium disease in residents surrounding a beryllium facility. Am J Respir Crit Care Med 177(9):1012–1017. 10.1164/rccm.200607-1042OC.18244954
Marchand-Adam S, El Khatib A, Guillon F, . 2008. Short- and long-term response to corticosteroid therapy in chronic beryllium disease. Eur Respir J 32(3):687–693. 10.1183/09031936.00149607.18757698
Martin SC, Larivière C. 2014. Community health risk assessment of primary aluminum smelter emissions. J Occup Environ Med 56(5 Suppl):S33–S39. 10.1097/JOM.0000000000000135.24806724
Martin AK, Mack DG, Falta MT, . 2011. Beryllium-specific CD4^+^ T cells in blood as a biomarker of disease progression. J Allergy Clin Immunol 128(5):1100–1106 e1101–1105. 10.1016/j.jaci.2011.08.022.21943943
Martinsen I, Thomassen Y. 1986. Multielemental characterization of human lung tissues by ICP-AES. Acta Pharmacol Toxicol (Copenh) 59(Suppl 7):620–623. 10.1111/j.1600-0773.1986.tb02841.x.3776639
Marx JJ, Burrell R. 1973. Delayed hypersensitivity to beryllium compounds. J Immunol 111(2):590–598. 10.4049/jimmunol.111.2.590.4717994
Mathur S, Mathur R. 1994. Transplacental transport of beryllium and its teratogenic effects. In: Collery P, Poirier LA, Littlefield NA, ., eds. Metal ions in biology and medicine. Vol. 3. London, England: John Libbey and Company Ltd, 129–135.
Mathur R, Mathur S, Prakash AO. 1987a. Beryllium induced haematological alterations and their response to Liv-52. Ind Health 25(3):131–138. 10.2486/indhealth.25.131.3679889
Mathur R, Nirala SK, Mathur A. 2004. Comparative effectiveness of CaNa_3_DTPA and tiron along with α-tocopherol against beryllium-induced biochemical alterations in rats. Indian J Exp Biol 42(6):570–574.15260107
Mathur R, Sharma S, Mathur S, . 1987b. Effect of beryllium nitrate on early and late pregnancy in rats. Bull Environ Contam Toxicol 38(1):73–77. 10.1007/bf01606561.3814854
Mathur S, Flora SJ, Mathur R, . 1993. Mobilization and distribution of beryllium over the course of chelation therapy with some polyaminocarboxylic acids in the rat. Hum Exp Toxicol 12(1):19–24. 10.1177/096032719301200104.8094965
Matsumoto A, Hisada Y, Yoshimura Y. 1991. Calcium and phosphate concentrations and alkaline and acid phosphatase activities in serum of the rat fed with low calcium and beryllium diets. Oral Ther Pharmacol 10:253–259. 10.11263/jsotp1982.10.253.
Mayer AS, Hamzeh N, Maier LA. 2014. Sarcoidosis and chronic beryllium disease: similarities and differences. Semin Respir Crit Care Med 35(3):316–329. 10.1055/s-0034-1377059.25007084
McCanlies EC, Ensey JS, Schuler CR, . 2004. The association between HLA-DPB1^Glu69^ and chronic beryllium disease and beryllium sensitization. Am J Ind Med 46(2):95–103. 10.1002/ajim.20045.15273960
McCanlies EC, Schuler CR, Kreiss K, . 2007. TNF-α polymorphisms in chronic beryllium disease and beryllium sensitization. J Occup Environ Med 49(4):446–452.17426528
McCanlies EC, Yucesoy B, Mnatsakanova A, . 2010. Association between IL-1A single nucleotide polymorphisms and chronic beryllium disease and beryllium sensitization. J Occup Environ Med 52(7):680–684.20595916
McCleskey TM, Buchner V, Field RW, . 2009. Recent advances in understanding the biomolecular basis of chronic beryllium disease: a review. Rev Environ Health 24(2):75–115. 10.1515/REVEH.2009.24.2.75.19658317
McConnochie K, Williams WR, Kilpatrick GS, . 1988. Chronic beryllium disease in identical twins. Br J Dis Chest 82(4):431–435. 10.1016/0007-0971(88)90101-5.3256356
McHard JA, Foulk SJ, Jorgensen JL, . 1980. Analysis of trace metals in orange juice. In: Nagy S, Attaway JA, eds. Citrus nutrition and quality. Washington, DC: American Chemical Society, 363–392.
Measures CI, Edmond JM. 1986. Determination of beryllium in natural waters in real time using electron capture detection gas chromatography. Anal Chem 58(9):2065–2069. 10.1021/ac00122a029.
Meehan WR, Smythe LE. 1967. Occurrence of beryllium as a trace element in environmental materials. Environ Sci Technol 1(10):839–844. 10.1021/es60010a007.22148381
Merrill JR, Lyden EFX, Honda M, . 1960. The sedimentary geochemistry of the beryllium isotopes. Geochim Cosmochim Acta 18(1):108–129. 10.1016/0016-7037(60)90022-3.
Messer RLW, Doeller JE, Kraus DW, . 2000. An investigation of fibroblast mitochondria enzyme activity and respiration in response to metallic ions released from dental alloys. J Biomed Mater Res 50(4):598–604. 10.1002/(SICI)1097-4636(20000615)50:4<598::AID-JBM16>3.0.CO;2-%23.10756319
Middleton DC, Lewin MD, Kowalski PJ, . 2006. The BeLPT: algorithms and implications. Am J Ind Med 49(1):36–44. 10.1002/ajim.20241.16362939
Middleton DC, Fink J, Kowalski PJ, . 2008. Optimizing BeLPT criteria for beryllium sensitization. Am J Ind Med 51(3):166–172. 10.1002/ajim.20548.18181198
Middleton DC, Mayer AS, Lewin MD, . 2011. Interpreting borderline BeLPT results. Am J Ind Med 54(3):205–209. 10.1002/ajim.20909.20957676
Mikulski MA, Leonard SA, Sanderson WT, . 2011a. Risk of beryllium sensitization in a low-exposed former nuclear weapons cohort from the Cold War era. Am J Ind Med 54(3):194–204. 10.1002/ajim.20913.21298695
Mikulski MA, Sanderson WT, Leonard SA, . 2011b. Prevalence of beryllium sensitization among Department of Defense conventional munitions workers at low risk for exposure. J Occup Environ Med 53(3):258–265.21293302
Misra UK, Gawdi G, Pizzo SV. 2002. Beryllium fluoride-induced cell proliferation: a process requiring P21 ras-dependent activated signal transduction and NF-κB-dependent gene regulation. J Leukoc Biol 71(3):487–494. 10.1189/jlb.71.3.487.11867686
Miyaki M, Akamatsu N, Ono T, . 1979. Mutagenicity of metal cations in cultured cells from Chinese hamster. Mutat Res 68(3):259–263. 10.1016/0165-1218(79)90157-5.514305
Morgareidge K, Cox GE, Bailey DE. 1975. Chronic feeding studies with beryllium sulfate in rats: Evaluation of carcinogenic potential. Pittsburgh, PA: Food and Drug Research Laboratories, Inc. Aluminum Company of America.
Morgareidge K, Cox GE, Gallo MA. 1976. Chronic feeding studies with beryllium in dogs. Food and Drug Research Laboratories, Inc. Aluminum Company of America. Alcan Research and Development, Ltd., Kawecki-Berylco Industries, Inc., and Brush-Wellman, Inc.
Morton J, Leese E, Cotton R, . 2011. Beryllium in urine by ICP-MS: a comparison of low level exposed workers and unexposed persons. Int Arch Occup Environ Health 84(6):697–704. 10.1007/s00420-010-0587-2.20963604
Mosquin PL, Rothman KJ. 2017. Reanalysis of reported associations of beryllium and lung cancer in a large occupational cohort. J Occup Environ Med 59(3):274–281.28157764
Mroz MM, Maier LA, Strand M, . 2009. Beryllium lymphocyte proliferation test surveillance identifies clinically significant beryllium disease. Am J Ind Med 52(10):762–773. 10.1002/ajim.20736.19681064
Mroz MM, Ferguson JH, Faino AV, . 2018. Effect of inhaled corticosteroids on lung function in chronic beryllium disease. Respir Med 138S:S14–S19. 10.1016/j.rmed.2018.01.009.29453139
Mudireddy SR, Abdul AR, Gorjala P, . 2014. Beryllium is an inhibitor of cellular GSK-3B that is 1,000-fold more potent than lithium. Biometals 27(6):1203–1216. 10.1007/s10534-014-9783-y.25104312
Muller C, Mazer B, Salehi F, . 2010. Urinary levels, tissue concentrations and lung inflammation after nose-only exposure to three different chemical forms of beryllium. J Appl Toxicol 30(5):411–415. 10.1002/jat.1512.20186892
Muller C, Salehi F, Mazer B, . 2011. Immunotoxicity of 3 chemical forms of beryllium following inhalation exposure. Int J Toxicol 30(5):538–545. 10.1177/1091581811413831.22013136
Muto H, Abe T, Takizawa Y, . 1994. Simultaneous multielemental analysis of daily food samples by inductively coupled plasma mass spectrometry. Sci Total Environ 144(1–3):231–239. 10.1016/0048-9697(94)90441-3.8209229
Naccache JM, Marchand-Adam S, Kambouchner M, . 2003. Ground-glass computed tomography pattern in chronic beryllium disease: pathologic substratum and evolution. J Comput Assist Tomogr 27(4):496–500. 10.1097/00004728-200307000-00007.12886131
Nadal M, Bocio A, Schuhmacher M, . 2005. Monitoring metals in the population living in the vicinity of a hazardous waste incinerator: levels in hair of school children. Biol Trace Elem Res 104(3):203–213. 10.1385/BTER:104:3:203.15930590
Nadal M, Mari M, Schuhmacher M, . 2019. Monitoring dioxins and furans in plasma of individuals living near a hazardous waste incinerator: Temporal trend after 20 years. Environ Res 173:207–211. 10.1016/j.envres.2019.03.051.30927599
Nalbandian H. 2012. Trace element emissions from coal. London, UK: IEA Clean Coal Centre. https://www.usea.org/sites/default/files/092012_Trace%20element%20emissions%20from%20coal_ccc203.pdf. December 15, 2022.
NAS/NRC. 1989. Report of the oversight committee. In: Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press, 15–35.
Neal C, Jeffery HA, Conway T, . 1992. Beryllium concentrations in rainfall, stemflow, throughfall, mist and stream waters for an upland acidified area of mid-Wales. J Hydrol 136(1):33–49. 10.1016/0022-1694(92)90003-E.
Newman LS. 1996a. Significance of the blood beryllium lymphocyte proliferation test. Environ Health Perspect 104(Suppl 5):953–956. 10.1289/ehp.96104s5953.8933041
Newman LS. 1996b. Immunology, genetics, and epidemiology of beryllium disease. Chest 109(3):40S–43S. 10.1378/chest.109.3_Supplement.40S.8598147
Newman LS, Kreiss K. 1992. Nonoccupational beryllium disease masquerading as sarcoidosis: identification by blood lymphocyte proliferative response to beryllium. Am Rev Respir Dis 145(5):1212–1214. 10.1164/ajrccm/145.5.1212.1586067
Newman LS, Kreiss K, King TE, . 1989. Pathologic and immunologic alterations in early stages of beryllium disease. Re-examination of disease definition and natural history. Am Rev Respir Dis 139(6):1479–1486. 10.1164/ajrccm/139.6.1479.2729754
Newman LS, Mroz MM, Maier LA, . 2001. Efficacy of serial medical surveillance for chronic beryllium disease in a beryllium machining plant. J Occup Environ Med 43(3):231–237.11285871
Newman LS, Mroz MM, Balkissoon R, . 2005. Beryllium sensitization progresses to chronic beryllium disease: a longitudinal study of disease risk. Am J Respir Crit Care Med 171(1):54–60. 10.1164/rccm.200402-190OC.15374840
Nickell-Brady C, Hahn FF, Finch GL, . 1994. Analysis of K-ras, p53 and c-raf-1 mutations in beryllium-induced rat lung tumors. Carcinogenesis 15(2):257–262. 10.1093/carcin/15.2.257.7545909
Nikula KJ, Swafford DS, Hoover MD, . 1997. Chronic granulomatous pneumonia and lymphocytic responses induced by inhaled beryllium metal in A/J and C3H/HeJ mice. Toxicol Pathol 25(1):2–12. 10.1177/019262339702500102.9061844
Nilsen AM, Vik R, Behrens C, . 2010. Beryllium sensitivity among workers at a Norwegian aluminum smelter. Am J Ind Med 53(7):724–732. 10.1002/ajim.20816.20187010
NIOSH. 1995. Report to Congress on workers’ home contamination study conducted under the Workers’ Family Protection Act (29 U.S.C. 671a). Cincinnati, OH: National Institute for Occupational Safety and Health. NIOSH Pub No. 95-123. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB96192000.xhtml. April 4, 2023.
NIOSH. 2002. National occupational exposure survey (NOES). Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service, Center for Disease Control, National Institute for Occupational Safety and Health.
NIOSH. 2007a. Beryllium in surface wipes by fluorometry: Method 9110. Issue 2. NIOSH manual of analytical methods (NMAM). National Institute for Occupational Safety and Health: https://www.cdc.gov/niosh/docs/2014-151/pdfs/methods/9110.pdf. December 15, 2022.
NIOSH. 2007b. Beryllium and beryllium compounds (as Be). NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health. DHHS (NIOSH) Publication No. 2005-149. https://www.cdc.gov/niosh/docs/2005-149/pdfs/2005-149.pdf. December 11, 2022.
Nirala SK, Bhadauria M. 2008. Synergistic effects of ferritin and propolis in modulation of beryllium induced toxicogenic alterations. Food Chem Toxicol 46(9):3069–3079. 10.1016/j.fct.2008.06.009.18620018
Nirala SK, Bhadauria M, Mathur R, . 2007. Amelioration of beryllium induced alterations in hepatorenal biochemistry and ultramorphology by co-administration of tiferron and adjuvants. J Biomed Sci 14(3):331–345. 10.1007/s11373-007-9147-5.17278010
Nirala SK, Bhadauria M, Shukla S, . 2008. Pharmacological intervention of tiferron and propolis to alleviate beryllium-induced hepatorenal toxicity. Fundam Clin Pharmacol 22(4):403–415. 10.1111/j.1472-8206.2008.00603.x.18705751
Nisse C, Tagne-Fotso R, Howsam M, . 2017. Blood and urinary levels of metals and metalloids in the general adult population of Northern France: The IMEPOGE study, 2008-2010. Int J Hyg Environ Health 220(2 Pt B):341–363. 10.1016/j.ijheh.2016.09.020.27931767
NLM. 2023a. PubChem compound summary: Beryllium (CASRN: 7440-41-7). National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/Beryllium. April 6, 2023.
NLM. 2023b. PubChem compound summary: Beryllium chloride (CASRN: 7787-47-5). National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/24588. April 6, 2023.
NLM. 2023c. PubChem compound summary: Beryllium fluoride (CASRN: 7787-49-7). National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/24589. April 6, 2023.
NLM. 2023d. PubChem compound summary: Beryllium hydroxide (CASRN: 13327-32-7). National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/518753. April 6, 2023.
NLM. 2023e. PubChem compound summary: Beryllium oxide (CASRN: 13044-56-9). National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/14775. April 6, 2023.
NLM. 2023f. PubChem compound summary: Phosphoric acid, beryllium salt (CASRN: 35089-00-0). National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/61941. April 6, 2023.
NLM. 2023g. PubChem compound summary: Beryllium nitrate (CASRN: 13597-99-4 (anhydrous), 7787-55-5 (trihydrate), 13510-48-0 (tetrahydrate)). National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/26126. April 6, 2023.
NLM. 2023h. PubChem compound summary: Beryllium sulfate (CASRN: 13510-49-1 (anhydrous), 7787-56-6 (tetrahydrate)). National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/26077. April 6, 2023.
NLM. 2023i. PubChem compound summary: Berylliumoxide carbonate (CASRN: 66104-24-3). National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/49868160. April 6, 2023.
Nogaj E, Kwapulinski J, Misiolek M, . 2014. Beryllium concentration in pharyngeal tonsils in children. Ann Agric Environ Med 21(2):267–271.24959774
NRC. 2008. Managing health effects of beryllium exposure. Washington, DC: National Research Council, 1–9, 85–105. 10.17226/12464.
NTP. 2021. Beryllium and beryllium compounds. In: Report on carcinogens. 15^th^ ed. National Toxicology Program. https://ntp.niehs.nih.gov/ntp/roc/content/profiles/beryllium.pdf. December 10, 2022.
OSHA. 2002. Preventing adverse health effects from exposure to beryllium in dental laboratories. Hazard information bulletin. Occupational Safety and Health Administration. HIB 02-04-19 (rev. 05-14-02). https://www.osha.gov/sites/default/files/publications/hib20020419.pdf.
OSHA. 2015. Occupational exposure to beryllium and beryllium compounds. Occupational Safety and Health Administration. Fed Regist 80(152):47565–47828.
OSHA. 2021a. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Beryllium. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1024. https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol6/pdf/CFR-2021-title29-vol6-sec1910-1024.pdf. December 10, 2022.
OSHA. 2021b. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Beryllium. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1024. https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol7/pdf/CFR-2021-title29-vol7-sec1915-1024.pdf. December 10, 2022.
OSHA. 2021c. Safety and health regulations for construction. Subpart Z - Toxic and hazardous substances. Beryllium. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.1124. https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol8/pdf/CFR-2021-title29-vol8-sec1926-1124.pdf. December 10, 2022.
Palmer BE, Mack DG, Martin AK, . 2008. Up-regulation of programmed death-1 expression on beryllium-specific CD4+ T cells in chronic beryllium disease. J Immunol 180(4):2704–2712. 10.4049/jimmunol.180.4.2704.18250483
Pappas GP, Newman LS. 1993. Early pulmonary physiologic abnormalities in beryllium disease. Am Rev Respir Dis 148(3):661–666. 10.1164/ajrccm/148.3.661.8368637
Paschal DC, Ting BG, Morrow JC, . 1998. Trace metals in urine of United States residents: reference range concentrations. Environ Res 76(1):53–59. 10.1006/enrs.1997.3793.9466897
Paton GR, Allison AC. 1972. Chromosome damage in human cell cultures induced by metal salts. Mutat Res Fundam Mol Mech Mutagen 16(3):332–336. 10.1016/0027-5107(72)90166-2.
Pearson AJ, Ashmore E. 2020. Risk assessment of antimony, barium, beryllium, boron, bromine, lithium, nickel, strontium, thallium and uranium concentrations in the New Zealand diet. Food Addit Contam Part A Chem Anal Control Expo Risk Assess 37(3):451–464. 10.1080/19440049.2019.1704445.31881162
Perry ST, Kulkarni SB, Lee K-L, . 1982. Selective effect of the metallocarcinogen beryllium on hormonal regulation of gene expression in cultured cells. Cancer Res 42(2):473–476.6120038
Pienta RJ, Poiley JA, Lebherz WB. 1977. Morphological transformation of early passage golden Syrian hamster embryo cells derived from cryopreserved primary cultures as a reliable in vitro bioassay for identifying diverse carcinogens. Int J Cancer 19(5):642–655. 10.1002/ijc.2910190508.863543
Polak L, Barnes JM, Turk JL. 1968. The genetic control of contact sensitization to inorganic metal compounds in guinea-pigs. Immunology 14(5):707–711.5656877
Pott GB, Palmer BE, Sullivan AK, . 2005. Frequency of beryllium-specific, T_H_1-type cytokine-expressing CD4^+^ T cells in patients with beryllium-induced disease. J Allergy Clin Immunol 115(5):1036–1042. 10.1016/j.jaci.2005.01.019.15867863
Raven KP, Loeppert RH. 1997. Heavy metals in the environment. J Environ Qual 26:551–557.
Redlich CA, Herrick CA. 2008. Lung/skin connections in occupational lung disease. Curr Opin Allergy Clin Immunol 8(2):115–119. 10.1097/ACI.0b013e3282f85a31.18317018
Reeves AL. 1965. The absorption of beryllium from the gastrointestinal tract. Arch Environ Health 11(2):209–214. 10.1080/00039896.1965.10664200.5832251
Reeves AL, Vorwald AJ. 1967. Beryllium carcinogenesis. II. Pulmonary deposition and clearance of inhaled beryllium sulfate in the rat. Cancer Res 27(3):446–451.6021503
Reeves AL, Deitch D, Vorwald AJ. 1967. Beryllium carcinogenesis. I. Inhalation exposure of rats to beryllium sulfate aerosol. Cancer Res 27(3):439–445.6021502
RePORTER. 2022. Beryllium. Research Portfolio Online Reporting Tools. National Institutes of Health. https://reporter.nih.gov/. November 8, 2022.
Resnick H, Roche M, Morgan WKC. 1970. Immunoglobulin concentrations in berylliosis. Am Rev Respir Dis 101(4):504–510. 10.1164/arrd.1970.101.4.504.4191591
Rhoads K, Sanders CL. 1985. Lung clearance, translocation, and acute toxicity of arsenic, beryllium, cadmium, cobalt, lead, selenium, vanadium, and ytterbium oxides following deposition in rat lung. Environ Res 36(2):359–378. 10.1016/0013-9351(85)90031-3.3872210
Richeldi L, Sorrentino R, Saltini C. 1993. HLA-DPB1 glutamate 69: a genetic marker of beryllium disease. Science 262(5131):242–244. 10.1126/science.8105536.8105536
Richeldi L, Kreiss K, Mroz MM, . 1997. Interaction of genetic and exposure factors in the prevalence of berylliosis. Am J Ind Med 32(4):337–340. 10.1002/(sici)1097-0274(199710)32:4<337::aid-ajim3>3.0.co;2-r.9258386
Robinson FR, Schaffner F, Trachtenberg E. 1968. Ultrastructure of the lungs of dogs exposed to beryllium-containing dusts. Arch Environ Health 17(2):193–203. 10.1080/00039896.1968.10665213.5672534
Rodrigues EG, McClean MD, Weinberg J, . 2008. Beryllium sensitization and lung function among former workers at the Nevada Test Site. Am J Ind Med 51(7):512–523. 10.1002/ajim.20585.18459143
Rogliani P, Amicosante M, Berretta F, . 2004. Role of the HLA-DP Glu 69 and the TNF-α TNF-α^2^ gene markers in susceptibility to beryllium hypersensitivity. Int J Immunopathol Pharmacol 17(2 Suppl):3–10.15345185
Romney EM, Childress JD. 1965. Effects of beryllium in plants and soil. Soil Sci 100(3):210–217.
Rosenkranz HS, Poirier LA. 1979. Evaluation of the mutagenicity and DNA-modifying activity of carcinogens and noncarcinogens in microbial systems. J Natl Cancer Inst 62(12):873–892. 10.1093/jnci/62.4.873.372656
Rosenman K, Hertzberg V, Rice C, . 2005. Chronic beryllium disease and sensitization at a beryllium processing facility. Environ Health Perspect 113(10):1366–1372. 10.1289/ehp.7845.16203248
Rosenman K, Reilly MJ, Hertzberg V, . 2006. Beryllium exposure data: Rosenman et al. respond. Environ Health Perspect 114(4):A213–A215. 10.1289/ehp.114-1440811.16581526
Rosenman KD, Rossman M, Hertzberg V, . 2011. HLA class II DPB1 and DRB1 polymorphisms associated with genetic susceptibility to beryllium toxicity. Occup Environ Med 68(7):487–493. 10.1136/oem.2010.055046.21186201
Rossman MD. 2001. Chronic beryllium disease: A hypersensitivity disorder. Appl Occup Environ Hyg 16(5):615–618. 10.1080/10473220121477.11370939
Rossman MD, Stubbs J, Lee CW, . 2002. Human leukocyte antigen Class II amino acid epitopes: susceptibility and progression markers for beryllium hypersensitivity. Am J Respir Crit Care Med 165(6):788–794. 10.1164/ajrccm.165.6.2104002.11897645
Rossman MD, Kern JA, Elias JA, . 1988. Proliferative response of bronchoalveolar lymphocytes to beryllium. A test for chronic beryllium disease. Ann Intern Med 108(5):687–693. 10.7326/0003-4819-108-5-687.3282464
Ryves WJ, Dajani R, Pearl L, . 2002. Glycogen synthase kinase-3 inhibition by lithium and beryllium suggests the presence of two magnesium binding sites. Biochem Biophys Res Commun 290(3):967–972. 10.1006/bbrc.2001.6305.11798168
Sackett HM, Maier LA, Silveira LJ, . 2004. Beryllium medical surveillance at a former nuclear weapons facility during cleanup operations. J Occup Environ Med 46(9):953–961. 10.1097/01.jom.0000139872.80118.bd.15354061
Salehi F, Zayed J, Audusseau S, . 2009. Immunological responses in C3H/HeJ mice following nose-only inhalation exposure to different sizes of beryllium metal particles. J Appl Toxicol 29(1):61–68. 10.1002/jat.1383.18980269
Salo JE, Harrison D, Archibald EM. 1986. Removing contaminants by groundwater recharge basins. Am Water Works Assoc J 78(9):76–81. 10.1002/j.1551-8833.1986.tb05813.x.
Saltini C, Winestock K, Kirby M, . 1989. Maintenance of alveolitis in patients with chronic beryllium disease by beryllium-specific helper T cells. New Engl J Med 320(17):1103–1109. 10.1056/NEJM198904273201702.2469014
Saltini C, Kirby M, Trapnell BC, . 1990. Biased accumulation of T lymphocytes with “memory”-type CD45 leukocyte common antigen gene expression on the epithelial surface of the human lung. J Exp Med 171(4):1123–1140. 10.1084/jem.171.4.1123.2139099
Saltini C, Richeldi L, Losi M, . 2001. Major histocompatibility locus genetic markers of beryllium sensitization and disease. Eur Respir J 18(4):677–684. 10.1183/09031936.01.00106201.11716174
Sanders CL, Cannon WC, Powers GJ, . 1975. Toxicology of high-fired beryllium oxide inhaled by rodents. I. Metabolism and early effects. Arch Environ Health 30(11):546–551. 10.1080/00039896.1975.10666773.1217915
Sanderson WT, Petersen MR, Ward EM. 2001a. Estimating historical exposures of workers in a beryllium manufacturing plant. Am J Ind Med 39(2):145–157. 10.1002/1097-0274(200102)39:2<145::aid-ajim1002>3.0.co;2-y.11170157
Sanderson WT, Ward EM, Steenland K. 2001c. Re: Response to criticisms of “Lung cancer case-control study of beryllium workers” Am. J. Ind. Med. 2001. 39:133–144. Am J Ind Med 40(3):286–288. 10.1002/ajim.1102.11170156
Sanderson WT, Henneberger PK, Martyny J, . 1999. Beryllium contamination inside vehicles of machine shop workers. Appl Occup Environ Hyg 14(4):223–230. 10.1080/104732299302990.10457644
Sanderson WT, Ward EM, Steenland K, . 2001b. Lung cancer case-control study of beryllium workers. Am J Ind Med 39(2):133–144. 10.1002/1097-0274(200102)39:2<133::AID-AJIM1001>3.0.CO;2-7.11170156
Saribal D. 2020. ICP-MS analysis of trace element concentrations in cow’s milk samples from supermarkets in Istanbul, Turkey. Biol Trace Elem Res 193(1):166–173. 10.1007/s12011-019-01708-4.30963409
Sato H, Silveira L, Fingerlin T, . 2007a. TNF polymorphism and bronchoalveolar lavage cell TNF-α levels in chronic beryllium disease and beryllium sensitization. J Allergy Clin Immunol 119(3):687–696. 10.1016/j.jaci.2006.10.028.17208287
Sato H, Spagnolo P, Silveira L, . 2007b. BTNL2 allele associations with chronic beryllium disease in HLA-DPB1*Glu69-negative individuals. Tissue Antigens 70(6):480–486. 10.1111/j.1399-0039.2007.00944.x.17927685
Sato H, Silveira L, Spagnolo P, . 2010. CC chemokine receptor 5 gene polymorphisms in beryllium disease. Eur Respir J 36(2):331–338. 10.1183/09031936.00107809.20075058
Sawyer RT, Maier LA. 2011. Chronic beryllium disease: an updated model interaction between innate and acquired immunity. Biometals 24(1):1–17.20981472
Sawyer RT, Abraham JL, Daniloff E, . 2005. Secondary ion mass spectroscopy demonstrates retention of beryllium in chronic beryllium disease granulomas. J Occup Environ Med 47(12):1218–1226.16340702
Sax SN, Bennett DH, Chillrud SN, . 2006. A cancer risk assessment of inner-city teenagers living in New York City and Los Angeles. Environ Health Perspect 114(10):1558–1566.17035143
Schepers GW. 1964. Biological action of beryllium reaction of the monkey to inhaled aerosols. Ind Med Surg 33:1–16.14104245
Schepers GW, Durkan TM, Delahant AB, . 1957. The biological action of inhaled beryllium sulfate; a preliminary chronic toxicity study on rats. AMA Arch Ind Health 15(1):32–58.13393810
Schlesinger RB, Ben-Jebria A, Dahl AR, . 1997. Disposition of inhaled toxicants. In: Massaro EJ, ed. Handbook of human toxicology. New York, NY: CRC Press, 493–550.
Schroeder HA, Mitchener M. 1975a. Life-term studies in rats: effects of aluminum, barium, beryllium, and tungsten. J Nutr 105(4):421–427. 10.1093/jn/105.4.421.1113208
Schroeder HA, Mitchener M. 1975b. Life-term effects of mercury, methyl mercury, and nine other trace metals on mice. J Nutr 105(4):452–458. 10.1093/jn/105.4.452.1113210
Schubauer-Berigan MK, Couch JR, Deddens JA. 2017. Is beryllium-induced lung cancer caused only by soluble forms and high exposure levels? Occup Environ Med 74(8):601–603. 10.1136/oemed-2016-104064.28259842
Schubauer-Berigan MK, Deddens JA, Steenland K, . 2008. Adjustment for temporal confounders in a reanalysis of a case-control study of beryllium and lung cancer. Occup Environ Med 65(6):379–383. 10.1136/oem.2007.033654.17890301
Schubauer-Berigan MK, Couch JR, Petersen MR, . 2011a. Cohort mortality study of workers at seven beryllium processing plants: update and associations with cumulative and maximum exposure. Occup Environ Med 68(5):345–353. 10.1136/oem.2010.056481.20952555
Schubauer-Berigan MK, Deddens JA, Couch JR, . 2011b. Risk of lung cancer associated with quantitative beryllium exposure metrics within an occupational cohort. Occup Environ Med 68(5):354–360. 10.1136/oem.2010.056515.21084327
Schuler CR, Kent MS, Deubner DC, . 2005. Process-related risk of beryllium sensitization and disease in a copper-beryllium alloy facility. Am J Ind Med 47(3):195–205. 10.1002/ajim.20140.15712254
Schuler CR, Kitt MM, Henneberger PK, . 2008. Cumulative sensitization and disease in a beryllium oxide ceramics worker cohort. J Occup Environ Med 50(12):1343–1350. 10.1097/JOM.0b013e31818def24.19092488
Schuler CR, Virji MA, Deubner DC, . 2012. Sensitization and chronic beryllium disease at a primary manufacturing facility, part 3: exposure-response among short-term workers. Scand J Work Environ Health 38(3):270–281.21877099
Seeger R, Schleicher G, Schweinshaut P. 1984. [Investigation into the occurrence of beryllium in mushrooms]. Dtsch Lebensm Rundsch 80:178–186. (German)
Sendelbach LE, Witschi HP. 1987a. Protection by parenteral iron administration against the inhalation toxicity of beryllium sulfate. Toxicol Lett 35(2–3):321–325. 10.1016/0378-4274(87)90222-0.3824419
Sendelbach LE, Witschi HP. 1987b. Bronchoalveolar lavage in rats and mice following beryllium sulfate inhalation. Toxicol Appl Pharmacol 90(2):322–329. 10.1016/0041-008X(87)90339-5.3629606
Sendelbach LE, Witschi HP, Tryka AF. 1986. Acute pulmonary toxicity of beryllium sulfate inhalation in rats and mice: Cell kinetics and histopathology. Toxicol Appl Pharmacol 85(2):248–256. 10.1016/0041-008X(86)90119-5.3764912
Sendelbach LE, Tryka AF, Witschi H. 1989. Progressive lung injury over a one-year period after a single inhalation exposure to beryllium sulfate. Am Rev of Respir Dis 139(4):1003–1009. 10.1164/ajrccm/139.4.1003.2930060
Sharma P, Shukla S. 2000. Comparative effectiveness of Tiron (4,5-dihydroxy benzene 1,3-disulphonic acid disodium salt) and CaNa2EDTA with time after beryllium poisoning. Indian J Exp Biol 38(8):785–790.12557911
Sharma P, Johri S, Shukla S. 2000. Beryllium-induced toxicity and its prevention by treatment with chelating agents. J Appl Toxicol 20(4):313–318. 10.1002/1099-1263(200007/08)20:4<313::AID-JAT660>3.0.CO;2-J.10942906
Sharma P, Shah A, Shukla S. 2002. Protective effect of Tiron (4,5-dihydroxybenzene-1,3-disulfonic acid disodium salt) against beryllium-induced maternal and fetal toxicity in rats. Arch Toxicol 76(8):442–448. 10.1007/s00204-002-0356-4.12185411
Shirai S, Suzuki Y, Yoshinaga J, . 2010. Maternal exposure to low-level heavy metals during pregnancy and birth size. J Environ Sci Health A Tox Hazard Subst Environ Eng 45(11):1468–1474. 10.1080/10934529.2010.500942.20694885
Shukla S, Sharma P, Johri S, . 1998. Influence of chelating agents on the toxicity and distribution of beryllium in rats. J Appl Toxicol 18(5):331–335. 10.1002/(sici)1099-1263(1998090)18:5<331::Aid-jat517>3.0.Co;2-0.9804433
Silveira LJ, McCanlies EC, Fingerlin TE, . 2012. Chronic beryllium disease, HLA-DPB1, and the DP peptide binding groove. J Immunol 189(8):4014–4023. 10.4049/jimmunol.1200798.22972925
Silveira LJ, Strand M, Van Dyke MV, . 2017. Clinical tool for disease phenotyping in granulomatous lung disease. PLoS ONE 12(11):e0188119. 10.1371/journal.pone.0188119.29145499
Simmon VF. 1979. In vitro assays for recombinogenic activity of chemical carcinogens and related compounds with Saccharomyces cerevisiae D3. J Natl Cancer Inst 62(1):901–909. 10.1093/jnci/62.4.901.372658
Sirover MA, Loeb LA. 1976. Metal-induced infidelity during DNA synthesis. Proc Natl Acad Sci USA 73(7):2331–2335. 10.1073/pnas.73.7.2331.1065882
Skalny AV, Kaminskaya GA, Krekesheva TI, . 2018. Assessment of hair metal levels in aluminium plant workers using scalp hair ICP-DRC-MS analysis. J Trace Elem Med Biol 50:658–663. 10.1016/j.jtemb.2018.06.014.29954652
Smith CJ, Livingston SD, Doolittle DJ. 1997. An international literature survey of “IARC Group I carcinogens” reported in mainstream cigarette smoke. Food Chem Toxicol 35(10–11):1107–1130. 10.1016/s0278-6915(97)00063-x.9463546
Snow ET. 1992. Metal carcinogenesis: mechanistic implications. Pharmacol Ther 53(1):31–65. 10.1016/0163-7258(92)90043-y.1641401
Snyder JA, Demchuk E, McCanlies EC, . 2008. Impact of negatively charged patches on the surface of MHC class II antigen-presenting proteins on risk of chronic beryllium disease. J R Soc Interface 5(24):749–758. 10.1098/rsif.2007.1223.17956852
Sood A. 2009. Current treatment of chronic beryllium disease. J Occup Environ Hyg 6(12):762–765. 10.1080/15459620903158698.19894178
Sparling DW, Lowe TP. 1996. Metal concentrations of tadpoles in experimental ponds. Environ Pollut 91(2):149–159. 10.1016/0269-7491(95)00057-7.15091435
Sprince NL, Kanarek DJ, Weber AL, . 1978. Reversible respiratory disease in beryllium workers. Am Rev Respir Dis 117(6):1011–1017. 10.1164/arrd.1978.117.6.1011.666100
Stange AW, Furman FJ, Hilmas DE. 1996a. Rocky Flats beryllium health surveillance. Environ Health Perspect 104(Suppl 5):981–986. 10.1289/ehp.96104s5981.8933045
Stange AW, Hilmas DE, Furman FJ. 1996b. Possible health risks from low level exposure to beryllium. Toxicology 111(1–3):213–224. 10.1016/0300-483x(96)03378-1.8711738
Stange AW, Furman FJ, Hilmas DE. 2004. The beryllium lymphocyte proliferation test: Relevant issues in beryllium health surveillance. Am J Ind Med 46(5):453–462. 10.1002/ajim.20082.15490468
Stange AW, Hilmas DE, Furman FJ, . 2001. Beryllium sensitization and chronic beryllium disease at a former nuclear weapons facility. Appl Occup Environ Hyg 16(3):405–417.11297055
Stanton ML, Henneberger PK, Kent MS, . 2006. Sensitization and chronic beryllium disease among workers in copper-beryllium distribution centers. J Occup Environ Med 48(2):204–211.16474270
Stark M, Lerman Y, Kapel A, . 2014. Biological exposure metrics of beryllium-exposed dental technicians. Arch Environ Occup Health 69(2):89–99. 10.1080/19338244.2012.744736.24205960
Steenland K, Ward E. 1991. Lung cancer incidence among patients with beryllium disease: a cohort mortality study. J Natl Cancer Inst 83(19):1380–1385. 10.1093/jnci/83.19.1380.1920480
Stefaniak AB, Virji MA, Day GA. 2010. Release of beryllium from beryllium-containing materials in artificial skin surface film liquids. Ann Work Expo Health 55(1):57–69. 10.1093/annhyg/meq057.
Stefaniak AB, Virji MA, Day GA. 2012. Release of beryllium into artificial airway epithelial lining fluid. Arch Environ Occup Health 67(4):219–228. 10.1080/19338244.2011.619218.23074979
Stephan CH, Fournier M, Brousseau P, . 2008. Graphite furnace atomic absorption spectrometry as a routine method for the quantification of beryllium in blood and serum. Chem Cent J 2:14. 10.1186/1752-153x-2-14.18597692
Sterner JH, Eisenbud M. 1951. Epidemiology of beryllium intoxication. AMA Arch Ind Hyg Occup Med 4(2):123–151.14856439
Stiefel T, Schulze K, Zorn H, . 1980. Toxicokinetic and toxicodynamic studies of beryllium. Arch Toxicol 45(2):81–92. 10.1007/bf01270905.6162434
Stoeckle JD, Hardy HL, Weber AL. 1969. Chronic beryllium disease. Long-term follow-up of sixty cases and selective review of the literature. Am J Med 46(4):545–561. 10.1016/0002-9343(69)90074-6.4892951
Stokes RF, Rossman MD. 1991. Blood cell proliferation response to beryllium: analysis by receiveroperating characteristics. J Occup Med 33(1):23–28. 10.1097/00043764-199101000-00009.1995798
Stokinger HE, Sprague GF, Hall RH, . 1950. Acute inhalation toxicity of beryllium; four definitive studies of beryllium sulfate at exposure concentrations of 100, 50, 10, and 1 mg. per cubic meter. Arch Ind Hyg Occup Med 1(4):379–397.15433488
Strupp C. 2011a. Beryllium metal. I. Experimental results on acute oral toxicity, local skin and eye effects, and genotoxicity. Ann Occup Hyg 55(1):30–42. 10.1093/annhyg/meq071.21196457
Strupp C. 2011b. Beryllium metal. II. A review of the available toxicity data. Ann Occup Hyg 55(1):43–56. 10.1093/annhyg/meq073.21196456
Stubbs J, Argyris E, Lee CW, . 1996. Genetic markers in beryllium hypersensitivity. Chest 109(3 Suppl):45S. 10.1378/chest.109.3_supplement.45s.
Sutton M, Bibby RK, Eppich GR, . 2012. Evaluation of historical beryllium abundance in soils, airborne particulates and facilities at Lawrence Livermore National Laboratory. Sci Total Environ 437:373–383. 10.1016/j.scitotenv.2012.08.011.22960112
Svilar M, Schuster G, Civic T, . 2013. Beryllium and beryllium compounds. In: Ullmann’s encyclopedia of industrial chemistry. Weinheim, Germany: Wiley-VCH, 1–35. 10.1002/14356007.a04_011.pub3.
Tai Y, De Long R, Goodkind RJ, . 1992. Leaching of nickel, chromium, and beryllium ions from base metal alloy in an artificial oral environment. J Prosthet Dent 68(4):692–697. 10.1016/0022-3913(92)90388-q.1403951
Taiwo OA, Slade MD, Cantley LF, . 2008. Beryllium sensitization in aluminum smelter workers. J Occup Environ Med 50(2):157–162. 10.1097/JOM.0b013e318161783f.18301172
Taiwo OA, Slade MD, Cantley LF, . 2010. Prevalence of beryllium sensitization among aluminium smelter workers. Occup Med 60(7):569–571. 10.1093/occmed/kqq097.
Talluri MV, Guiggiani V. 1967. Action of beryllium ions on primary cultures of swine cells. Caryologia 20(4):355–367. 10.1080/00087114.1967.10796274.
Taylor TP, Ding M, Ehler DS, . 2003. Beryllium in the environment: a review. J Environ Sci Health A Tox Hazard Subst Environ Eng 38(2):439–469. 10.1081/ESE-120016906.12638707
Taylor-McCabe KJ, Wang Z, Sauer NN, . 2006. Proteomic analysis of beryllium-induced genotoxicity in an Escherichia coli mutant model system. Proteomics 6(5):1663–1675. 10.1002/pmic.200500190.16447159
Tazoe H, Yamagata T, Obata H, . 2014. Determination of picomolar beryllium levels in seawater with inductively coupled plasma mass spectrometry following silica-gel preconcentration. Anal Chim Acta 852:74–81. 10.1016/j.aca.2014.09.015.25441882
Tepper LB, VanOrdstrand HS. 1972. Beryllium. CRC Crit Rev Toxicol 1(3):235–259. 10.3109/10408447209103366.
Tinkle SS, Schwitters PW, Newman LS. 1996. Cytokine production by bronchoalveolar lavage cells in chronic beryllium disease. Environ Health Perspect 104(5):969–971. 10.1289/ehp.96104s5969.8933043
Tinkle SS, Kittle LA, Schumacher BA, . 1997. Beryllium induces IL-2 and IFN-gamma in berylliosis. J Immunol 158(1):518–526. 10.4049/jimmunol.158.1.518.8977230
Tinkle SS, Antonini JM, Rich BA, . 2003. Skin as a route of exposure and sensitization in chronic beryllium disease. Environ Health Perspect 111(9):1202–1208. 10.1289/ehp.5999.12842774
Togna G, Togna AR, Russo P, . 1997. Toxicological effects of beryllium on platelets and vascular endothelium. Toxicol Appl Pharmacol 144(2):262–267. 10.1006/taap.1997.8127.9194409
Toledo F, Silvestre JF, Cuesta L, . 2011. Contact allergy to beryllium chloride: report of 12 cases. Contact Derm 64(2):104–109. 10.1111/j.1600-0536.2010.01835.x.
Tolle DA, Arthur MF, Van Voris P. 1983. Microcosm/field comparison of trace element uptake in crops grown in fly ash-amended soil. Sci Total Environ 31(3):243–261. 10.1016/0048-9697(83)90079-7.
TRI21. 2022. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: U.S. Environmental Protection Agency. https://enviro.epa.gov/triexplorer/tri_release.chemical. December 16, 2022.
Tso WW, Fung WP. 1981. Mutagenicity of metallic cations. Toxicol Lett 8(1):195–200. 10.1016/0378-4274(81)90100-4.7022752
Tsujii H, Hoshishima K. 1979. [Effect of the administration of trace amounts of metals to pregnant mice upon the behavior and learning of their offspring]. Shinshu Daigaku Nogakubu Kiyo 16:13–28. (Japanese)
Ulitzur S, Barak M. 1988. Detection of genotoxicity of metallic compounds by the bacterial bioluminescence test. J Biolumin Chemilumin 2(2):95–99. 10.1002/bio.1170020206.3213595
UNSCEAR. 2000. Annex B. Exposures from natural radiation sources. Sources and effects of ionizing radiation. United Nations Scientific Committee on the Effects of Atomic Radiation, 114. https://www.unscear.org/docs/publications/2000/UNSCEAR_2000_Annex-B.pdf. December 23, 2022.
USGS. 1961. Beryllium content of American Coals. Washington, DC: U.S. Geological Survey. U.S. Geological Survey Bulletin 1084-K. https://pubs.usgs.gov/bul/1084k/report.pdf. December 15, 2022.
USGS. 1984. Element concentration in soils and other materials of the conterminous United States. U.S. Geological Survey. Professional Paper 1270. https://pubs.usgs.gov/pp/1270/. December 15, 2022.
USGS. 1998. Coal combustion products. Mineral yearbook: Volume I. Metals and minerals. U.S. Geological Survey. S1–S19.
USGS. 2009. Occurrence and distribution of iron, manganese, and selected trace elements in ground water in the glacial aquifer system of the northern United States. U.S. Geological Survey. Scientific Investigation Report 2009-5006. 10.3133/sir20095006.
USGS. 2011. Trace elements and radon in groundwater across the United States, 1992-2003. U.S. Geological Survey. Scientific Investigations Report 2011–5059. 10.3133/sir20115059.
USGS. 2015. Water quality in principal aquifers of the United States, 1991-2010. Reston, VA: U.S. Geological Survey. Circular 1360. 10.3133/cir1360.
USGS. 2016. National geochemical database: Soil. U.S. Geological Survey. https://mrdata.usgs.gov/ngdb/soil/. November 29, 2022.
USGS. 2017. Chapter E of critical mineral resources of the United States: Economic and environmental geology and prospects for future supply. Reston, Virginia: U.S. Geological Survey. Professional Paper 1802-E. 10.3133/pp1802E.
USGS. 2019. Mineral commodity summaries 2019. Reston, VA: U.S. Geological Survey. 10.3133/70202434.
USGS. 2020. 2017 Minerals yearbook. Beryllium [advance release]. U.S. Geological Survey. https://www.usgs.gov/centers/nmic/beryllium-statistics-and-information. December 15, 2022.
USGS. 2022. Mineral commodity summaries 2022. Reston, VA: U.S. Geological Survey. 10.3133/mcs2022.
Vaessen HA, Szteke B. 2000. Beryllium in food and drinking water-a summary of available knowledge. Food Addit Contam 17(2):149–159. 10.1080/026520300283504.10793846
Valberg PA, Drivas PJ, McCarthy S, . 1996. Evaluating the health impacts of incinerator emissions. J Hazard Mater 47(1):205–227. 10.1016/0304-3894(96)82225-4.
Van Dyke MV, Martyny JW, Mroz MM, . 2011a. Exposure and genetics increase risk of beryllium sensitisation and chronic beryllium disease in the nuclear weapons industry. Occup Environ Med 68(11):842–848. 10.1136/oem.2010.064220.21460389
Van Dyke MV, Martyny JW, Mroz MM, . 2011b. Risk of chronic beryllium disease by HLA-DPB1 E69 genotype and beryllium exposure in nuclear workers. Am J Respir Crit Care Med 183(12):1680–1688. 10.1164/rccm.201002-0254OC.21471109
VanOrdstrand HS, Hughes R, DeNardi JM, . 1945. Beryllium poisoning. J Am Med Assoc 129:1084–1090. 10.1001/jama.1945.02860500016005.21004768
Venugopal B, Luckey TD. 1978. Beryllium. In: Metal toxicity in mammals. 2: Chemical toxicity of metals and metalloids. New York, NY: Plenum Press, 43–50.
Verma DK, Ritchie AC, Shaw ML. 2003. Measurement of beryllium in lung tissue of a chronic beryllium disease case and cases with sarcoidosis. Occup Med 53(3):223–227. 10.1093/occmed/kqg042.
Viet SM, Torma-Krajewski J, Rogers J. 2000. Chronic beryllium disease and beryllium sensitization at Rocky Flats: a case-control study. AIHAJ 61(2):244–254. 10.1080/15298660008984533.10782196
Vorwald AJ, Reeves AL. 1959. Pathologic changes induced by beryllium compounds; experimental studies. AMA Arch Ind Health 19(2):190–199.13616742
Wade MF, Collins MK, Richards D, . 2018. TLR9 and IL-1R1 promote mobilization of pulmonary dendritic cells during beryllium sensitization. J Immunol 201(8):2232–2243. 10.4049/jimmunol.1800303.30185516
Wagner WD, Groth DH, Holtz JL, . 1969. Comparative chronic inhalation toxicity of beryllium ores, bertrandite and beryl, with production of pulmonary tumors by beryl. Toxicol Appl Pharmacol 15(1):10–29. 10.1016/0041-008X(69)90127-6.4307951
Wagoner JK, Infante PF, Bayliss DL. 1980. Beryllium: an etiologic agent in the induction of lung cancer, nonneoplastic respiratory disease, and heart disease among industrially exposed workers. Environ Res 21(1):15–34. 10.1016/0013-9351(80)90004-3.6771133
Wang HC, Peng HW, Kuo MS. 2001. Determination of beryllium and selenium in human urine and of selenium in human serum by graphite-furnace atomic absorption spectrophotometry. Anal Sci 17(4):527–532. 10.2116/analsci.17.527.11990571
Wang Z, White PS, Petrovic M, . 1999. Differential susceptibilities to chronic beryllium disease contributed by different Glu69 HLA-DPB1 and -DPA1 alleles. J Immunol 163(3):1647–1653. 10.4049/jimmunol.163.3.1647.10415070
Ward E, Okun A, Ruder A, . 1992. A mortality study of workers at seven beryllium processing plants. Am J Ind Med 22(6):885–904. 10.1002/ajim.4700220610.1463033
Watanabe K, Shia S, Taccaceae S, . 1985. [Biotoxicity and beryllium distribution in organs by oral administration of beryllium compounds for long periods. II. Experimental study on oral administration of beryllium compounds]. Rodo Kagaku 61:235–246. (Japanese)
Wegner R, Heinrich-Ramm R, Nowak D, . 2000. Lung function, biological monitoring, and biological effect monitoring of gemstone cutters exposed to beryls. Occup Environ Med 57(2):133–139. 10.1136/oem.57.2.133.10711282
Welch L, Ringen K, Bingham E, . 2004. Screening for beryllium disease among construction trade workers at Department of Energy nuclear sites. Am J Ind Med 46(3):207–218. 10.1002/ajim.20059.15307119
Welch LS, Ringen K, Dement J, . 2013. Beryllium disease among construction trade workers at Department of Energy nuclear sites. Am J Ind Med 56(10):1125–1136. 10.1002/ajim.22202.23794247
Weston A. 2011. Work-related lung diseases. IARC Sci Publ 163:387–405.
Weston A, Ensey J, Kreiss K, . 2002. Racial differences in prevalence of a supratypic HLA-genetic marker immaterial to pre-employment testing for susceptibility to chronic beryllium disease. Am J Ind Med 41(6):457–465. 10.1002/ajim.10072.12173370
White MR, Finkel AJ, Schubert J. 1951. Protection against experimental beryllium poisoning by aurin tricarboxylic acid. J Pharmacol Exp Ther 102(2):88–93.14841591
WHO. 2001. Concise international chemical assessment document 32. Beryllium and beryllium compounds. Geneva, Switzerland: World Health Organization. https://apps.who.int/iris/bitstream/handle/10665/42369/9241530324.pdf?sequence=1&isAllowed=y. December 15, 2022.
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. April 25, 2012.
WHO. 2022. Guidelines for drinking-water quality. Fourth edition incorporating the first and second addenda. World Health Organization. https://www.who.int/publications/i/item/9789240045064. June 22, 2022.
Widyaningsih V, Rosenman K, Reilly MJ, . 2020. Lack of an exposure response and interaction with HLA-DPβ1 and DRβ1 polymorphisms in the development of beryllium toxicity in a high beryllium exposure cohort. J Occup Environ Med 62(1):64–73. 10.1097/jom.0000000000001766.31743304
Williams WR, Williams WJ. 1982. Comparison of lymphocyte transformation and macrophage migration inhibition tests in the detection of beryllium hypersensitivity. J Clin Pathol 35(6):684–687. 10.1136/jcp.35.6.684.7085919
Williams WJ, Williams WR. 1983. Value of beryllium lymphocyte transformation tests in chronic beryllium disease and in potentially exposed workers. Thorax 38(1):41–44. 10.1136/thx.38.1.41.6845261
Williams WJ, Kelland D. 1986. New aid for diagnosing chronic beryllium disease (CBD): laser ion mass analysis (LIMA). J Clin Pathol 39(8):900–901. 10.1136/jcp.39.8.900.3745481
Williams GM, Mori H, McQueen CA. 1989. Structure-activity relationships in the rat hepatocyte DNA-repair test for 300 chemicals. Mutat Res 221(3):263–286. 10.1016/0165-1110(89)90039-0.2682231
Williams WJ, Williams WR, Kelland D, . 1988. Beryllium skin disease. In: Grassi C, Rizzato G, Pozzi E., eds. Sarcoidosis and other granulomatous disorders. Proceedings from the 11th World Conference on Sarcoidosis, Milan 1987. Elsevier Science Publishers B.V., 689–690.
Witschi HP. 1970. Effects of beryllium on deoxyribonucleic acid-synthesizing enzymes in regenerating rat liver. Biochem J 120(3):623–634. 10.1042/bj1200623.5499975
Witschi HP, Aldridge WN. 1968. Uptake, distribution and binding of beryllium to organelles of the rat liver cell. Biochem J 106(4):811–820. 10.1042/bj1060811.5637364
Wolnik KA, Fricke FL, Gaston CM. 1984. Quality assurance in the elemental analysis of foods by inductively coupled plasma spectroscopy. Spectrochim Acta B 39(5):649–655. 10.1016/0584-8547(84)80151-2.
WQP. 2022. Water quality portal data: Beryllium. National Water Quality Monitoring Council. https://www.waterqualitydata.us/portal/. November 10, 2022.
Xiao-Quan S, Zheng Y, Zhe-Ming N. 1989. Determination of beryllium in urine by graphite-furnace atomic absorption spectrometry. Anal Chim Acta 217:271–280. 10.1016/S0003-2670(00)80409-2.
Yamamoto A, Kohyama Y, Hanawa T. 2002. Mutagenicity evaluation of forty-one metal salts by the umu test. J Biomed Mater Res 59(1):176–183. 10.1002/jbm.1231.11745551
Yang IV, Konigsberg I, MacPhail K, . 2019. DNA methylation changes in lung immune cells are associated with granulomatous lung disease. Am J Respir Cell Mol Biol 60(1):96–105. 10.1165/rcmb.2018-0177OC.30141971
Yoshifuku A, Kawai K, Saruwatari H, . 2012. Active sensitization to beryllium by diagnostic patch tests. J Dermatol 39(12):1084–1085. 10.1111/j.1346-8138.2012.01610.x.22758206
You CF, Lee T, Li YH. 1989. The partition of Be between soil and water. Chem Geol 77(2):105–118. 10.1016/0009-2541(89)90136-8.
Zakour RA, Glickman BW. 1984. Metal-induced mutagenesis in the lacI gene of Escherichia coli. Mutat Res Fundam Mol Mech Mutagen 126(1):9–18. 10.1016/0027-5107(84)90164-7.
Zhihong C, Yezhen L, Zhiyuan G, . 2011. Comparison of the cytogenotoxicity induced by five different dental alloys using four in vitro assays. Dent Mater J 30(6):861–868. 10.4012/dmj.2011-127.22123010
Zissu D, Binet S, Cavelier C. 1996. Patch testing with beryllium alloy samples in guinea pigs. Contact Derm 34(3):196–200. 10.1111/j.1600-0536.1996.tb02173.x.
Zorn H, Stiefel T, Porcher H. 1986. Clinical and analytical follow-up of 25 persons exposed accidentally to beryllium. Toxicol Environ Chem 12(3–4):163–171. 10.1080/02772248609357156.