# VERSION HISTORY

Date | Description
September 2023 | Final toxicological profile released
January 2022 | Draft for public comment toxicological profile released
June 2015 | Addendum to the toxicological profile released
September 2002 | Final toxicological profile released
April 1993 | Final toxicological profile released
December 1988 | Final toxicological profile released