# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding beryllium in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for beryllium.

Table 7-1 Regulations and Guidelines Applicable to Beryllium

Agency | Description | Information | Reference
Air
EPA | RfC: beryllium and compounds | 2x10^-5^ mg/m^3^ (5x10^-5^ ppm) | IRIS 2002
WHO | Air quality guidelines | No data | WHO 2010
Water & Food
EPA | Drinking water standards and health advisories | | EPA 2018a
EPA | 1-Day health advisory (10-kg child) | 30 mg/L | EPA 2018a
EPA | 10-Day health advisory (10-kg child) | 30 mg/L | EPA 2018a
EPA | DWEL | 0.07 mg/L | EPA 2018a
EPA | Lifetime health advisory | No data | EPA 2018a
EPA | National primary drinking water regulations | | EPA 2009
EPA | MCL | 0.004 mg/L | EPA 2009
EPA | MCLG | 0.004 mg/L | EPA 2009
EPA | RfD: beryllium and compounds | 2x10^-3^ mg/kg/day | IRIS 2002
WHO | Drinking water quality guidelines | Not established | WHO 2022
FDA | Allowable level in bottled water | 0.004 mg/L | FDA 2017
FDA | Substances added to food (formerly EAFUS) | Not listed | FDA 2022b
Cancer
HHS | Carcinogenicity classification: beryllium and beryllium compounds | Known to be human carcinogens | NTP 2021
EPA | Carcinogenicity classification: beryllium and compounds | B1^a,b^ | IRIS 2002
EPA | Air unit risk | 2.4x10^-3^ per µg/m^3^ ^c^ | IRIS 2002
IARC | Carcinogenicity classification: beryllium and beryllium compounds | Group 1^d^ | IARC 2012
Occupational
OSHA | PEL (8-hour TWA) for general industry, shipyards, and construction | 0.2 µg/m³ | OSHA 2021a, 2021b, 2021c
OSHA | STEL (15 minutes) | 2 µg/m³ | OSHA 2021a, 2021b, 2021c
NIOSH | REL (up to 10-hour TWA): beryllium and beryllium compounds (as Be) | 0.0005 mg/m^3^ ^e^ | NIOSH 2007b
NIOSH | IDLH: beryllium compounds (as Be) | 4 mg/m^3^ ^e^ | NIOSH 2007b
Emergency Criteria
EPA | AEGLs-air | No data | EPA 2018b
DOE | PACs-air | | DOE 2018a
DOE | Beryllium | | DOE 2018a
DOE | PAC-1^f^ | 0.0023 mg/m^3^ | DOE 2018a
DOE | PAC-2^f^ | 0.025 mg/m^3^ | DOE 2018a
DOE | PAC-3^f^ | 0.1 mg/m^3^ | DOE 2018a
DOE | Beryllium chloride | | DOE 2018a
DOE | PAC-1^f^ | 0.02 mg/m^3^ | DOE 2018a
DOE | PAC-2^f^ | 0.22 mg/m^3^ | DOE 2018a
DOE | PAC-3^f^ | 0.89 mg/m^3^ | DOE 2018a
DOE | Beryllium fluoride | | DOE 2018a
DOE | PAC-1^f^ | 0.012 mg/m^3^ | DOE 2018a
DOE | PAC-2^f^ | 0.13 mg/m^3^ | DOE 2018a
DOE | PAC-3^f^ | 0.52 mg/m^3^ | DOE 2018a
DOE | Beryllium hydroxide | | DOE 2018a
DOE | PAC-1^f^ | 0.011 mg/m^3^ | DOE 2018a
DOE | PAC-2^f^ | 0.12 mg/m^3^ | DOE 2018a
DOE | PAC-3^f^ | 0.48 mg/m^3^ | DOE 2018a
DOE | Beryllium nitrate | | DOE 2018a
DOE | PAC-1^f^ | 0.047 mg/m^3^ | DOE 2018a
DOE | PAC-2^f^ | 0.52 mg/m^3^ | DOE 2018a
DOE | PAC-3^f^ | 2.1 mg/m^3^ | DOE 2018a
DOE | Beryllium oxide | | DOE 2018a
DOE | PAC-1^f^ | 0.0063 mg/m^3^ | DOE 2018a
DOE | PAC-2^f^ | 0.069 mg/m^3^ | DOE 2018a
DOE | PAC-3^f^ | 0.28 mg/m^3^ | DOE 2018a

a B1: probable human carcinogen.

b The following classifications using the 1996 Proposed Guidelines for Carcinogen Risk assessment (EPA 1996) are also given: inhaled beryllium, a likely carcinogen in humans; ingested beryllium, the human carcinogenic potential cannot be determined.

c The unit risk should not be used if the air concentration exceeds 4 µg/m^3^, since above this concentration the unit risk may not be appropriate.

d Group 1: carcinogenic to humans.

e Potential occupational carcinogen.

f Definitions of PAC terminology are available from DOE (2018b).

AEGL = acute exposure guideline level; DOE = Department of Energy; DWEL = drinking water equivalent level; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; MCL = maximum contaminant level; MCLG = maximum contaminant level goal; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; STEL = short-term exposure limit; TWA = time-weighted average; WHO = World Health Organization