# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Beryllium is a naturally occurring element found in earth’s rocks at levels of 1–15 mg/kg. It appears in Group IIA of the periodic table and the most common oxidation state is Be(+2), although an oxidation state of (0) has been observed in certain compounds. Because of its high reactivity, beryllium is not found as the free metal in nature. There are approximately 45 mineralized forms of beryllium. The important beryllium minerals in the world are beryl (3BeOAl2O36SiO2) and bertrandite (Be4Si2O7(OH)2). Beryl has been known since ancient times as the gemstones: emerald (green), aquamarine (light blue), and beryl (yellow). Beryllium, like other metals, can form organometallic complexes. Table 4-1 lists common synonyms, trade names, and other pertinent identification information for beryllium and its compounds.

Table 4-1 Chemical Identity of Beryllium and Beryllium Compounds^a^

Characteristic | Beryllium | Beryllium chloride | Beryllium fluoride
Synonym(s) and registered trade name(s) | Beryllium-9; glucinium; glucinum; beryllium metallic | Beryllium dichloride | Beryllium difluoride
Chemical formula | Be | BeCl_2_ | BeF_2_
CAS Registry Number | 7440-41-7 | 7787-47-5 | 7787-49-7
Characteristic | Beryllium hydroxide | Beryllium oxide | Beryllium phosphate (3H_2_O)
Synonym(s) and registered trade name(s) | Beryllium hydrate; beryllium dihydroxide | Beryllia; beryllium monoxide; Thermalox 995 | Beryllium orthophosphate
Chemical formula | Be(OH_2_) | BeO | Be_3_(PO_4_)_2_^−^3H2O
CAS Registry Number | 13327-32-7 | 13044-56-9 | 35089-00-0^b^
Characteristic | Beryllium nitrate | Beryllium sulfate | Beryllium carbonate (basic)
Synonym(s) and registered trade name(s) | Nitric acid, beryllium salt | Sulfuric acid, beryllium salt | Basic beryllium carbonate; bis[carbonato(2-)]dihydroxy triberyllium
Chemical formula | Be(NO_3_)_2_ | BeSO_4_ | Be_3_(OH)_2_(CO_3_)_2_^c^
CAS Registry Number | 13597-99-4 (anhydrous); 7787-55-5 (trihydrate); 13510-48-0 (tetrahydrate) | 13510-49-1 (anhydrous); 7787-56-6 (tetrahydrate) | 66104-24-3^b^

a All information from NLM (2023a, 2023b, 2023c, 2023d, 2023e, 2023f, 2023g, 2023h, 2023i) except where noted.

b EPA 2019

c Lide 2005

CAS = Chemical Abstracts Service

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Beryllium is a solid at room temperature and atmospheric pressure. It is part of the metal family and consistent with the high charge-to-radius ratio, beryllium has a strong tendency to form compounds via covalent bonds, even compounds with the most electronegative elements (e.g., BeF_2_). Its properties are characterized as stiffer than steel and lighter than aluminum; these make it attractive for aerospace and military parts and beryllium alloy applications such as in aircrafts and cell phones. No data are available on the vapor pressure of beryllium or its compounds as it is too low to be measured. Although beryllium belongs to Group IIA of the periodic table, it is chemically very similar to aluminum, which also has a high charge-to-radius ratio. Like aluminum, the hydroxide of beryllium can act as either a base or acid (Cotton and Wilkinson 1980; EPA 1978, 1998). The interaction of cosmic-ray particles in the atmosphere produces a number of radionuclides including beryllium-7 (Be-7) and beryllium-10 (Be-10). The radioactive half-life of Be-7 is 53.29 days, and the radioactive half-life of Be-10 is 1.51x10^6^ years (UNSCEAR 2000). Table 4-2 lists important physical and chemical properties of beryllium and its compounds.

Table 4-2 Physical and Chemical Properties of Beryllium and Beryllium Compounds^a^

Property | Beryllium metal | Beryllium chloride | Beryllium fluoride | Beryllium hydroxide | Beryllium oxide
Molecular weight | 9.012 | 79.918 | 47.01 | 43.027 | 25.011
Color | Gray | White-yellow | White | White | White
Physical state | Solid; hexagonal crystals^b^ | Orthorhombic crystals or needles | Glassy hygroscopic mass | Powder | Amorphous powder or hexagonal crystals
Melting point | 1,287°C | 415°C | 555°C | 138°C (decomposes) | 2,578°C
Boiling point | 2,468°C | 482°C | 1,283°C | Not applicable | 3,787°C
Density | 1.85 g/cm^3^ ^b^ | 1.90 g/cm^3^ | 2.1 g/cm^3^ | 1.92 g/cm^3^ | 3.01 g/cm^3^
Taste | No data | Sweet^b^ | No data | No data | No data
Odor | Odorless | Sharp, acrid^b^ | Odorless | None | Odorless
Odor threshold: | Not applicable | No data | Not applicable | Not applicable | Not applicable
Solubility:
Water | Insoluble | 71.5 g/100 mL water at 25°C | Very soluble | Very slightly soluble | 2 µg/100 mL
Organic solvent(s) | No data | Soluble in ethanol, ethyl ether, pyridine | Slightly soluble in ethanol, more soluble in mixture of alcohol and ether | No data | No data
Inorganic solvent(s) | Soluble in acid and alkaline solutions^b^ | No data | No data | Soluble in hot concentrated acid and alkali | Soluble in concentrated acids
Partition coefficients:
Log K_ow_ | No data | No data | No data | No data | No data
Log K_oc_ | No data | No data | No data | No data | No data
Vapor pressure at 20°C | No data | No data | No data | No data | No data
Henry’s law constant at 25°C | No data | No data | No data | No data | No data
Degradation half-life in air via reaction with OH radicals | No data | No data | No data | No data | No data
Dissociation constants:
pK_a,1_ | No data | No data | No data | No data | No data
pK_a,2_ | No data | No data | No data | No data | No data
Autoignition temperature | No data | No data | No data | No data | No data
Flashpoint | No data | No data | No data | No data | No data
Flammability limits in air | No data | No data | No data | No data | No data
Conversion factors^b^ | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable
Explosive limits | No data | No data | No data | No data | No data
Property | Beryllium phosphate | Beryllium nitrate | Beryllium carbonate (basic) | Beryllium sulfate | Beryllium sulfate (tetrahydrate)
Molecular weight | 104.991 | 133.02 | 181.069^c^ | 105.07 | 177.13
Color | White | White | White-yellow^c^ | Colorless | Colorless
Physical state | Solid | Crystals | Powder^c^ | Tetragonal crystals | Tetragonal crystals
Melting point | 100°C (decomposes) | 60°C | No data | 550–600°C (decomposes) | 100°C (loses 2H_2_O); 400°C (loses 4H_2_O)
Boiling point | No data | 142°C (decomposes) | No data | No data | No data
Density | No data | 1.557 g/cm^3^ | No data | 2.443 g/cm^3^ | 1.713 g/cm^3^
Taste | No data | No data | No data | No data | No data
Odor | None | None | None | None | None
Odor threshold | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable
Solubility:
Water | Slightly soluble | Soluble | Insoluble (cold); Decomposes (hot) | Insoluble | 41.3 g/ 100 mL^c^
Organic solvent(s) | Soluble in acetic acid | Soluble in alcohol | No data | No data | No data
Inorganic solvent(s) | No data | No data | Acid, alkali | No data | No data
Partition coefficients:
Log K_ow_ | No data | No data | No data | No data | No data
Log K_oc_ | No data | No data | No data | No data | No data
Vapor pressure at 20°C | No data | No data | No data | No data | No data
Henry’s law constant at 25°C | No data | No data | No data | No data | No data
Degradation half-life in air via reaction with OH radicals | No data | No data | No data | No data | No data
Dissociation constants:
pK_a,1_ | No data | No data | No data | No data | No data
pK_a,2_ | No data | No data | No data | No data | No data
Autoignition temperature | No data | No data | No data | No data | No data
Flashpoint | No data | No data | No data | No data | No data
Flammability limits in air | No data | No data | No data | No data | No data
Conversion factors^b^ | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable
Explosive limits | No data | No data | No data | No data | No data

a All information from NLM (2023a, 2023b, 2023c, 2023d, 2023e, 2023f, 2023g, 2023h, 2023i) except where noted.

b These compounds do not exist in the atmosphere in the vapor phase; therefore, an air conversion factor is not applicable.

c Lide 2005.