# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S106-5, Atlanta, Georgia 30329-4027.

## Beryllium and compounds Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Beryllium and compounds
CAS Numbers: | 7440-41-7
Date: | September 2023
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL.

Rationale for Not Deriving an MRL: The animal studies identify SLOAELs, which are not suitable for deriving MRLs; the lowest LOAEL was 0.184 mg/m^3^ (Schepers 1964). This was a SLOAEL, as two of three of the monkeys died at this dose.

Agency Contacts (Chemical Managers): Rae T. Benedict, Ph.D.

## Beryllium and compounds Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Beryllium and compounds
CAS Numbers: | 7440-41-7
Date: | September 2023
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL.

Rationale for Not Deriving an MRL: Derivation of an intermediate-duration inhalation MRL is precluded because there are no human intermediate-duration studies. The lowest LOAEL is a SLOAEL for metaplasia and granulomas of lung at 0.035 mg/m^3^ (Schepers et al. 1957) in rats. Less serious LOAELs identified in Muller et al. (2011) are not suitable for setting an MRL since each study only tested one concentration level and none had identified a NOAEL for any of the endpoints examined, including respiratory and immunological, thus making it inappropriate to derive an MRL from animal data.

Agency Contacts (Chemical Managers): Rae T. Benedict, Ph.D.

## Beryllium and compounds Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Beryllium and compounds
CAS Numbers: | 7440-41-7
Date: | September 2023
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic
MRL: | 0.001 μg beryllium/m^3^
Critical Effect: | Immunological beryllium sensitization
Reference: | Schuler et al. 2012
Point of Departure: | LOAEL of 0.04 μg/m^3^
Uncertainty Factor: | 30
LSE Graph Key: | 22
Species: | Human

MRL Summary: A chronic-duration inhalation MRL of 0.001 µg beryllium/m^3^ was derived for beryllium based on evidence of immunological beryllium sensitization in humans following occupational exposures to beryllium for up to 6 years (Schuler et al. 2012). The MRL is based on a LOAEL of 0.04 µg/m^3^ for beryllium sensitization and a total uncertainty factor of 30 (10 for use of a LOAEL and 3 for human variability due to subpopulation of genetically susceptible workers).

Selection of the Critical Effect: The long-term studies that evaluated inhalation exposure to beryllium are primarily occupational epidemiology studies (Table A-1). Madl et al. (2007) examined exposure-response relationships for beryllium sensitization and CBD in workers exposed to beryllium. Results showed that within a given year of their work history, beryllium-sensitized and CBD workers were exposed to beryllium concentrations >0.2 μg/m^3^ (95^th^ percentile). Two earlier studies, Cullen et al. (1987) and Kreiss et al. (1996), also observed health effects (beryllium sensitization) at 1.2 and 0.55 μg/m^3^. These studies are not included in the LSE tables as the exposure measurements are not sufficient for inclusion (they are summarized in Chapter 2). Schuler et al. (2012) evaluated exposure-response relationships for beryllium sensitization and CBD in workers with ≤6 years of beryllium exposure. The study authors reported no cases of beryllium sensitization among workers with average respirable concentrations of <0.04 µg/m^3^ and observed cases of CBD among workers with respirable cumulative concentrations of <0.33 µg/m^3^-year. Sensitization prevalence was 9.8% and CBD prevalence was 2.3%.

Beryllium sensitization is a cell-mediated immune response triggered by exposure to beryllium. Whether an individual will become sensitized to beryllium is dependent on several factors including beryllium form, amount and duration of exposure, and genetic susceptibility. Beryllium production workers have the highest rates of beryllium sensitization, with rates ranging from 7 to 19% (Bailey et al. 2010; Donovan et al. 2007; Henneberger et al. 2001; Kreiss et al. 1996, 1997; Newman et al. 2001; Rosenman et al. 2005; Schuler et al. 2005, 2008, 2012). Although beryllium sensitization does not cause any physical impairment, it is considered an adverse health effect. ATSDR considers beryllium sensitization to be an adverse health effect because it indicates susceptibility to CBD. Longitudinal studies of beryllium workers have demonstrated that 8.8–31% of workers will progress from beryllium sensitization to CBD (Mroz et al. 2009; Newman et al. 2005).

Selection of the Principal Study: Schuler et al. (2012) is chosen as the principal study and beryllium sensitization is the critical effect. The selection was made because Schuler et al. (2012) established the lowest LOAEL (at 0.04 µg/m^3^) that did not cause a SLOAEL and the study measured respirable air concentrations, which are important for deposition of beryllium into the lungs through breathing.

Table A-1 Summary of Relevant Human LOAEL Values Considered for Derivation of a Chronic Inhalation MRL for Beryllium

Exposure duration | LOAEL (µg/m^3^) | Effect^a^ | Reference/chemical form
Respiratory
Occupational, average 17.6 years | 0.2^b^ | CBD diagnosed (95^th^ percentile of exposure concentration, among beryllium sensitization and CBD workers) | Madl et al. 2007/beryllium metal
Occupational, average 12.6 years | 1.2^b^ | Breathing difficulties, scarring of the lung | Cullen et al. 1987/beryllium alloy
Occupational, average 12.6 years | 0.52^b^ | CBD | Cullen et al. 1987/beryllium alloy
Occupational, NS | 0.2^b,c^ | Beryllium sensitization and CBD diagnosed (median concentration among beryllium sensitization and CBD) | Kreiss et al. 1996/beryllium oxide
Occupational, ≤6 years (median 1.75 years) | 0.17^b^ | CBD case observed with average exposure concentration | Schuler et al. 2012/beryllium metal, oxide, and beryllium-copper alloy
Immunotoxicity
Occupational average, 17.6 years | 0.4 | Beryllium sensitization diagnosed (95^th^ percentile of exposure concentration, among beryllium sensitization and CBD workers) | Madl et al. 2007/beryllium metal
Occupational average, 12.6 years | 0.52 | Increased T cell activity | Cullen et al. 1987/beryllium alloy
Occupational, ≤6 years (median 1.75 years) | 0.04 | Beryllium sensitization case observed with average exposure | Schuler et al. 2012/beryllium metal, oxide, and beryllium-copper alloy

a Unless otherwise noted, effects were observed at average exposure levels.

b Denotes a SLOAEL.

c Denotes exposure converted into beryllium fraction by applying a ratio conversion factor (i.e., beryllium oxide is comprised 36.03% of beryllium and multiplied by exposure).

Highlighted row indicates the principal study used for the MRL.

CBD = chronic beryllium disease; LOAEL = lowest-observed-adverse-effect level; NS = not specified; SLOAEL = serious lowest-observed-adverse-effect level

Summary of the Principal Study:

Schuler CR, Virji MA, Deubner DC, . 2012. Sensitization and chronic beryllium disease at a primary manufacturing facility, part 3: exposure-response among short-term workers. Scand J Work Environ Health 38(3):270–281.21877099

The study population consisted of workers who were employed in 1999. The study population was limited to those workers who were not employed at the facility before January 1993 and had no known previous work beryllium exposure. The participation rate was almost 91% with 264 out of 291 eligible. Workers completed a work history questionnaire and were evaluated for beryllium sensitization and CBD. Individual estimates of average, cumulative, and highest job exposures for total, respirable, and submicron beryllium mass concentrations were developed from the work history of each participant where:

- Average exposure (µg/m^3^) = TWA annual exposure of all jobs in the employee’s work history.
- Cumulative exposure (μg/m^3^/year) = exposure levels for each job worked, multiplied by number of years at that job, summed over all jobs in the work history.
- Highest job exposure (µg/m^3^) = exposure level for each participant’s single job with the highest mean exposure.

Of the 264 participants, 26 were diagnosed with beryllium sensitization and 6 of those with CBD. Individuals were considered sensitized if they had ≥2 abnormal BeLPTs during the 1999 survey, or if they had abnormal test results in the pre-1999 testing. An increase in sensitization prevalence was reported as exposure quartile increased. For average respirable beryllium, the quartiles included (<0.06, 0.06–0.42, 0.43–1.02, and 1.03–3.56 µg/m^3^. Among the quartiles, based on a Cochran-Armitage test for trend (exact), the p-value was <0.05 for total mass of beryllium and between 0.05 and 0.1 for respirable beryllium. Beryllium sensitization was observed when respirable beryllium concentrations were 0.04 µg/m^3^ for average and highest job categories.

Selection of the Point of Departure for the MRL: The chronic-duration inhalation MRL for beryllium was calculated using the reported LOAEL of 0.04 µg/m^3^.

Calculations

Intermittent Exposure: Not applicable.

Human Equivalent Concentration: Not applicable.

Uncertainty Factor: The NOAEL was divided by 30:

- 10 for use of a LOAEL
- 3 for human variability as study included sensitive population of genetically susceptible workers that could develop beryllium sensitization and CBD.

MRL = LOAEL ÷ UFs = 0.04 μg/m^3^ ÷ ( 10 × 3 ) = 0.001 μg/m^3^ ( 0.000001 mg/m^3^ )

Other Additional Studies or Pertinent Information that Lend Support to this MRL: A case-control study and community study support the MRL. Confirming the LOAEL value of 0.04 µg/m^3^, Viet et al. (2000) assessed exposure-response relationships in a case-control study of workers at the Rocky Flats nuclear production facility. Beryllium sensitization cases were classified if two BeLPT results were positive, either by two consecutive draws or two different lab analyses of the same draw. Beryllium sensitization cases were observed at 0.036 µg beryllium/m^3^, with CBD occurring at mean exposure levels of 0.07 µg/m^3^. Furthermore, the derived MRL of 0.001 µg/m^3^, a value likely to be without appreciable risk of adverse health effects, is below the concentrations found to have an effect in a community study by Maier et al. (2008). Maier et al. (2008) studied a community that lived near a beryllium manufacturing facility. This study found that beryllium exposures were 0.0155–0.028 µg/m^3^ based on ambient air sampling in 1958, with some exposures potentially >0.35 μg/m^3^. CBD was found in residents around the plant (within 1.5 miles) who were not workers at the plant or family members of workers (Maier et al. 2008).

Agency Contacts (Chemical Managers): Rae T. Benedict, Ph.D.

## Beryllium and compounds Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Beryllium and compounds
CAS Numbers: | 7440-41-7
Date: | September 2023
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL.

Rationale for Not Deriving an MRL: The available data on the acute-duration toxicity of ingested beryllium are from lethality studies in rats and mice, and several older studies lacked control groups (these are not presented in the LSE table). Ashby et al. (1990) identified a SLOAEL (death) at 140 mg/kg/day. El-Beshbishy et al. (2012) identified less serious LOAELs at 9.8 mg/kg/day at several endpoints; however, since this study only tested one dose level and identified no NOAELs, these endpoints are not suitable for deriving an acute-duration oral MRL.

Agency Contacts (Chemical Managers): Rae T. Benedict, Ph.D.

## Beryllium and compounds Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Beryllium and compounds
CAS Numbers: | 7440-41-7
Date: | September 2023
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration oral MRL.

Rationale for Not Deriving an MRL: The available data from intermediate-duration studies have identified several effects including hematological (hypoplasia of bone marrow), gastrointestinal, and musculoskeletal (rickets) endpoints as targets of beryllium toxicity (Guyatt et al. 1933; Jacobson 1933; Kay and Skill 1934; Morgareidge et al. 1976). In a chronic-duration dog study (Morgareidge et al. 1976), extensive ulcerative and inflammatory lesions were observed in the gastrointestinal tract after exposure to 12 mg beryllium/kg/day for males and 17 mg beryllium/kg/day for females for 26–33 weeks. Other effects observed at this dose level included hypoplasia of the bone marrow and deaths (2/10). Because deaths were observed at the same dose as the hematological and gastrointestinal findings, it is not possible to derive an MRL based on that dose. The gastrointestinal effects have never been substantiated. The musculoskeletal effect of rickets is not considered a direct effect from beryllium exposure. Rather, the rickets are due to a phosphorus deficiency, which is hypothesized to result from the precipitation of beryllium with dietary phosphorus in the acidic environment of the digestive tract (Kay and Skill 1934). Additionally, these effects have only been observed following exposure to beryllium carbonate.

Agency Contacts (Chemical Managers): Rae T. Benedict, Ph.D.

## Beryllium and compounds Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Beryllium and compounds
CAS Numbers: | 7440-41-7
Date: | September 2023
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL.

Rationale for Not Deriving an MRL: No adverse effects were observed in rats exposed to 31 mg/kg/day beryllium sulfate tetrahydrate in the diet (Morgareidge et al. 1975). Schroeder and Mitchener (1975a, 1975b) exposed rats (females 0.7 and males 0.6 mg/kg/day) and mice (1 mg/kg/day) to beryllium sulfate in drinking water without observing significant adverse effects. Morgareidge et al. (1976) conducted a chronic-duration dog feeding study in which groups of five male and five female dogs were exposed to beryllium sulfate tetrahydrate in the diet for 143–172 weeks. The highest dose group (500 ppm or 12 mg beryllium/kg/day for males and 17 mg beryllium/kg/day for females) was discontinued between 26 and 33 weeks due to high morbidity and mortality, resulting in an intermediate-duration exposure rather than a chronic-duration exposure for this portion of the study. Findings for the highest dose group have been categorized in the profile as intermediate- instead of chronic-duration exposure effects. Of the remaining dose groups, ulcerative lesions were observed in 1 of 10 dogs exposed to 50 ppm (1 mg beryllium/kg/day). No gastrointestinal effects were observed at the lower dose levels. After a portion of the study was re-categorized as intermediate due to the early deaths, there was no longer a statistically significant health effect nor a clear dose-response relationship for the chronic-duration portion of the Morgareidge et al. (1976) study. Therefore, it is not suitable for developing a chronic-duration oral MRL.

Agency Contacts (Chemical Managers): Rae T. Benedict, Ph.D.