# 9 REFERENCES

* Cited in text

ACGIH. 1992. Threshold limit values for chemical substances in the work environment. American Conference of Governmental Industrial Hygienists. Cincinnati, OH.
*ACGIH. 1998. Documentation of the threshold limit values for chemical substances and physical agents. 6^th^ ed. American Conference of Governmental Industrial Hygienists. Cincinnati, OH.
*ACGIH. 2000. Threshold limit values for chemical substances and physical agents and biological exposure indices. American Conference of Governmental Industrial Hygienists. Cincinnati, OH.
*Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27:532–537.4029526
*Adler O. 1908. [Die wirkung und das Schicksal des Benzidins im tierkorper.] (Partial translation) Arch Exp Pathol Pharmakol 58:167–197. (German)
*Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect suppl 103:103–112.
Albrecht W, Neumann HG. 1984. Covalent binding of benzidine to rat hemoglobin [Abstract]. Naunyn Schmiedebergs Arch Pharmacol 325:R21.
*Aldrich FD. 1993. Written communication (June 4) to Sharon Madar, Life Systems, Inc., regarding technical flaws in an IBM-sponsored dermal absorption study to two azo dyes (International Business Machines 1979). Consultant, IBM Center for Process and Product Toxicology.
*Aldrich. 1998. Catalog handbook of fine chemicals. Milwaukee, WI: Aldrich Chemical Company, Inc., 435.
*Aldrich FD, Busby WF, Fox JG. 1986. Excretion of radioactivity from rats and rabbits following cutaneous application of two 14C-labeled azo dyes. J Toxicol Environ Health 18:347–355.3712495
Althouse R, Huff J, Tomatis L, 1979. Chemicals and industrial processes associated with cancer in humans. IARC Monographs on the evaluation of the carcinogenic risk of chemicals to humans. 1:20–25.
*Pl Altman, Dittmer DS, eds. 1974. In: Biological handbooks: Biology data book. Vol. III, 2^nd^ ed. Bethesda, MD: Federation of American Societies for Experimental Biology, 1987–2008.
*Ames BN, Durston WE, Yamasaki E, 1973. Carcinogens are mutagens: A simple test system combining liver homogenates for activation and bacteria for detection. Proc Natl Acad Sci USA 70(8):2281–2285.4151811
Amlacher VE, Rudolph C. 1983. Spezifisch hemmung der nuklearen DNS-synthese durch karzinogene. Acta Histochem 27(Suppl):55–162.
Andersen ME, ed. 1991. Quantitative risk assessment and chemical carcinogens in occupational environments. In: Carcinogenically active chemicals: A reference guide. New York, NY: Van Nostrand Reinhold, 17–28.
*Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives. New York, NY: Marcel Dekker, Inc., 9–25.
*Andersen ME, Clewell HJ, Gargas ML, 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87:85–205.
*Anderson D, Styles JA. 1978. Appendix II: The bacterial mutation test. Br J Cancer 37:924–930.354673
Anderson KE, Hammons GJ, Kadlubar FF, 1997. Metabolic activation of aromatic amines by human pancreas. Carcinogenesis 18:1085–1092.9163700
*Anonymous. 1999. Cambridge software chemfinder database. Http://www.chemfinder.com/ (http://Http://www.chemfinder.com/). August 8, 1999.
*Anthony HM, Thomas GM. 1970. Tumors of the urinary bladder: An analysis of the occupations of 1030 patients in Leeds, England. J Natl Cancer Inst 45:879–895.18605414
*APHA. 1992. 6410B. Liquid-liquid extraction gas chromatographic/mass spectrometric method. 18th ed. In: Greenberg A, Clesceri L, Eaton A, Eds. Standard methods for the elimination of water and wastewater. Washington, DC: American Public Health Association.
*Araki S, Tanigawa T, Ishizu S, 1993. Decrease of CD4-positive T lymphocytes in workers exposed to benzidine and beta-naphthylamine. Arch Environ Health 48(4):205–208.8102843
Arlett CF, Cole J. 1990. The third United Kingdom environmental mutagen society collaborative trial: Overview, a summary and assessment. Mutagenesis 5:85–88.2184327
*Ashby J, Mohammed R. 1988. UDS activity in the rat liver of the human carcinogens benzidine and 4-aminobiphenyl, and the rodent carcinogens 3,3'-dichlorobenzidine and direct black 38. Mutagenesis 3(1):69–71 3282145
*Ashby J, Lefevre PA, Elcombe CR. 1990. Cell replication and unscheduled DNA synthesis (UDS) activity of low molecular weight chlorinated paraffins in the rat liver in vivo. Mutagenesis 5(5):515–518.2263209
*Ashby J, Styles JA, Paton D. 1978. In vitro evaluation of some derivatives of the carcinogen butter yellow: Implications for environmental screening. Br J Cancer 38:34–50.99159
ATSDR. 1989. Agency for Toxic Substances and Disease Registry. Part V. Federal Register 54:37619–37633.
*ATSDR. 1994. Public health assessment for Nyanza Chemical Waste Dump Ashland, Middlesex County, Massachusetts, Region 1: CERCLIS No. MAD990685422. Atlanta, GA: Agency for Toxic Substances and Disease Registry. PB94–194446.
*ATSDR. 1999. TOPKAT 3.0 toxicity assessment report. Prepared by Health Designs, Inc. for the Agency for Toxic Substances and Disease Registry, Atlanta, GA.
Autrup H. 1988. Metabolic activation of chemical carcinogens in animal and human tissues: DNA binding. Ann NY Acad Sci 534: 89–94.3291731
*Babu SR, Lakshmi VM, Hsu FF, 1992. Role of N-glucuronidation in benzidine-induced bladder cancer in dog. Carcinogenesis 13(7):1235–1240.1638692
*Babu ST, Lakshmi VM, Hsu FF, 1993a. N-acetylbenzidine-N'-glucuronidation by human, dog and rat liver. Carcinogenesis 14(12):2605–2611.8269633
*Babu SR, Lakshmi VM, Hsu FF, 1995. Glucuronidation of N-hydroxy metabolites of N-acetylbenzidine. Carcinogenesis 16(12):3069–3074.8603487
Babu SR, Lakshmi VM, Huang GP W, 1996. Glucuronide conjugates of 4-aminobiphenyl and its N-hydroxy metabolites. Biochem Pharmacol 51:1679–1685.8687483
*Babu SR, Lakshmi VM, Owens IS, 1994a. Human liver glucuronidation of benzidine. Carcinogenesis 15(9):2003–2007.7923596
*Babu SR, Lakshmi VM, Zenser TV, 1994b. Glucuronidation of N-acetylbenzidine by human liver. Drug Metab Dispos 22(6):922–927.7895611
Babu SR, Wongsurawat VJ, Zenser TV, 1993b. Benzidine glucuronidation in dog liver. Carcinogenesis 14:893–897.8389254
*Baer RL. 1945. Benzidine as cause of occupational dermatitis in a physician. J Am Med Assoc 129:442–443.
*Baird R, Carmona L, Jenkins RL. 1977. Behavior of benzidine and other aromatic amines in aerobic wastewater treatment. J Water Pollut Control Fed 49:1609–1615.
Baker RK. 1953. The carcinogenic activity of dihydroxybenzidine, further investigations. Cancer Res 13:137.13042798
*Banerjee S, Sikka H, Gray R, 1978. Photodegradation of 3,3'-dichlorobenzidine. Environ Sci Toxicol 12(13):1425–1427.
*Barfknecht TR, Mecca DJ, Naismith RW. 1988. Effect of varying the exposure and 3H-thymidine labeling period upon the outcome of the primary hepatocyte DNA repair assay. Cell Biol Toxicol 4(2):199–209.3233531
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
Baxter PJ. 1989. Editorial: Occupational bladder cancer and the hospital clinician. Br J Ind Med 46:73.2923827
*Baynes RE, Brownie C, Freeman H, 1996. In vitro percutaneous absorption of benzidine in complex mechanistically defined chemical mixtures. Toxicol Appl Pharmacol 141:497–506.8975774
Beal DD, ed. 1990. Use of mouse liver tumor data in risk assessments performed by the U.S. Environmental Protection Agency. In: Mouse liver carcinogenesis: Mechanisms and species comparisons: Proceedings of the symposium held in Austin, Texas, November 30-December 3, 1988. New York, NY: Butterworths, 5–18.
Beland FA, Kadlubar FF. 1985. Formation and persistence of arylamine DNA adducts in vivo. Environ Health Perspect 62:19–30.4085422
*Beland FA, Beranek DT, Dooley KL, 1983. Arylamine-DNA adducts in vitro and in vivo: Their role in bacterial mutagenesis and urinary bladder carcinogenesis. Environ Health Perspect 49:125–134.6339219
*Bell DA, Taylor JA, Paulson DF, 1993. Genetic risk and carcinogen exposure: A common inherited defect of the carcinogen-metabolism gene glutathione S-transferase M1 (GSTM1) that increases susceptibility to bladder cancer. J Natl Cancer Inst 85(14):1159–1164.8320745
Bender AP, Parker DL, Johnson RA, 1989. Minnesota highway maintenance worker study: Cancer mortality. Am J Ind Med 15:545–556.2741960
Benigni R. 1992. Rational approach to the quantification of genotoxicity. Environ Mol Mutagen 19:83–89.1732108
Benigni R, Andreoli C, Giuliani A. 1989. Interrelationships among carcinogenicity, mutagenicity, acute toxicity, and chemical structure in a genotoxicity data base. J Toxicol Environ Health 27:1–20.2724362
Berenblum I, Bonser GM. 1937. Experimental investigation of "aniline cancer". J Ind Hyg Toxicol 19:86–91.
*Berger GS, ed. 1994. Epidemiology of endometriosis. In: Endometriosis: Advanced management and surgical techniques. New York, NY: Springer-Verlag.
*Betowski LD, Pyle SM, Ballard JM, 1987. Thermospray LC/MS/MS analysis of wastewater for disperse azo dyes. Biomed Environ Mass Spectrom 14:343–354.2959343
Bhardwaj SK, Jagota SK. 1993. Effect of age on susceptibility of carcinogen benzidine-hydrochloride. Indian J Exp Biol 31:299–300.8500849
*Bi W, Hayes RB, Feng P, 1992. Mortality and incidence of bladder cancer in benzidine-exposed workers in China. Am J Ind Med 21:481–489.1580253
Bilbo AJ, Wyman GM. 1953. Steric hindrance to coplanarity in o-fluorobenzidines. J Am Chem Soc 75:5312–5314.
*Birner G, Albrecht W, Neumann H-G. 1990. Biomonitoring of aromatic amines. III: Hemoglobin binding of benzidine and some benzidine congeners. Arch Toxicol 64:97–102.2350241
*Blum M, Demierre A, Grant DM, 1991. Molecular mechanism of slow acetylation of drugs and carcinogens in humans. Proc Natl Acad Sci 88:5237–5241.1675794
Bochner B. 1993. Written communication (February 10, 1993) to BF Neustadter, Life Systems, Inc. regarding the current manufacture and use of benzidine and benzidine-based dyes by the U.S. dye manufacturing industry. Fabricolor Manufacturing Corporation, Paterson, NJ.
Bolanowska W, Sapota A, Mogilnicka E. 1972. Evaluation of the present exposure to benzidine. Medycyna Pracy 23:129–138.
Bolognesi C, Cesarone CF, Santi L. 1981. Evaluation of DNA damage by alkaline elution technique after in vivo treatment with aromatic amines. Carcinogenesis 2:265–268.7273312
*Bonser GM. 1959. Test for carcinogenic aromatic amines. Ann Rep Br Emp Canc Campaign 37:417–21.
*Bos RP, Brouns RM E, Van Doorn R, 1980. The appearance of mutagens in urine of rats after the administration of benzidine and some other aromatic amines. Toxicology 16:113–122.7414612
*Bos RP, Brouns RM E, Van Doorn R, 1981. Involvement of non-oxidative enzymes in mutagenic activation of urine from rats, given benzidine and some other aromatic amines. Toxicology 21:223–233.7027539
*Bos RP, Neis JM, Van Gemert PJ L, 1983. Mutagenicity testing with the Salmonella/hepatocyte and the Salmonella/microsome assays: A comparative study with some known genotoxic compounds. Mutat Res 124:103–112.6358883
*Bos RP, Van Der Krieken W, Smeijsters L, 1986. Internal exposure of rats to benzidine derived from orally administered benzidine-based dyes after intestinal azo reduction. Toxicology 40:207–213.3726894
Bower EA, Kaji H. 1986. Characterization of human IMR-90 fibroblasts as a model system for the study of chemical carcinogenesis in vitro. J Toxicol Environ Health 19:165–172.3093686
*Boyd SA, Kao C-W, Suflita JM. 1984. Fate of 3,3'-dichlorobenzidine in soil: Persistence and binding. Environ Toxicol Chem 3:201–208.
*Brockmoller J, Cascorbi I, Kerb R, 1996. Combined analysis of inherited polymorphisms in arylamine N-acetyltransferase 2, glutathione S-transferases M1 and T1, microsomal epoxide hydrolase, and cytochrome P450 enzymes as modulators of bladder cancer risk. Cancer Res 56:3915–3925.8752158
*Bronstein AC, Currance PL, eds. 1988. Emergency care for hazardous materials exposure. St. Louis, MO: The C.V. Mosby Company 189–190.
*Brouns RE, Poot M, deVrind R, 1979. Measurement of DNA-excision repair in suspensions of freshly isolated rat hepatocytes after exposure to some carcinogenic compounds: Its possible use in carcinogenicity screening. Mutat Res 64:425–432.392315
*Brouns RM E, Bos RP, Van Doorn R, 1982. Studies on the metabolic activation of benzidine by isolated rat hepatocytes. Toxicology 23:235–247.7112596
*Brown SL. 1988. Differential susceptibility: Implications for epidemiology, risk assessment, and public policy. Basic Life Sci 43:255–269.3365222
*Brumley WC, Brownrigg CM. 1994. Application of MEKC in the determination of benzidines following extraction from water, soil, sediment, and chromatographic adsorbents. J Chromatogr Sci 32:69–75.
*Buchholz SE, Omer CA, Viitanen PV, 1992. Activation and detection of (pro)mutagenic chemicals using recombinant strains of Streptomyces griseus. Appl Biochem Biotechnol 32:149–158.1416947
*Budavari S, O’Neil MJ, Smith A, Eds. 1996. The Merck index: An encyclopedia of chemicals, drugs, and biologicals 12th ed. Rathway, NJ: Merk & Co., Inc., 180.
*Budnick LD, Sokal DC, Falk H, 1984. Cancer and birth defects near the Drake Superfund site, Pennsylvania. Arch Environ Health 39(6):409–413.6524960
*Bulbulyan MA, Figgs LW, Zahm SH, 1995. Cancer incidence and mortality among beta-naphthylamine and benzidine dye workers in Moscow. Int J Epidemiol 24(2):266–275.7635585
*Butler MA, Iwasaki M, Guengerich FP, 1989. Human cytochrome P-450_PA_(P-450IA2), the phenacetin O-deethylase, is primarily responsible for hepatic 3-demethylation of caffeine and N-oxidation of carcinogenic arylamines. Proc Natl Acad Sci 86:7696–7700.2813353
Calvet R. 1989. Adsorption of organic chemicals in soils. Environ Health Perspect 83:145–177.2695323
*Cartwright RA. 1983. Historical and modern epidemiological studies on populations exposed to N-substituted aryl compounds. Environ Health Perspect 49:13–19.6339220
Cartwright RA. 1990. Bladder cancer screening in the United Kingdom. J Occup Med 32:878–880.2074512
Cartwright RA, Glashan RW. 1984. The epidemiology and management of occupational bladder cancer. In: Smith PH, Prout GR, eds. Butterworth's international medical reviews: Urology. Volume 1. Bladder Cancer. Boston, MA: Butterworths and Co. Ltd., 125–150.
*Cartwright RA, Glashan RW, Rogers HJ, 1982. Role of N-acetyltransferase phenotypes in bladder carcinogenesis: A pharmacogenetic epidemiological approach to bladder cancer. Lancet 16:842–845.
Case RA M, Hosker ME, McDonald DB, 1993. Tumours of the urinary bladder in workmen engaged in the manufacture and use of certain dyestuff intermediates in the British chemical industry. Br J Ind Med 50:389–411.8507592
*CDC. 1999. Centers for Disease Control and Prevention. Http://search.cdc.gov/shd/search2.html (http://Http://search.cdc.gov/shd/search2.html).
*CDC/ATSDR. 1990. Biomarkers of organ damage or dysfunction for the renal, hepatobiliary and immune systems. Atlanta GA: CDC/ATSDR Subcommittee on Biomarkers of Organ Damage and Dysfunction, Centers for Disease Control, Agency for Toxic Substances and Disease Registry. Summary report, August 27, 1990.
*Cerniglia CE, Freeman JP, Franklin W, 1982. Metabolism of benzidine-congener based dyes by human, monkey and rat intestinal bacteria. Biochem Biophys Res Comm 107(4):1224–1229.6814437
CFR. 1990. Code of Federal Regulations. Washington DC: Office of the Federal Register, National Archives and Records Administration, 516–536.
Chacko M, Gupta RC. 1986. Identification of aromatic carcinogen-DNA adducts by pH-dependent partitioning and P-adduct assay. Proc Am Assoc Cancer Res 27:107.
Chapta SC, Boyer JM. 1990. Fate of pollutants: Modeling, observations, and general studies. Hazardous Wastes 4:569–577.
Chen SC. 1997. Studies of the mutagenicity and toxicity of benzidine, P-phenylenediamine, and their analogues (azo dyes, aromatic amines). Diss Abstr Int B 59–01B:62.
*Chipman JK, Mohn GR. 1989. Host-mediated bacterial mutagenesis and enterohepatic circulation of benzidine-derived mutagenic metabolites in rodents. Xenobiotica 19(1):43–50.2667260
Chung KT, Cerniglia CE. 1992. Mutagenicity of azo dyes: Structure-activity relationships. Mutat Res 227:201–220.
*Chung KT, Chen SC, Wong TY, 2000. Mutagenicity studies of benzidine and its analogs: Structure-activity relationships. Toxicol Sci 56:351–356.10910993
*Cihak R. 1979. Evaluation of benzidine in the micronucleus test. Mutat Res 67:383–384.384240
Cikryt P, Josephy PD. 1989. Binding of chlorinated benzidines to the rat hepatic aromatic hydrocarbon receptor. Chem Biol Interact 72:57–64.2555073
Ciotti M, Lakshmi VM, Basu N, 1999. Glucuronidation of benzidine and its metabolites by cDNA-expressed human UDP-glucuronosyltransferases and pH stability of glucuronides. Carcinogenesis 20(10):1963–1969.10506112
*Clay P, Cross MF. 1990. Microwell mutation assays: Evaluation of ethylmethanesulphonate, benzo[a]pyrene and benzidine using the tk locus in L5178Y mouse lymphoma cells. Mutagenesis 5:45–54.
Clayson DB. 1981. Specific aromatic amines as occupational bladder carcinogens. Monograph no. 58. Washington DC: National Cancer Institute, 15–19.
*Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Clongero E, Venicr P, Granella M, 1990. Mutagenic and carcinogenic risks of leather azo dyes. Med Lav 81:222–229.2277597
CLPSD. 1988. Contract laboratory program statistical database. Viar and Company. Alexandria, VA. August 10.
Cohen SM. 1963. Urinary bladder carcinogenesis with N-substituted aryl compounds: Initiation and promotion. Monograph no. 58. Washington, DC: Department of Health and Human Services, National Cancer Institute. 63–66.
Copeland-Haines D, Eustis SL, eds. 1990. Specialized sebaceous glands. In: Pathology of the Fischer rat: Reference and atlas. San Diego, CA: Academic Press, 279–293.
Cortesi E, Saffiotti U, Donovan PJ, 1983. Dose-response studies on neoplastic transformation of BALB/3T3 Clone A31–1-1 cells by aflatoxin B, benzidine, benzo-(a)-pyrene, 3-methylcholanthrene, and N-methly-N-nitro-N-nitrosoguanidine. Teratog Carcinog Mutagen 3:101–110.6133364
Costantini AS, Paci E, Miligi L, 1989. Cancer mortality among workers in the Tuscan tanning industry. Br J Ind Med 45:384–388.
Crespi CL, Gonzalez FJ, Steimel DT, 1991. A metabolically competent human cell line expressing five cDNAs encoding procarcinogen-activating enzymes: Application to mutagenicity testing. Chem Res Toxicol 4:566–572.1793807
*Crosby JH, Allsbrook WC Jr, Koss LG, 1991. Cytologic detection of urothelial cancer and other abnormalities in a cohort of workers exposed to aromatic amines. Acta Cytologica 35(3):263–268.2042428
Crump K. 1989. Correlation of carcinogenic potency in animals and humans. Cell Biol Toxicol 4:393–403.
Crump K, Allen B, Shipp A. 1989. Choice of dose measure for extrapolating carcinogenic risk from animals to humans: An empirical investigation of 23 chemicals. Health Phys 57:387–393.2606698
Dai QH, Zheng QY, Wang ZY. 1991. Quantitative explanation on structure-carcinogenic activity relationship of aromatic amines by di-region theory. Sci in China 5:547–559.
*Daly AK, Thomas DJ, Cooper J, 1993. Homozygous deletion of gene for glutathione S-transferase M1 in bladder cancer. Br Med J 307:481–482.8400932
*Das L, Das SK, Hooberman BH, 1994. Chromosomal aberrations in mouse lymphocytes exposed in vitro and in vivo to benzidine and 5 related aromatic amines. Mutat Res 320:69–74.7506388
Debnath AK, Debnath G, Shusterman AJ, 1992. A QSAR investigation of the role of hydrophobicity in regulating mutagenicity in the Ames test: 1 mutagenicity of aromatic and heteroaromatic amines in Salmonella typhimurium TA98 and TA100. Environ Mol Mutagen 19:37–52.1732103
Decarli A, Peto J, Piolatto G, 1985. Bladder cancer mortality of workers exposed to aromatic amines: Analysis of models of carcinogenesis. Br J Cancer 51:707–712.3994914
*Delzell E, Macaluso M, Cole P. 1989. A follow-up study of workers at a dye and resin manufacturing plant. J Occup Med 31(3):273–278.2918413
*DeMarini DM, Brooks LR, Bhatnagar VK, 1997. Urinary mutagenicity as a biomarker in workers exposed to benzidine: Correlation with urinary metabolites and urothelial DNA adducts. Carcinogenesis 18(5):981–988.9163684
*DePass LR, Morris MD. 1981. Feedback control of cholesterol biosynthesis in rats fed the liver carcinogens benzidine and 2-acetylaminoflourene. Cancer Biochem Biophys 5:91–95.7248921
*DePass LR, Morris MD. 1982. Feedback control of cholesterol biosynthesis in mice fed the liver carcinogens benzidine and 2-acetylamino-fluorene. Cancer Biochem Biophys 6:47–51.7093937
*Dewan A, Jani JP, Patel JS, 1988. Benzidine and its acetylated metabolites in the urine of workers exposed to Direct Black 38. Arch Environ Health 43(4):269–272.3415352
*DHHS. 1991. Sixth annual report on carcinogens: Summary. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Services, National Toxicology Program.
Doctor SV. 1980. A study of the conversion of selected aromatic amines to mutagens by porcine hepatocyte microsomal fraction and nuclei. Diss Abstr Int 41:1746B.
Dolara P, Mazzoli S, Rosi D, 1981. Exposure to carcinogenic chemicals and smoking increases urinary excretion of mutagens in humans. J Toxicol Environ Health 8:95–103.7328717
Dolin PJ. 1992. A descriptive study of occupation and bladder cancer in England and Wales. Br J Cancer 65:476–478.1558806
*Dorado G, Pueyo C. 1988. L-Arabinose resistance test with Salmonella typhimurium as a primary tool for carcinogen screening. Cancer Res 48:907–912.3276401
*DOT. 1972. Reclassification of materials listed as transportation health hazards: Final Report. Washington, DC: Department of Transportation. Report no. TSA-20–72-3. PB214270.
DOT. 1976. Department of Transportation. Code of Federal Regulations. 49 CFR 172.101.
*DOT. 2001. List of hazardous substances and reportable quantities. U.S. Department of Transportation. Code of Federal Regulations. 49 CFR 172.101, Appendix A. Http://www.dot.gov/safety.html (http://Http://www.dot.gov/safety.html). May 02, 2001.
Dunnick JK, Morgan DL, Jokinen MP. 1991. Toxicology and carcinogenesis studies in benzidine congeners and derived dyes in F344/N rats [Abstract]. Proc Am Assoc Cancer Res 32:84.
*Duverger-Van Bogaert M, Dierickx PJ, Crutzen M-C. 1995. Mutagenic activation of aromatic amines by a human hepatoma cell (Hep G2) supernatant tested by means of Salmonella typhimurium strains with different acetyltransferase activities. Mutat Res 335:219–227.8524336
El Gazzar RM, Abdel Hamid HA, Shamy MY. 1994. Biological monitoring of occupational exposure to electrophilic compounds. J Environ Pathol Toxicol Oncol 13:19–23.7529835
Eling TE, Petry TW, Hughes MF, 1988. Aromatic amine metabolism catalyzed by prostaglandin H synthase. In: King CM, Romano JL, Schuetzle D, eds. Carcinogenic and mutagenic responses to aromatic amines and nitroamines. New York, NY: Elsevier Science Publishing Company, 161–172.
Eling TE, Thompson DC, Foureman GL, 1990. Prostaglandin H synthase and xenobiotic oxidation. Annu Rev Pharmacol Toxicol 30:1–45.2111654
*Englebertz P, Babel E. 1953. Nachweis von Benzidin und seinen Umwandlungsprodukten im harn und in Organteilen. Zentralblatt fur Arbeitsmedizin und Arbeitsschutz. 3:161–168.13137486
EPA. 1973a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 136.3.
EPA. 1973b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 136 Methods 1625, 605.
*EPA. 1976a. Persistence and degradability testing of benzidine and other carcinogenic compounds. Washington, DC: U.S. Environmental Protection Agency. EPA-560/5–7-005.
*EPA. 1976b. Preliminary scoring of selected organic air pollutants. Appendix I. Chemistry, production and toxicity of chemicals A-C. Research Triangle Park, NC. U.S. Environmental Protection Agency, Office of Air and Waste Management. EPA-450/3–77-008b.
EPA. 1977a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 129.4.
EPA. 1977b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 129.104.
EPA. 1977c. Review of the environmental fate of selected chemicals. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. EPA-560/5–77-003.
EPA. 1978a. In-depth studies on health and environmental impacts of selected water pollutants. Contract no. 68–01-4646. Washington, DC: U.S. Environmental Protection Agency.
*EPA. 1978b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 122 Appendix D.
*EPA. 1978c. Reviews of the environmental effects of pollutants. II. Benzidine. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development. EPA 600/1–78-024.
EPA. 1979a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 401.15.
*EPA. 1979b. TSCA chemical assessment series, preliminary risk assessment, phase I: Benzidine, its congeners and their derivatives dyes and pigments. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. EPA-560/11–8-019.
*EPA. 1979c. Water-related environmental fate of 129 priority pollutants: Volume II: Halogenated aliphatic hydrocarbons, halogenated ethers, monocyclic aromatics, phthalate esters, polycyclic aromatic hydrocarbons, nitrosamines, and miscellaneous compounds. Washington, DC: U.S. Environmental Protection Agency, Office of Water and Waste Management, Office of Water Planning and Standards. EPA-440/4–79-029b.
*EPA. 1979d. Status assessment of toxic chemicals: Benzidine. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development. EPA-600/2–79-210e. PB8O-146343.
*EPA. 1980a. Ambient Water Quality Criteria for benzidine. Washington, DC: U.S. Environmental Protection Agency, Office of Water Regulations and Standards. EPA-440/5–80-023.
*EPA. 1980b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.33(f).
EPA. 1980c. Guidelines and methodology used in the preparation of health effect assessment chapters of the consent decree water criteria documents. Washington, DC: U.S. Environmental Protection Agency. Federal Register 45:79347–79357.
EPA. 1980d. Sorption properties of sediments and energy-related pollutants. Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development. EPA-600/3–80-041.
EPA. 1980d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261 VIII.
EPA. 1981a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 413.02.
*EPA. 1981b. Aquatic fate process data for organic priority pollutants. Washington, DC: U.S. Environmental Protection Agency, Office of Water Regulations and Standards. EPA-440/4–81-014.
*EPA. 1982a. Benzidines - method 605. In: Methods for organic chemical analysis of municipal and industrial wastewater. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring and Support Laboratory. EPA-600/4–87-057, 605–1 to 605–7.
*EPA. 1982b. Test method: Base/neutrals and acids - method 625. In: Methods for organic chemical analysis of municipal and industrial wastewater. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring and Support Laboratory. EPA-600/4–87-057, 625–1 to 625–19.
EPA. 1982c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 423 Appendix A.
EPA. 1983a. Treatability manual. Volume I. Treatability data. Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development.
EPA. 1983b. Sorption properties of sediments and energy-related pollutants. Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development. EPA-600/2–80-041.
EPA. 1983c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 433.11.
*EPA. 1984. Method 1625: Revision B: Semivolatile organic compounds by isotope dilution GC/MS. Washington, DC: U.S. Environmental Protection Agency, 1625–1 to 1625–44.
EPA. 1985a. U.S. Environmental Protection Agency. Part II. Notification requirements; reportable quantity adjustments; final rule and proposed rule. Federal Register. 50:13456–13522.
EPA. 1985b. Master scheme for the analysis of organic compounds in water. Part I. State-of-the-art review of analytical operations. Athens, GA: U.S. Environmental Protection Agency, Environmental Research Laboratory.
EPA. 1986a. Gas chromatography/mass spectrometry for semivolatile organics: Capillary column technique-method 8270. In: Test methods for evaluating solid wastes. SW-846. 3rd ed. Volume 1B: Laboratory manual. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
EPA. 1986b. Capillary column analysis of semivolatile organic compounds by gas chromatography/fourier transform infrared (GC/FT-IR) spectrometry-method 8410. In: Test methods for evaluating solid wastes SW-846. 3rd ed. Washington DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
*EPA. 1986c. Health and environmental effects profile for benzidine. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Criteria and Assessment Office, Office of Research and Development. EPA600/-x-86/157.
EPA. 1986d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 403 Appendix B.
EPA. 1986e. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.11.
EPA. 1986f. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.42.
EPA. 1987a. Hazardous substances; reportable quantity adjustments; proposed rule. U.S. Environmental Protection Agency. Federal Register. 50:8140.
*EPA. 1987b. Health effects assessment for benzidine. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Criteria and Assessment Office, Office of Health and Environmental Assessment, Office of Research and Development. EPA600/8–88/019.
*EPA. 1987c. Processes, coefficients, and models for simulating toxic organics and heavy metals in surface waters. Athens, GA: U.S. Environmental Protection Agency, Office of Research and Development. EPA-600/3–87-015.
EPA. 1987d. Reference dose (RfD): Description and use in health risk assessments. Volume l, Appendix A: Integrated risk information system supportive documentation. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA/600/8–86/032a.
*EPA. 1988a. Public Health Risk Evaluation Database. Washington, DC: U.S. Environmental Protection Agency, Office of Emergency and Remedial Response.
EPA. 1988b. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency.
EPA. 1988c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65.
EPA. 1988d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 716.120.
EPA. 1989a. Method IP-7. Determination of benzo(a)pyrene [B(a)P] and other polynuclear aromatic hydrocarbons (PAHs) in indoor air. Washington DC: U.S. Environmental Protection Agency.
EPA. 1989b. U.S. Environmental Protection Agency. Part V. Federal Register 54:33451.
EPA. 1990a. Project summary: Compendium of methods for the determination of air pollutants in indoor air. In: Project summary. Research Triangle Park, NC: U.S. Environmental Protection Agency, Atmospheric Research and Exposure Assessment Laboratory. EPA/600/S4–90/010.
*EPA. 1990b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 721.1675.
EPA. 1991. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 266 VII.
EPA. 1993. U.S. Environmental Protection Agency. Federal Register. 58 FR 48092.
*EPA. 1994. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 63.74.
*EPA 1996. Method 8325: Solvent extractable nonvolatile compounds by high performance liquid chromatography/particle beam/mass spectrometry (HPLC/PB/MS). Washington, DC: U.S. Environmental Protection Agency.
*EPA. 1997. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: Environmental Protection Agency, Office of Research and Development. EPA/630/R-96/012.
*EPA. 1998a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.33.
*EPA. 1998b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4.
*EPA. 1998c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 129.104.
*EPA. 1998d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 401.15.
*EPA. 1998e. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 413.02.
*EPA. 1998f. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 433.11.
*EPA. 1998g. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 63.74.
*EPA. 1998h. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65.
*EPA. 1998i. Method 8270D: Semivolatile organic compounds by gas chromatography/mass spectrometry (GC/MS). Washington, DC: U.S. Environmental Protection Agency.
*EPA. 1999a. National recommended water quality criteria-correction. U. S. Environmental Protection Agency, Office of Water. EPA 822-Z-99-001.
*EPA. 1999b. National archives and records administration. Code of Federal Regulations. U.S. Environmental Protection Agency. 40 CFR 302.4.
*EPA. 1999c. National Archives and Records Administration. Code of Federal Regulations. U.S. Environmental Protection Agency. 40 CFR 372.65.
*EPA. 2000a. National Archives and Records Administration. Code of Federal Regulations. U.S. Environmental Protection Agency. 40 CFR 413.02.
*EPA. 2000b. National Archives and Records Administration. Code of Federal Regulations. U.S. Environmental Protection Agency. 40 CFR 433.11.
*EPA. 2000c. National Archives and Records Administration. Code of Federal Regulations. U.S. Environmental Protection Agency. 40 CFR 129.104.
*EPA. 2000d. National Archives and Records Administration. Code of Federal Regulations. U.S. Environmental Protection Agency. 40 CFR 401.15.
*EPA. 2000e. National Archives and Records Administration. Code of Federal Regulations. U.S. Environmental Protection Agency. 40 CFR 261.33.
*EPA. 2001a. Benzidine, hazard summary. U.S. Environmental Protection Agency. Http://www.epa.gov/ttn/uatw/hlthef/benzidin.html (http://Http://www.epa.gov/ttn/uatw/hlthef/benzidin.html).
*EPA. 2001b. Health and environmental protection standards at uranium and thorium mill tailings. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 192, Appendix I. Http://www.access.gpo.gov/nara/cfr/cfrhtml_00/Title_40/40cfrv17_00.html (http://Http://www.access.gpo.gov/nara/cfr/cfrhtml_00/Title_40/40cfrv17_00.html). May 02, 2001.
*EPA. 2001c. Health based limits for exclusion of waste-derived residue. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 266, Appendix VII. [underlined: Wysiwyg://35/]http://www.epa.gov/epacfr40/chapt-I.info/chi-toc.htm. May 02, 2001.
*EPA. 2001d. Identification and listing of hazardous waste. Comparable/Syngas fuel exclusion. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.38. Http://ecfrback.access.gpo.gov/otcgi/cfr/otfilter.cgi...TI&QUERY=51773&RGN=BSECCT&SUBSET=SUBSET&FROM=1&ITEM=1. May 02, 2001.
*EPA. 2001e. National emission standards for HAPs for source categories. Demonstration of early reduction of high risk pollutants. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 63.74. Http://ecfrback.access.gpo.gov/otcg...=BSECCT&SUBSET=SUBSET&FROM=1&ITEM=1. May 02, 2001.
*EPA. 2001f. Risk specific doses. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 266, Appendix V. Http://ecfrback.access.gpo.gov/otcgi/cfr/otfilter.cgi...and&QUERY=9974&RGN=BAPPCT&SUBSET=SUBSET&FROM=1&ITEM=1. May 02, 2001.
*EPA. 2001g. Steam electric power generating point source category. Priority pollutants. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 423, Appendix A. Http:/www.access.gpo.gov/nara/cfr/cfrhtml_00/Title_40/40cfr21_00.html. May 02, 2001.
*EPA. 2001h. Toxic pollutant effluent standards. Regulated toxic pollutants. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 129.4. [underlined: Wysiwyg://114/]http://www.epa.gov/docs/epacfr40/chapt-I.info/subch-D.htm. May 02, 2001.
*EPA. 2001i. Toxic Substances Control Act (TSCA). Health and Safety Data Reporting. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 716.120. Http://ecfrback.access.gpo.gov/otcgi/cfr/otfilter.cgi...I&QUERY=173296&RGN=BSECCT&SUBSET=SUBSET&FROM=1&ITEM=1. May 02, 2001.
*EPA. 2001j. Toxic Substances Control Act (TSCA). Significant new uses of chemical substances. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 721.1660. Http://ecfrback.access.gpo.gov/otcgi/cfr/otfilter.cgi...BTI&QUERY=8791&RGN=BSECCT&SUBSET=SUBSET&FROM=1&ITEM=1. May 02, 2001.
*EPA. 2001k. TSD facilities. Compounds with a Henry’s law constant less than 0.1 Y/K. Regulated toxic pollutants. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 265, Appendix VI. [underlined: Wysiwyg://114/]http://www.epa.gov/docs/epacfr40/chapt-I.info/subch-I.htm. May 02, 2001.
*Fahmy MJ, Fahmy OG. 1977. Mutagenicity of hair dye components relative to the carcinogen benzidine in Drosophila melanogaster. Mutat Res 56:31–38.413033
*Fassina G, Abbondandolo A, Mariani L 1990. Mutagenicity in V79 cells does not correlate with carcinogenicity in small rodents for 12 aromatic amines. J Toxicol Environ Health 29:190–130.
*FDA. 1998a. Food and Drug Administration. Code of Federal Regulations. 21 CFR 74.705.
*FDA. 1998b. Food and Drug Administration. Code of Federal Regulations. 21 CFR 74.706.
*FDA. 2000a. Food and Drug Administration. National Archives and Records Administration. Code of Federal Regulations. 21CFR 74.705.
*FDA. 2000b. Food and Drug Administration. National Archives and Records Administration. Code of Federal Regulations. 21CFR 74.706.
*FEDRIP. 1999. Federal Research in Progress [database]. Dialog Information Retrieval System, CA.
*Ferber KH, Hill WJ, Cobb DA. 1976. An assessment of the effect of improved working conditions on bladder tumor incidence in a benzidine manufacturing facility. Am Ind Hyg Assoc J 37:61–68.1246951
*Ferretti JJ, Lu W, Liu M-B. 1977. Mutagenicity of benzidine and related compounds employed in the detection of hemoglobin. Am J Clin Pathol 67:526–527.326025
Fiserova-Bergerova V, Pierce JT, Droz PO. 1990. Dermal absorption potential of industrial chemicals: Criteria for skin notation. Am J Ind Med 17:617–635.2337085
Fischer AB, Kaw JL, Diemer K, 1998. Low dose effects of fibrous and non-fibrous mineral dusts on the proliferation of mammalian cells in vitro. Toxicol Lett 96,97:97–103.9820653
Fiserova-Bergerova V, Pierce JT, Droz PO. 1990. Dermal absorption potential of industrial chemicals: Criteria for skin notation. Am J Ind Med 17:617–635.2337085
Fishbein L. 1984. Current uses of ambient and biological monitoring: Reference workplace hazards. Organic toxic agents - aromatic amines. II. In: Berlin A, Yodaiken RE, Henman BA, eds. Assessment of toxic agents at the workplace. Roles of ambient and biological monitoring. Amsterdam: Martinus Nijhoff Publishers, 202–207.
*Flammang TJ, Yamazoe Y, Benson RW, 1989. Arachidonic acid-dependent peroxidative activation of carcinogenic arylamines by extrahepatic human tissue microsomes. Cancer Res 49:1977–1982.2495173
*Fluck EP, Poirier LA, Ruelius HW. 1976. Evaluation of a DNA polymerase-deficient mutant of E. coli for the rapid detection of carcinogens. Chem Biol Interact 15:219–231.793736
*Fomon SJ. 1966. Body composition of the infant: Part I: The male “reference infant”. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
*Fomon SJ, Haschke F, Ziegler EE, 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35:1169–1175.7081099
Fourney RM, O'Brien PJ, Davidson WS. 1986. Peroxidase catalyzed aggregation of plasmid pBR322 DNA by benzidine metabolites in vitro. Carcinogenesis 7:1535–1542.3742727
Fouts JR, Kamm JJ, Brodie BB. 1957. Enzymatic reduction of protosil and other azo dyes. J Pharmacol Exp Ther 210:291–300.
*Fox TR. 1990. Mutational analysis of the H-ras oncogene in spontaneous B6C3F1 mouse liver tumors and tumors induced with a genotoxic and nongenotoxic hepatocarcinogens [Abstract]. Diss Abstr Int 51:4189B.
Fox TR, Schumann AM, Watanabe PG, 1990. Mutational analysis of the H-ras oncogene in spontaneous C57BL/6 × C3H/He mouse liver tumors and tumors induced with genotoxic and nongenotoxic hepatocarcinogens. Cancer Res 50:4014–4019.2191770
Frederick CB, Mays JB, Ziegler DM, 1982. Cytochrome P-450- and flavin-containing monooxygenase catalyzed formation of the carcinogen n-hydroxy-2-aminofluorene and its covalent binding to nuclear DNA. Cancer Res 42:2671–2677.7083159
*Frederick CB, Weis CC, Flammang TJ, 1985. Hepatic N-oxidation, acetyl-transfer and DNA-binding of the acetylated metabolites of the carcinogen, benzidine. Carcinogenesis 6(7):959–965.4017176
*Frederickson SM, Hatcher JF, Reznikoff CA, 1992. Acetyl transferase-mediated metabolic activation of N-hydroxy-4-aminobiphenyl by human uroepithelial cells. Carcinogenesis 13(6):955–961.1600616
*Frith CH, Baetcke KP, Nelson CJ, 1979. Importance of mouse liver tumor in carcinogenesis bioassay studies using benzidine dihydrochloride as a model. Toxicol Lett 4:507–518.
*Frith CH, Baetcke KP, Nelson CJ, 1980. Sequential morphogenesis of liver tumors in mice given benzidine dihydrochloride. Eur J Cancer 16:1205–1216.
Frumin E, Velez H, Bingham E, 1990. Occupational bladder cancer in textile dyeing and printing workers: Six cases and their significance for screening programs. J Occup Med 32:887–890.2074514
FSTRAC. 1990. Summary of state and federal drinking water standards and guidelines. Federal-State Toxicology and Regulatory Alliance Committee.
Furihata C, Matsushima T. 1987. Use of in vivo unscheduled DNA synthesis for identification of organspecific carcinogens. Crit Rev Toxicol 17:245–277.3556021
*Garner RC, Walpole AL, Rose FL. 1975. Testing of some benzidine analogues for microsomal activation to bacterial mutagens. Cancer Lett 1:39–42.797441
Garrett NE, Stack HF, Gross MR, 1984. An analysis of the spectra of genetic activity produced by known or suspected human carcinogens. Mutat Res 134:89–111.6504068
*GDNR. 2000. Georgia instream water quality standards for all waters: Toxic substances. Georgia Department of Natural Resources. Http://search.state.ga.us/dnr/query...benzidine&qp=url1%3Awww.ganet.org.
*Genin VA. 1977. Formation of blastogenic diphenylamino derivatives as a result of direct azo dyes. Vopr Onkol 23:50–52.
*Giwercman A, Carlsen E, Keiding N, 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl 101:65–71.
Glashan RW, Wijesinghe DP, Riley A. 1981. The early changes in the development of bladder cancer in patients exposed to known industrial carcinogens. Br J Urol 53:571–577.7317744
*Glowinski IB, Radtke HE, Weber WW. 1978. Genetic variation in N-acetylation of carcinogenic arylamines by human and rabbit liver. Mol Pharmacol 14:940–949.714030
Gold LS, Slone TH, Bernstein L. 1989. Summary of carcinogenic potency and positivity of 492 rodent carcinogens in the carcinogenic potency database. Environ Health Perspect 79:259–272.
Gold LS, Slone TH, Manley NB, 1991. Target organs in chronic bioassays of 533 chemical carcinogens. Environ Health Perspect 93:233–246.1773795
*Goldwater LJ, Rosso AJ, Kleinfeld M. 1965. Bladder tumors in a coal tar dye plant. Arch Environ Health 11:814–817.5846076
*Golka K, Prior V, Blaszkewicz M, 1996. Occupational history and genetic N-acetyltransferase polymorphism in urothelial cancer patients of Leverkusen, Germany. Scand J Work Environ Health 22:332–338.8923605
Goodman G, Wilson R. 1991. Predicting the carcinogenicity of chemicals in humans from rodent bioassay data. Environ Health Perspect 94:195–218.1954931
*Gorbach SL, Goldin BR. 1990. The intestinal microflora and the colon cancer connection. Rev Infect Dis 12(Suppl 2):252–261.
Gorrod JW, Manson D. 1986. The metabolism of aromatic amines. Xenobiotica 16:933–955.3541401
Grady MK, Jacobson-Kram D, Dearfield K, 1985. Prostaglandin synthetase-mediated metabolism of benzidine to DNA-damaging forms by rat and human hepatoma cells in vitro [Abstract]. Journal of Environmental Mutagen Society 7(Suppl 3):8.
*Grady MK, Jacobson-Kram D, Dearfield KL, 1986. Induction of sister chromatid exchanges by benzidine in rat and human hepatoma cell lines and inhibition by indomethacin. Cell Biol Toxicol 2(2):223–230.3267448
*Graf U, Frie H, Kagi A, 1989. Thirty compounds tested in the Drosophila wing spot test. Mutat Res 222:359–373.2495439
*Grant DM, Josephy PD, Lord HL, 1992. Salmonella typhimurium strains expressing human arylamine N-acetyltransferases: Metabolism and mutagenic activation of aromatic amines. Cancer Res 52:3961–3964.1617672
*Graveel JG, Sommers LE, Nelson DW. 1985. Sites of benzidine, α-naphthylamine and p-toluidine retention in soils. Environ Toxicol Chem 4:607–613.
*Graveel JG, Sommers LE, Nelson DW. 1986. Decomposition of benzidine, α-naphthylamine and p-toluidine in soils. J Environ Qual 15(1):53–59.
Green LC, Skipper PL, Turesky RJ, 1984. In vivo dosimetry of 4-aminobiphenyl in rats via a cysteine adduct in hemoglobin. Cancer Res 44:4254–4259.6467185
Green MD, King CD, Mojarrabi B, 1998. Glucuronidation of amines and other xenobiotics catalyzed by expressed human UDP-glucuronosyltransferase 1A3. Drug Metab Dispos 26:507–512.9616184
*Gregory AR. 1984. The carcinogenic potential of benzidine-based dyes. J Environ Pathol Toxicol Oncol 5:243–259.6520730
Gregory AR. 1988. Species comparisons in evaluating carcinogenicity in humans. Regul Toxicol Pharmacol 8:160–190.3051141
*Gregory AR, Elliott J, Kluge P. 1981. Ames testing of Direct Black 38 parallels carcinogenicity testing. J Appl Toxicol 1(6):308–313.6764474
*Grimalt F, Romaguera C. 1981. Cutaneous sensitivity to benzidine. Dermatosen 29(4):95–97.
*Griswold DP Jr., Casey AE, Weisburger EK, 1968. The carcinogenicity of multiple intragastric doses of aromatic and heterocyclic nitro or amino derivatives in young female Sprague-Dawley rats. Cancer Res 28:924–933.5652305
Gupta RC, Earley K, Sharma S. 1987. Use of human lymphocytes to measure DNA binding capacity of chemical carcinogens. Proc Am Assoc Cancer Res 28:124.
*Gupta RC, Earley K, Sharma S. 1988. Use of human peripheral blood lymphocytes to measure DNA binding capacity of chemical carcinogens. Proc Natl Acad Sci 85:3513–3517.3368462
*Guzelian PS, Henry CJ, Olin SS, eds. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences Institute Press.
*Haley TJ. 1975. Benzidine revisited: A review of the literature and problems associated with the use of benzidine and its congeners. Clin Toxicol 8(1):13–42.805682
Haley TJ. 1982. Metabolism and pharmacokinetics of benzidine and its congeners in man and animals. Drug Metab Rev 13:473–483.7049641
Haley TJ. 1984. Occupational cancer and chemical structure: Past, present and future. Drug Metab Rev 15:919–939.6396060
*Hammond SK, Coghlin J, Gann PH, 1993. Relationship between environmental tobacco smoke exposure and carcinogen-hemoglobin adduct levels in non-smokers. J Natl Cancer Inst 85(6):474–478.8445675
Hammons GJ, Guengerich FP, Weis CC, 1985. Metabolic oxidation of carcinogenic arylamines by rat, dog, and human hepatic microsomes and by purified flavin-containing and cytochrome P-450 monooxygenases. Cancer Res 45:3578–3585.4016738
*Hanke J, Krajewska B. 1990. Acetylation phenotypes and bladder cancer. J Occup Med 32(9):917–920.2074519
Hanna MA, Girges MM. 1995. Heterocyclic alternatives for benzidine-based mono- and disarylazo pigments: Synthesis and characterization of a novel class of pyrazolo (1,5-a)pyrimidine azo pigments. J Chem Technol Biotechnol 62:392–400.
*Hansch C, Leo A, Hoekman D, eds. 1995. Exploring QSAR: Hydrophobic, electronic, and steric constants. Washington, DC: American Chemical Society.
*Harbach PR, Wiser SK, Smith AL, 1991. Strain differences in in vitro rat hepatocyte unscheduled DNA synthesis (UDS): Effect of UV is independent of strain while increased sensitivity is apparent using Fischer-344 instead of Sprague-Dawley rats. Mutat Res 252:149–155.2017204
*Harper BL, Sadagopa Ramanujam VM, Legator MS. 1989. Micronucleus formation by benzene, cyclophosphamide, benzo(a)pyrene, and benzidine in male, female, pregnant female, and fetal mice. Teratogenesis Carcinog Mutagen 9:239–252.2572067
Hasegawa R, Murasaki G, St. John MK, 1990. Evaluation of nitrofurantoin on the two stages of urinary bladder carcinogenesis in the rat. Toxicology 62:333–347.2117780
*Hassett JJ, Banwart WL, Griffin RA. 1983. Correlation of compound properties with sorption characteristics of nonpolar compounds by soils and sediments: Concepts and limitations. In: Francis CW, Auerback SI, eds. Environment and solid wastes: Characterization, treatment, and disposal. Boston, MA: Butterworths, 161–178.
*Hatcher JF, Swaminathan S. 1992. Microsome-mediated transacetylation and binding of N-hydroxy-4-aminobiphenyl to nucleic acids by hepatic and bladder tissues from dog. Carcinogenesis 13:1705–1711.1423829
*Haworth S, Lawlor T. 1978. Comparative in vitro metabolic activation of benzidine and 3,3'-dichlorobenzidine by rodent and human liver preparations. Abstract no. Aa-8. In: 9th Annual Meeting of the Environmental Mutation Society. San Francisco, CA.
Haworth S, Lawlor T, Mortelmans K, 1983. Salmonella mutagenicity test results for 250 chemicals. Environ Mutagen 1(Suppl):3–142.
*Hawthorne SB. 1988. 1988 Workshop on supercritical fluid chromatography. American Laboratory, August, 6–8.
Hayashi K, Mashizu N, Haga S, 1988. Comparative study on the mutagenic activity of rat liver and bladder S9 by fluctuation test. Jpn J Ind Health 30:385–391.
Hayashi Y, ed. 1991. Cancer risk assessment of food additives and food contaminants. In: Mutagens in food: Detection and prevention. Boca Raton, FL: CRC Press, 243–257.
*Hayes RB, Bi W, Rothman N, 1993. N-acetylation phenotype and genotype and risk of bladder cancer in benzidine-exposed workers. Carcinogenesis 14(4):675–678.8472331
*HazDat. 2001. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA. 2000.
Hein DW. 1988. Acetylator genotype and arylamine-induced carcinogenesis. Biochim Biophys Acta 948:37–66.3293663
Hein DW, Flammang TJ, Kirlin WG, 1988. Acetylator genotype-dependent metabolic activation of N-hydroxyarylamine by S-acetyl coenzyme A-dependent enzymes of inbred hamster tissue cytosols: Relationship to arylamine N-acetyltransferase. Carcinogenesis 8:1767–1774.
Hein DW, Kirlin WG, Yerokun T, 1987. Inheritance of acetylator genotype-dependent arylamine N-acetyltransferase in hamster bladder cytosol. Carcinogenesis 8:647–652.3581423
Helmes CT. 1993. Letter regarding benzidine-based dyes. Ecological and Toxicological Association of Dyes and Organic Pigments Manufacturers.
*Henderson L, Ransome S, Brabbs C, 1990. Induction of mutations in mouse lymphoma L5178Y cells by ethylmethanesulphonate, benzidine and benzo[a]pyrene. Mutagenesis suppl 5:27–34.
*Hites RA, Budde WL. 1991. EPA's analytical methods for water: The next generation. Environmental Science and Technology 25(6):998–1006.
Hlavica P, Golly I, Lehnerer M, 1997. Primary aromatic amines: Their N-oxidative bioactivation. Human Exp Toxicol 16:441–448.
*Hodgson E. 1987. Metabolism of toxicants. In: Hodgson E, Levi PE, eds. A textbook of modern toxicology. New York, NY: Elsevier Publishing, 51–84.
*Hoel DG, Davis DL, Miller AB, 1992. Trends in cancer mortality in 15 industrialized countries, 1969–1986. J Natl Cancer Inst 84(5):313–320.1738181
Honma Y, Kakizoe T, Komatsu H, 1983. Agglutination assay of bladder cells by concanavalin A proved the high susceptibility of analbuminemic rats to bladder carcinogens. Cancer Lett 19:7–11.6850570
*Howard PH, ed. 1989. Handbook of environmental fate and exposure data for organic chemicals. Vol I. In: Chelsea, MI: Lewis Publishers, Inc.
Hradec J, Seidel A, Platt KL, 1990. The initiator tRNA acceptance assay as a short-term test for carcinogens. 6. Results with 78 polycyclic aromatic compounds. Carcinogenesis 11:1921–1926.2225323
*HSDB. 1999. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Information Program, Bethesda, MD. April 16, 1999.
*HSDB. 2001. Hazardous Substances Data Bank. Exposure Standards and Regulations. January 16, 2001.
*Hsu FF, Lakshmi V, Rothman N, 1996. Determination of benzidine, N-acetylbenzidine, and N,N'-diacetylbenzidine in human urine by capillary gas chromatography/negative ion chemical ionization mass spectrometry. Anal Biochem 234:183–189.8714596
Huang SL, Waters MD. 1983. Induction of 6-thioguanine resistance in human fibroblasts treated with mutagens in the presence of rat liver microsomes. Environ Mutagen 5:414.
Hueper WC, Wiley FH, Wolfe HD. 1938. Experimental production of bladder tumors in dogs by administration of beta-naphthylamine. J Ind Hyg Toxicol 20:46–84.
*Hurst RE, Settine RL, Fish F, 1981. Analysis of urine for parts per trillion of aromatic diamines with capillary chromatography and selected-ion monitoring mass spectrometry. Anal Chem 53(14):2175–2179.7316210
IARC. 1972. Benzidine and its sulphate, hydrochloride and dihydrochloride. Lyon, France: International Agency for Research on Cancer. 29.
*IARC. 1981a. Method 2. Determination of benzidine and 3,3'-dichlorobenzidine and their salts by high-performance liquid chromatography. In: Egan, Fishbein L, O’Neill I, eds. Environmental carcinogens selected methods of analysis. Volume 4. Some aromatic amines and azo dyes in the general and industrial environment. Lyon, France: International Agency for Research on Cancer, 119–131.
*IARC. 1981b. Method 9. Possible carcinogenic metabolites of azo dye and pigment: Trace-level determination of benzidine, 3,3'-dichlorobenzidine and their acetylated metabolites and conjugated products in human and hamster urine. In: Egan H, Fishbein L, O’Neill I, eds. Environmental carcinogens selected methods of analysis. Volume 4. Some aromatic amines and azo dyes in the general and industrial environment. Lyon, France: International Agency for Research on Cancer, 193–217.
*IARC. 1982a. IARC Monographs on the evaluation of the carcinogenic risk of chemicals to man. Volume 29, Benzidine and its sulfate, hydrochloride and dihydrochloride. Lyon, France: International Agency for Research on Cancer, Supplement I:25.
IARC. 1982b. IARC Monographs on the evaluation of the carcinogenic risk of chemicals to humans. Chemicals, industrial processes and industries associated with cancer in humans. Lyon, France: International Agency for Research on Cancer. Volumes 1 to 29, Supplement 4.
*IARC. 1987. IARC Monographs on the evaluation of the carcinogenic risk of chemicals to man. Lyon, France: International Agency for Research on Cancer, Suppl 7:123–125.
IARC. 1990. Carcinogens in our environment. In: Vainio H, Sorsa M, McMichael A, eds. Complex Mixtures and Cancer Risk. Lyon, France: International Agency for Research on Cancer, 233–237.
*IARC. 2001. Overall evaluations of carcinogenicity to humans. International Agency for Research on Cancer. Http://193.51.164.11/monoeval/crthall.html. August 9, 2000.
*Iba MM. 1987. Comparative activation of 3,3'-dichlorobenzidine and related benzidines to mutagens in the Salmonella typhimurium assay by hepatic S9 and microsomes from rats pretreated with different inducers of cytochrome P-450. Mutat Res 182:231–241.3309638
Iba MM, Lang B. 1988. Stimulation of the conjugation of lipid dienes in hepatic microsomes by 3,3'-dichlorobenzidine. Biochem Pharmacol 37:781–791.3345196
Iba MM, Sikka HC. 1983. Induction of hepatic microsomal cytochrome P-448-mediated oxidases by 3,3'-dichlorobenzidine in the rat. Biochem Pharmacol 32:901–909.6838636
Iba MM, Ghosal A, Poyer JL, 1991. In vivo spin-trapping of the radical metabolites of 3,3'-dichlorobenzidine and related compounds in the rat. Prog Pharmacol Clin Pharmacol 8:255–266.
*International Business Machines. 1979. TSCA sec 8(e) submission 8EHQ-0779–0295. Skin absorption study—direct black 38. Preliminary results, filed July 9, 1979. Washington, DC: U.S. Environmental Protection Agency, Office of Pesticides and Toxic Substances.
Ioannides C, Lum PY, Parke DV. 1984. Cytochrome P-448 and the activation of toxic chemicals and carcinogens. Xenobiotica 14:119–137.6719936
*IRIS. 2001. Benzidine. Integrated Risk Information System, U.S. Environmental Protection Agency. Http://www.epa.gov/iris/subst/index.html.
*Jedrzejczak K, Gaind VS. 1993. Determination of benzidine in urine using capillary gas chromatography and negative-ion chemical ionisation mass spectrometry. Fresenius' J Anal Chem 347:136–140.
*Jenkins CL. 1978. Textile dyes are potential hazards. J Environ Health 40(5):256–263.
*Johanson CE. 1980. Permeability and vascularity of the developing brain: Cerebellum vs cerebral cortex. Brain Res 190:3–16.6769537
Johansson SL, Cohen SM. 1997. Epidemiology and etiology of bladder cancer. Sem Surg Oncol 13:291–298.
*Johnson HJ, Cernosek SF, Gutierrez-Cernosek RM, 1981. Validation of a radioimmunoassay procedure for N,N'-diacetylbenzidine, a metabolite of the chemical carcinogen benzidine, in urine. J Anal Toxicol 5:157–161.7278152
*Johnson WE, Means JC, eds. 1986. Sorption/desorption properties of benzidine to estuarine sediments. In: 191st National Meeting: New York, NY, April 13–18, 1986. New York, NY: American Chemical Society, Division of Environmental Chemistry, 241.
Josephy PD. 1985. Oxidation activation of benzidine and its derivatives by peroxidases. Environ Health Perspect 64:171–178.3007087
Josephy PD. 1986. Benzidine: Mechanisms of oxidative activation and mutagenesis. Pediatr Proc 45:2465–2470.
Josephy PD. 1989. Activation of aromatic amines by prostaglandin H synthase. Free Radic Biol Med 6:533–540.2501165
*Josephy PD, Chiu AL H, Eling TE. 1989. Prostaglandin H synthase-dependent mutagenic activation of benzidine in a Salmonella typhimurium Ames tester strain possessing elevated N-acetyltransferase levels. Cancer Res 49:853–856.2492207
Ju YH, Plewa MJ. 1997. Plant-activation of the bicyclic aromatic amines benzidine and 4-aminobiphenyl. Environ Mol Mut 29:81–90.
*Kada T. 1981. The DNA-damaging of activity 42 coded compounds in the rec-assay. Progress in Mutation Research 1:175–182.
Kadlubar FF, Butler MA, Hayes BE, 1988. Role of microsomal cytochromes P-450 and prostaglandin H-synthase in 4-aminobiphenyl-DNA adduct formation. Microsomes and Drug Oxidations 370–379.
*Kadlubar FF, Fredrick CB, Weis CC, 1982. Prostaglandin endoperoxide synthetase-mediated metabolism of carcinogenic aromatic amines and their binding to DNA and protein. Biochem Biophys Res Commun 108(1):253–258.6816227
Kadlubar FF, Yamazoe Y, Flammay JJ, 1986a. Peroxidative activation of carcinogenic aromatic amines by human extra hepatic tissues. Proc Am Assoc Cancer Res 27:115.
*Kadlubar FF, Yamazoe Y, Lang NP, 1986b. Carcinogen-DNA adduct formation as a predictor of metabolic activation pathways and reactive intermediates in benzidine carcinogenesis. Adv Exp Med Biol 197:537–549.3766280
Kamataki T, Kaori M, Yasushi Y, 1983. A high-spin form of cytochrome P-450 highly purified from polychlorinated biphenyl-treated rats. Mol Pharmacol 24:146–155.6408394
*Kellner H-M, Christ OE, Lotzsch K. 1973. Animal studies on the kinetics of benzidine and 3,3'-dichlorobenzidine. Arch Toxicol 31:61–79.
Kelly SL, Kelly DE, King DJ, 1985. Interaction between yeast cytochrome P-450 and chemical carcinogens. Carcinogenesis 6:1321–1325.4028332
*Kelly TJ, Mukund R, Spicer CW, 1994. Concentrations and transformations of hazardous air pollutants. Environ Sci Technol 28(8):378A–387A.
*Kennelly JC, Beland FA, Kadlubar FF, 1984. Binding of N-acetylbenzidine and N,N'-diacetylbenzidine to hepatic DNA of rat and hamster in vivo and in vitro. Carcinogenesis 5(3):407–412.6705145
*Kennelly JC, Clare CB, Campbell J, 1990. The mutagenic activity of ethylmethanesulphonate, benzidine and benzo[a]pyrene at the hprt locus of wild-type L5178Y mouse lymphoma cells. Mutagenesis suppl 5:21–26.
Klopman G, Frierson MR, Rosenkranz HS. 1990. The structural basis of the mutagenicity of chemicals in Salmonella typhimurium: The gene-tox data base. Mutat Res 228:1–50.2405259
Kockhar R, Sharma R, Dani HM, 1985. Effects of benzidine on some phosphohydrolases of rat tissues. Research Bulletin Punjab University 36:295–297.
Kodell RL, Nelson CJ. 1980. An illness-death model for the study of the carcinogenic process using survival/sacrifice data. Biometrics 36:267–277.7407315
*Komori M, Nishio K, Kitada M, 1990. Fetus-specific expression of a form of cytochrome P-450 in human liver. Biochemistry 29:4430–4433.2350547
*Korenman IM, Nikolaev BA. 1974. Extraction determination of stepwise ionisation constants of weak diacid bases. Russian Journal of Physical Chemistry 48:1502–1504.
*Korfmacher WA, Holder CL, Betowski LD, 1987. Identification of two glucuronide metabolites of doxylamine via thermospray/mass spectrometry and thermospray/mass spectrometry/mass spectrometry. J Anal Toxicol 11:182–184.3626532
*Kornburst DJ, Barfknecht TR. 1984a. Comparison of 7 azo dyes and their azo reduction products in the rat and hamster hepatocyte primary culture/DNA-repair assays. Mutat Res 136:255–266.6738568
*Kornburst DJ, Barfknecht TR. 1984b. Comparison of rat and hamster hepatocyte primary culture/DNA repair assays. Environ Mutagen 6:1–11.
*Krishnan K, Andersen ME. 1994. Physiologically-based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. New York, NY: Academic Press, 399–437.
*Krishnan K, Andersen ME, Clewell HJ, 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RS H, ed. Toxicology of Chemical Mixtures; case studies, mechanisms, and novel approaches. San Diego, California: Academic Press, 399–437.
Kulkarni AP, Cook DC. 1988. Hydroperoxidase activity of lipoxygenase: Dioxygenase activity in role in xenobiotic metabolism. Int J Biochem 24(2):255–261.
Kulkarni AP, Cai Y, Richards IS. 1992. Rat pulmonary lipoxygenase: Dioxygenase activity and role in xenobiotic metabolism. Int J Biochem 2:255–261.
Kumar S, Wilson P, Brenchley P, 1978. Frequent elevation of tissue polypeptide antigen in the sera of workers exposed to bladder carcinogen. Int J Cancer 22:542–545.82541
Ladero JM, Kwok CK, Jara C, 1985. Hepatic acetylator phenotype in bladder cancer patients. Ann Clin Res 17:96–99.4051447
*Lahav N, Raziel S. 1971. Interaction between montmorillonite and benzidine in aqueous solutions II. A general kinetic study. Israel Journal of Chemistry 9:691–694.
*Lakshmi VM, Bell DA, Watson MA, 1995a. N-acetylbenzidine and N,N'-diacetylbenzidine formation by rat and human liver slices exposed to benzidine. Carcinogenesis 16(7):1565–1571.7614690
*Lakshmi VM, Mattammal MB, Spry LA, 1990a. Metabolism and disposition of benzidine in the dog. Carcinogenesis 11(1):139–144.2403856
*Lakshmi VM, Mattammal MB, Zenser TV, 1990b. Mechanism of peroxidative activation of the bladder carcinogen 2-amino-4-(5-nitro-2-furyl)-thiazole (ANFT): Comparison with benzidine. Carcinogenesis 11(11):1965–1970.2121382
Lakshmi VN, Wise RW, Mattammal MB, 1987. Initiation of benzidine binding to DNA. Pro Am Assoc Cancer Res 28:96.
*Lakshmi VM, Zenser TV, Davis BB. 1994. Mechanism of 3-(glutathion-S-yl)-benzidine formation. Toxicol Appl Pharmacol 125:256–263.8171433
*Lakshmi VM, Zenser TV, Davis BB. 1997. Rat liver cytochrome P450 metabolism of N-acetylbenzidine and N,N'-diacetylbenzidine. Drug Metab Dispos 25(4):481–488.9107548
*Lakshmi VM, Zenser TV, Goldman HD, 1995b. The role of acetylation in benzidine metabolism and DNA adduct formation in dog and rat liver. Chem Res Toxicol 8:711–720.7548754
Lakshmi VM, Zenser N, Hsu F, 1996a. Different cytochrome P450s metabolize benzidine and its N-acetylated analogues in rat liver. Proc Am Assoc Cancer Res 37:130.
*Lakshmi VM, Zenser NT, Hsu FF, 1996b. NADPH-dependent oxidation of benzidine by rat liver. Carcinogenesis 17(9):1941–1947.8824518
*Lancaster FE, Lawrence JF. 1999. Determination of benzidine in the food colours tartrazine and sunset yellow FCF, by reduction and derivatization followed by high-performance liquid chromatography. Food Addit Contam 16(9):381–390.10755129
*Lang B, Iba MM. 1988. Metabolism of 3,3'-dichlorobenzidine by horseradish peroxidase. Xenobiotica 18(8):893–904.3188570
*Lawler GM, ed. 1977. Chemical origins and markets. 5th ed. Menlo Park, CA: Stanford Research Institute. 118.
*Lee Y. 1997. The environmental fate of three carcinogens: Benzo-(d)-pyrene, benzidine and vinyl chloride evaluated in laboratory model systems. Arch Environ Contam Toxicol 6:129–142.
*Lee LS, Nyman AK, Li H, 1997. Initial sorption of aromatic amines to surface soils. Environ Toxicol Chem 16(8):1575–1582.
*Leeder JS, Kearns GL. 1997. Pharmacogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
*Leung H-W. 1993. Physiologically-based pharmacokinetics modeling. In: Ballentine B, Marro T, Turner P, eds. General and applied toxicology. New York, NY: Stockton Press, 153–164.
*Levine WG. 1991. Metabolism of azo dyes: Implication for detoxication and activation. Drug Metab Rev 23(3/4):253–309.1935573
*Levy GN, Weber WW. 1988. High-performance liquid chromatographic analysis of 32P-postlabeled DNA-aromatic carcinogen adducts. Anal Biochem 174:381–392.3239743
*Lewis RJ, ed. 1993. Hawley’s condensed chemical dictionary. 12th ed. New York, NY: Van Nostrand Reinhold Company, 130.
Li AP, Aaron CS, Auletta AR, 1991. An evaluation of the roles of mammalian cell mutation assays in the testing of chemical genotoxicity. Regul Toxicol Pharmacol 14:24–40.1947242
Li AP, Gupta RS, Heflich RH, 1988. A review and analysis of the Chinese hamster ovary/hypoxanthine guanine phosphoribosyl transferase assay to determine the mutagenicity of chemical agents. Mutat Res 196:17–36.3292898
Lide DR, ed. 1997. CRC Handbook of chemistry and physics: A ready-reference book of chemical and physical data. 78th ed. Boca Raton, FL: CRC Press.
*Lide DR, ed. 1998. CRC Handbook of chemistry and physics: A ready-reference book of chemical and physical data. 79th ed. Boca Raton, FL: CRC Press.
Light HC, Hubert JJ, Josephy PD, 1987. Benzidine activation in the Ames test: Roles of hepatic N-acetyltransferase and other cytosolic and microsomal factors. Carcinogenesis 8:139–143.3542272
*Lin HJ, Han CY, Bernstein DA, 1994. Ethnic distribution of the glutathione transferase Mu 1–1 (GSTM1) null genotype in 1473 individuals and application to bladder cancer susceptibility. Carcinogenesis 15(5):1077–1081.8200072
*Lindahl-Kiessling K, Karlberg I, Olofsson AM. 1989. Induction of sister-chromatid exchanges by direct and indirect mutagens in human lymphocytes, co-cultured with intact rat liver cells. Effect of enzyme induction and preservation of the liver cells by freezing in liquid nitrogen. Mutat Res 211:77–87.2922003
Liteplo RG, Meek ME. 1994. Benzidine: Evaluation of risks to health from environmental exposure in Canada. J Environ Sci Health C 12:173–177.
*Littlefield NA, Nelson CJ, Frith CH. 1983. Benzidine dihydrochloride: Toxicological assessment in mice during chronic exposure. J Toxicol Environ Health 12:671–685.6366243
*Littlefield NA, Nelson CJ, Gaylor DW. 1984. Benzidine dihydrochloride risk assessment. Fund Appl Toxicol 4:69–80.
Littlefleld NA, Wolff GL, Nelson CJ. 1985. Influence of genetic composition of test animal populations on chronic toxicity studies used for risk estimation. J Toxicol Environ Health 15:357–367.4032486
*Livingston AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4:301–324.351201
*Lower GM. 1979. N-acetyltransferase phenotype and risk in industrial urinary bladder cancer: Approaches to high risk groups. In: Deichmann W, ed. Toxicology and occupational medicine. New York, NY: Elsevier, 209–219.
*Lower GM, Nilsson T, Nelson CE, 1979. N-acetyltransferase phenotype and risk in urinary bladder cancer: Approaches in medical epidemiology. Preliminary results in Sweden and Denmark. Environ Health Perspect 29:71–79.510245
*Lu P-Y, Metcalf RL, Plummer N, 1977. The environmental fate of three carcinogens: Benzo-(α)-pyrene, benzidine, and vinyl chloride evaluated in laboratory model ecosystems. Arch Environ Contam Toxicol 6:129–142.20063
*Lunn G, Sansone EB. 1991. The safe disposal of diaminobenzidine. Appl Occup Environ Hyg 6(1):49–53.
Luster MI, Germolec DR, Rosenthal GJ. 1990. Immunotoxicology review of current status. Ann Allergy 64:427–432.2186671
*Luster MI, Portier C, Pait DG, 1992. Risk assessment in immunotoxicity: I. Sensitivity and predictability of immune tests. Fundam Appl Toxicol 18:200–210.1534777
Lynn RH, Donielson DW, Ilias AM, 1980. Metabolism of bisazobiphenyl dyes derived from benzidine, 3,3'-dimethylbenzidine or 3,3'-di methoxybenzidine to carcinogenic aromatic amines in the dog and rat. Toxicol Appl Pharmacol 56:248–258.7466824
*Lynn RK, Garvie-Gould C, Milam DF, 1983. Metabolism of the human carcinogen, benzidine, in the isolated perfused rat liver. Drug Metab Dispos 11(2):109–114.6133713
*Lynn RK, Garvie-Gould C, Milam DF, 1984. Disposition of the aromatic amine, benzidine, in the rat: Characterization of mutagenic urinary and biliary metabolites. Toxicol Appl Pharmacol 72:1–14.6710475
*Mancuso TF, El-Attar AA. 1967. Cohort study of workers exposed to betanaphthylamine and benzidine. J Occup Med 9:277–285.6026374
*Martin CN, Beland FA, Roth RW, 1982. Covalent binding of benzidine and N-acetylbenzidine to DNA at the C-8 atom of deoxyguanosine in vivo and in vitro. Cancer Res 42:2678–2696.7083160
Martin CN, Kennelly JC. 1985. Metabolism, mutagenicity, and DNA binding of biphenyl-based azodyes. Drug Metab Rev 16(1–2):89–117.3905319
*Martin CN, McDermid AC, Garner RC. 1978. Testing of known carcinogens and noncarcinogens for their ability to induce unscheduled DNA synthesis in HeLa cells. Cancer Res 38:2621–2627.667855
Mason TJ. 1984. Study of the DuPont Chambers Works plant bladder cancer screening program. Proceedings of the Third NCI/EPA/NIOSH Collaborative Workshop: Progress on Joint Environmental and Occupational Cancer Studies, 295–300.
Mason TJ, Vogler WJ. 1990. Bladder cancer screening at the Dupont chambers works: A new initiative. J Occup Med 32:874–877.2074511
*Mason TJ, Prorok PC, Neeld WE Jr., 1986. Screening for bladder cancer at the DuPont Chambers Works: Initial findings. J Occup Med 28(10):1011–1016.3772535
Massachusetts Department of Public Health. 1994. Public Health Assessment for Nyanza Chemical Waste Dump Ashland, Middlesex County, Massachusetts, Region 1. CERCLIS No. MAD990685422. Agency for Toxic Substances and Disease Registry (ATSDR). PB94–194446.
Matsushima M. 1989. Occupational cancer of the urinary bladder: The diagnostic value of urinary cytology in dyestuff workers exposed to aromatic amines. Acta Urol Jpn 35:2033–2040.
Mavournin KH, Blakey DH, Cimino MC, 1990. The in vivo micronucleus assay in mammalian bone marrow and peripheral blood. A report of the U.S. Environmental Protection Agency gene-tox program. Mutat Res 239:29–80.2195332
*Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74:135–149.1387742
*McCann J, Choi E, Yamasaki E, 1975. Detection of carcinogens as mutagens in the Salmonella/microsome test: Assay of 300 chemicals. Proc Natl Acad Sci 72(12):5135.1061098
McFee AF, Jauhar PP, Lowe KW, 1989. Assays of three carcinogen/non-carcinogen chemical pairs for in vivo induction of chromosome aberrations, sister chromatid exchanges and micronuclei. Environ Mol Mutagen 14:207–220.2583129
McManus ME. 1989. The role of cytochromes P-450 and N-acetyl transferase in the carcinogenicity of aromatic amines and amides. Clin Exp Pharmacol Physiol 16:491–495.2670357
*McNally EP, Wheeler JR. 1988. Supercritical fluid extraction coupled with supercritical fluid chromatography for the separation of sulfonylurea herbicides and their metabolites from complex matrices. J Chromatogr 435:63–71.3350898
*McQueen CA, Way BM, Williams GM. 1987. Biotransformation of aromatic amines to DNA-damaging products by urinary bladder organ cultures. Carcinogenesis 8(3):401–404.3815734
*Means JC, Wijayaratne RD. 1989. Sorption of benzidine, toluidine, and azobenzene on colloidal organic matter. In: Suffet IH, MacCarth P, eds. Aquatic humic substances; Influence on fate and treatment of pollutants. Washington, DC: American Chemical Society, 209–222.
*Meigs JW, Brown RM, Sciarini IJ. 1951. A study of exposure to benzidine and substituted benzidine in a chemical plant. AMA Arch Ind Hyg Occup Med 4:533–540.14877312
*Meigs JW, Marrett LD, Ulrich FU, 1986. Bladder tumor incidence among workers exposed to benzidine: A thirty-year follow-up. J Natl Cancer Inst 76(1):1–8.3455732
*Meigs JW, Sciarini LJ, Van Sandt WA. 1954. Skin penetration by diamines of the benzidine group. Arch Ind Hyg 9:122–132.
Merck. 1989. The Merck index (11th edition). Budavari, ed. Merck & Co., Inc., Rahway, NJ.
*Messerly EA, Fekete JE, Wade DR, 1987. Structure-mutagenicity relationships of benzidine analogues. Environ Mol Mutagen 10:263–274.3315653
*Meylan WM, Howard PH. 1991. Bond contribution method for estimating Henry’s law constants. Environ Toxicol Chem 10:1283–1293.
*Meylan WM, Howard PH. 1993. Computer estimation of the atmospheric gas-phase reaction rate of organic compounds with hydroxyl radicals and ozone. Chemosphere 26(2):2293–2299.
Michael LC, Pellizzari ED, Wiseman RW. 1988. Development and evaluation of a procedure for determining volatile organics in water. Environ Sci Technol 22:565–570.22195629
Miller ME, Cosgriff JM. 1983. Acetylator phenotype in human bladder cancer. J Urol 130:65–66.6864917
*Mirkova E. 1990. Activity of the human carcinogens benzidine and 2-naphthylamine in triple- and single-dose mouse bone marrow micronucleus assays: Results for a combined test protocol. Mutat Res 234:161–163.2366784
*Mirkova ET, Ashby J. 1988. Activity of the human carcinogens benzidine and 2-naphthylamine in male mouse bone marrow micronucleus assays. Mutagenesis 3(5):437–439.3070279
*Mirkova ET, Lalchev SG. 1990. The genetic toxicity of the human carcinogens benzidine and benzidine-based dyes: Chromosomal analysis in exposed workers. Mutation and the Environment Part C:397–405.
*Mitchell AD, Rudd CJ, Caspary WJ. 1988. Evaluation of the L5178Y mouse lymphoma cell mutagenesis assay: Intralaboratory results for sixty-three coded chemicals tested at SRI International. Environ Mol Mutagen 12(suppl 13):37–101.3416841
*Mitchell I, Gilbert PJ. 1991. Comparison of three forward mutation systems in Saccharomyces cerevisiae for sensitivity to polycyclic and heterocyclic compounds. Mutagenesis 6(3):229–236.1715506
Mommsen S, Wolf H. 1985. N-acetyltransferase phenotypes in bladder tumour patients with and without carcinoma in situ in selected site biopsies. Scand J Urol Nephrol 19:203–204.4070990
*Mommsen S, Aagaard J. 1986. Susceptibility in urinary bladder cancer: Acetyltransferase phenotypes and related risk factors. Cancer Lett 32:199–205.3756846
Monks TJ, Lau SS. 1988. Reactive intermediates and their toxicological significance. Toxicology 52:1–53.3055427
*Montanaro F, Ceppi M, Demers PA, 1997. Mortality in a cohort of tannery workers. Occup Environ Med 54:588–591.9326162
*Moore BP, Potter PM, Hicks RM. 1984. Metabolism of 2-naphthylamine and benzidine by rat and human bladder organ cultures. Carcinogenesis 5(7):949–954.6733857
Morgan DL, Jameson CW, Mennear JH, 1989. Thirteen-week toxicity studies of 3,3'-dimethoxybenzidine and CI direct blue 15 in the Fischer 344 rat. Toxicology 59:297–309.2631298
Morgan DL, Bucher JR, Huff JE, 1990b. Multi-organ carcinogenicity of 3,3'-dimethoxybenzidine dihydrochloride given in drinking water to F344/N rats. J Am Coll Toxicol 9:79–91.
Morgan DL, Jokinen MP, Haseman JK, 1990b. Carcinogenicity of 3,3'-dimethylbenzidine dihydrochloride given in drinking water to F344/N rats. J Am Coll Toxicol 10:255–267.
*Morgan DL, Dunnick JK, Goehl T, 1994. Summary of the National Toxicology Program Benzidine Dye Initiative. Environ Health Perspect 102(suppl 12):63–78.
*Morgan KT, Crowder DM, Frith CH, 1981. Spongiform leukoencephalopathy induced in mice by oral benzidine administration. Toxicol Pathol 9(1):4–8.
Mori H, Yoshimi N, Sugie S, 1988. Genotoxicity of epoxy resin hardeners in the hepatocyte primary culture/DNA repair test. Mutat Res 204:683–688.3352649
*Morikawa Y, Shiomi K, Ishihara Y, 1997. Triple primary cancers involving kidney, urinary bladder, and liver in a dye worker. Am J Ind Med 31:44–49.8986253
*Morinaga K, Oshima A, Hara I. 1982. Multiple primary cancers following exposure to benzidine and betanaphthylamine. Am J Ind Med 3:243–246.7171086
*Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related difference and the therapeutic implications. Clin Pharmacokinet 5:485–527.7002417
*Morton KC, Beland FA, Evans FE, 1980. Metabolic activation of N-hydroxy-N,N'-diacetylbenzidine by hepatic sulfotransferase. Cancer Res 40:751–757.6937241
*Morton KC, Wang CY, Garner CD, 1981. Carcinogenicity of benzidine, N,N'-diacetylbenzidine and N-hydroxy-N,N'-diacetylbenzidine for female CD rats. Carcinogenesis 2(8):747–752.7285281
*Myhr BC, Caspary WJ. 1988. Evaluation of the L5178Y mouse lymphoma cell mutagenesis assay: Intralaboratory results for sixty-three coded chemicals tested at Litton Bionetics, Inc. Environ Mol Mutagen 12(suppl 13):103–194.3416838
Myslak ZW, Bolt HM, Brockmann W. 1991. Tumors of the urinary bladder in painters: A case-control study. Am J Ind Med 19:705–713.1882850
*Naidu AK, Naidu AK, Kulkarni AP. 1992. Dioxygenase and hydroperoxidase activities of rat brain cytosolic lipoxygenase. Res Commun Chem Pathol Pharmacol 75(3):347–356.1509201
*Naito S, Tanaka K, Koga H, 1995. Cancer occurrence among dyestuff workers exposed to aromatic amines: A long term follow-up study. Cancer 76(8):1445–1452.8620422
*NAS/NRC. 1989. Report of the oversight committee. In: Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press.
NATICH. 1987. NATICH data base report on state, local and EPA air toxics activities. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards, National Air Toxics Information Clearinghouse, July.
NATICH. 1991. National Air Toxics Information Clearinghouse: NATICH data base report on state, local and EPA air toxics activities. Report to U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards. Research Triangle Park, NC, by Radian Corporation, Austin, TX. EPA 450/3–91-018.
NATICH. 1992. National Air Toxics Information Clearinghouse. Report on state, local, and EPA air toxics activities. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards.
*Neely WB, Blau GE. 1985. Environmental exposure from chemicals. Volume 1: Agricultural Products Department Midland, MI: The Dow Chemical Company.
*Neis JM, te Brommelstroet BW J, VanGemert PJ L, 1985a. Influence of ethanol induction on the metabolic activation of genotoxic agents by isolated rat hepatocytes. Arch Toxicol 57:217–221.3911922
*Neis JM, Yap SH, VanGemert PJ L, 1985b. Mutagenicity of five arylamines after metabolic activation with isolated dog and human hepatocytes. Cancer Lett 27:53–60.4005824
*Nelson CJ, Baetcke KP, Frith CH, 1982. The influence of sex, dose, time and cross on neoplasia in mice given benzidine dihydrochloride. Toxicol Appl Pharmacol 64:171–186.7123548
Nersessians AK. 1992. Activity of human carcinogens in the Salmonella and rodent bone marrow cytogenetic tests. Mutat Res 281:239–243.1373216
*Neumann H-G. 1988. Biomonitoring of aromatic amines and alkylating agents by measuring hemoglobin adducts. Int Arch Occup Environ Health 60:151–155.3384479
*Neumeister CE. 1991. Analysis of urine to monitor exposures to benzidine, o-tolidine, and 4,4'-methylenedianiline. Appl Occup Environ Hyg 6(11):953–958.
Nicholson WJ. 1988. IARC evaluations in the light of limitations of human epidemiological data. Ann NY Acad Sci 44–54.
NIOSH. 1972. Field survey of Allied Chemical Corp. Report. Cincinnati OH: National Institute for Occupational Safety and Health.
NIOSH. 1978. An investigation of the metabolic reduction of benzidine azo dyes to benzidine and its metabolites, and their possible relationship to carcinoma of the bladder in man. Cincinnati, OH: National Institute for Occupational Safety and Health, U.S. Department of Health, Education and Welfare, Public Health Service, Center for Disease Control.
*NIOSH. 1980a. Health hazard alert: Benzidine-, o-tolidine-, and o-dianisidine-based dyes. Cincinnati, OH: U.S. Department of Health and Human Services. National Institute for Occupational Safety and Health. DHEW (NIOSH) publication no. 81–106.
NIOSH. 1980b. Special occupational hazard review for benzidine-based dyes. Cincinnati, OH: U.S. Department of Health and Human Services. National Institute for Occupation Safety and Health. DHEW (NIOSH) publication no. 80–109.
*NIOSH. 1980c. Technical report on the carcinogenicity and metabolism of azo dyes, especially those derived from benzidine. Cincinnati, OH: U.S. Department of Health and Human Services. National Institute of Safety and Health. (NIOSH) Publication no. 80–119.
*NIOSH. 1984a. Benzidine in urine (TLC) - NIOSH method 8304. NIOSH manual of analytical methods. 3rd ed. Cincinnati, OH: National Institute for Occupational Safety and Health, 8304–1 to 8304–4.
*NIOSH. 1984b. Benzidine in urine (GC) - NIOSH method 8306. NIOSH manual of analytical methods. 3rd ed. Cincinnati, OH: National Institute for Occupational Safety and Health, 8306–1 to 8306–4.
*NIOSH. 1984c. Registry of toxic effects of chemical substances. Cincinnati, OH: National Institute of Occupational Safety and Health, 355.
NIOSH. 1985a. Dyes, benzidine, o-tolidine, o-dianisidine - NIOSH method 5013. NIOSH manual of analytical methods. 3rd ed. 1985 Supplement. Cincinnati, OH: National Institute for Occupational Safety and Health, 5013–1 to 5013–5.
*NIOSH. 1985b. Benzidine and 3,3'-dichlorobenzidine - NIOSH method 5509. NIOSH manual of analytical methods. 3rd ed. 1985 Supplement. Cincinnati, OH: National Institute for Occupational Safety and Health, 5509–1 to 5509–4.
NIOSH. 1986. NIOSH recommendations for occupational safety and health standards. Atlanta GA: U.S. Department of Health and Human Services, National Institute for Occupation Safety and Health. September.
NIOSH. 1988. Current intelligence bulletins: Summaries. Cincinnati, OH: National Institute for Occupational Safety and Health. PB89–138697.
*NIOSH. 1990. NIOSH pocket guide to chemical hazard. Cincinnati, OH: National Institute for Occupational Safety and Health, Centers for Disease Control.
NIOSH. 1999. Pocket guide to chemical hazards. Washington DC: National Institute for Occupational Safety and Health, U.S. Department of Health and Human Services.
*NLM. 1988. Chemline. National Library of Medicine, Bethesda, MD. August, 1988.
*Nony CR, Bowman MC. 1980. Trace analysis of potentially carcinogenic metabolites of an Azo dye and pigment in hamster and human urine as determined by two chromatographic procedures. J Chromatogr Sci 18:64–74.7372761
*Nony CR, Bowman MC, Cairns T, 1980. Metabolism studies of an Azo dye and pigment in the hamster based on analysis of urine for potentially carcinogenic aromatic amine metabolites. J Anal Toxicol 4:132–140.7421147
*Novara R, Coda R, Martone T, 1996. Exposure to aromatic amines and ras and c-erbB-2 overexpression in bladder cancer. J Occup Environ Med 38:390–393.8925323
*NRC. 1993. Pesticides in the diets of infants and children. Washington, DC: National Research Council. National Academy Press.
NTP. 1982. NTP Technical Bulletin. Issue Number 6. Research Triangle Park, NC: National Toxicology Program, Department of Health and Human Services.
*NTP. 1990. NTP Technical Report on the toxicology and carcinogenesis of 3,3'-dimethoxybenzidine dihydrochloride in F344/N rats (drinking water studies). Research Triangle Park, NC: National Toxicology Program, Department of Health and Human Services. NTP TR 372.
*NTP. 1991a. NTP Technical Report Series. Number 390. Toxicology and Carcinogenesis studies of 3,3'-dimethylbenzidine dihydrochloride in F344/N rats (drinking water studies). Research Triangle Park, NC: National Toxicology Program, Department of Health and Human Services.
*NTP. 1991b. NTP Technical Report Series. Number 405. Toxicology and Carcinogenesis studies of C.I. acid red 114 in F344/N rats (drinking water studies). Research Triangle Park, NC: National Toxicology Program, Department of Health and Human Services.
*NTP. 1992. NTP Technical Report Series. Number 397. Toxicology and carcinogenesis studies of C.I. direct blue 15 in F344/N rats (drinking water study). Research Triangle Park, NC: National Toxicology Program, Department of Health and Human Services.
*NTP. 1994. NTP Technical Report Series. Number 430. Toxicology and carcinogenesis studies of C.I. direct blue 218 in F344/N rats and B6C3F_1_ mice (feed studies). Research Triangle Park, NC: National Toxicology Program, Department of Health and Human Services.
*NTP. 2000. Report on Carcinogens, ninth edition. U.S. Department of Health and Human Services, Public Health Service. National Toxicology Program. Research Triangle Park, NC.
*Oberly TJ, Bewsey BJ, Probst GS. 1984. An evaluation of the L5178Y TK+/- mouse lymphoma forward mutation assay using 42 chemicals. Mutat Res 125:291–306.6700611
*Oberly TJ, Rexroat MA, Bewsey BJ, 1990. An evaluation of the CHO/HGPRT mutation assay involving suspension cultures and soft agar cloning: Results for 33 chemicals. Environ Mol Mutagen 16:260–271.2253605
*O'Brien KA F, Gatehouse DG, Tiley M. 1990. Induction of mutations in TK6 human lymphoblastoid cells by ethyl methanesulphonate, benzo[a]pyrene and benzidine. Mutagenesis suppl 5:55–60.
O'Brien PJ. 1988a. Free-radical-mediated chemical carcinogenesis. Ann NY Acad Sci 534:552–564.3133970
O'Brien PJ. 1988b. Radical formation during the peroxidase catalyzed metabolism of carcinogens and xenobiotics: The reactivity of these radicals with GSH, DNA, and unsaturated lipid. Free Radical Biol Med 4:169–183.3281871
Oda Y, Yamazaki H, Watanbe M, 1995. Development of high sensitive umu test system: Rapid detection of genotoxicity of promutagenic aromatic amines by Salmonella typhimurium strain NM2009 possessing high O-acetyltransferase activity. Mutat Res 334:145–156.7885366
*O'Donovan MR. 1990. Mutation assays of ethyl methanesulphonate, benzidine and benzo[a]pyrene using Chinese hamster V79 cells. Mutagenesis 5:9–13.2184328
*Oglesby LA, Hix C, Snow L, 1983. Bovine bladder urothelial cell activation of carcinogens to metabolites mutagenic to Chinese hamster V-79 cells and Salmonella typhimurium. Cancer Res 43:5194–5199.6352016
*Ohsako S, Deguchi T. 1990. Cloning and expression of cDNAs for polymorphic and monomorphic arylamine N-acetyltransferases from human liver. J Biol Chem 265(8):4630–4634.1968463
*Oida S. 1958a. Studies on acute and subacute benzidine poisoning: III. An experimental study (on subacute poisoning). J Sci Labor 34:172–195.
*Oida S. 1958b. Studies on acute and subacute benzidine poisoning. IV. Summary. J Sci Labor 34:352.
*Okubo T, Kraus JF, Yamaguchi N, 1985. Multiple primary concerns with special reference to occupational exposure. Jpn J Clin Oncol 15(Suppl l):243–253.4009986
OĽeary LM, Hicks AM, Peters JM, 1991. Parental occupational exposures and risk of childhood cancer: A review. Am J Ind Med 20:17–35.1867215
*Ononye AI, Graveel JG. 1994. Modeling the reactions of 1-napthylamine and 4-methylaniline with humic acids: spectroscopic investigations of the covalent linkages. Environ Toxicol Chem 13(4):537–541.
*Ononye AI, Graveel JG, Wolt JD. 1989. Kinetic studies of the reactions of benzidine with humic acid. Soil Sci Soc Am J 53:981–983.
*Oostdyk TS, Grob RL, Snyder JL, 1993a. Study of sonication and supercritical fluid extraction of primary aromatic amines. Anal Chem 65:596–600.
*Oostdyk TS, Grob RL, Snyder JL, 1993b. Optimization of the supercritical fluid extraction of primary aromatic amines. J Chromatogr Sci 31:177–182.
*Orzeck D, Gregory AR. 1981. The importance of accurate recording and optimal treatment of dye ingestions. Vet Human Toxicol 22:413–415.
OSHA. 1975. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1010.
*OSHA. 1999. U. S. Department of Labor. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1003.
*OSHA. 2001. 13 Carcinogens. Occupational Safety and Health Administration. U.S. Department of Labor. Code of Federal Regulations. 29 CFR 1910.1003. Http://www.osha-slc.gov/OshStd_data/1910_1003.html. May 02, 2001.
*OTA. 1990. Neurotoxicity: Identifying and controlling poisons of the nervous system. Washington, DC: Office of Technology Assessment, U.S. Congress. OTA-BA-436.
*Owen GM, Brozek J. 1966. Influence of age, sex, and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human Development. Philadelphia, PA: WB Saunders, 222–238.
Painter RB. 1978. DNA synthesis inhibition in HeLa cells as a simple test for agents that damage human DNA. J Environ Pathol Toxicol 2:65–78.722225
*Parodi SM, Taningher M, Russo P, 1981. DNA-damaging activity in vivo and bacterial mutagenicity of sixteen aromatic amines and azo-derivatives, as related quantitatively to their carcinogenicity. Carcinogenesis 2:1317–1326.7034987
*Peiperl MD, Prival MJ, Bell SJ. 1995. Determination of combined benzidine in FD&C yellow No.6 (sunset yellow FCF). Food Chem Toxicol 33(10):829–839.7590527
*Percy AJ, Moore N, Chipman JK. 1989. Formation of nuclear anomalies in rat intestine by benzidine and its biliary metabolites. Toxicology 57:217–223.2749748
Pereira MA, Chang LW. 1981. Binding of chemical carcinogens and mutagens to rat hemoglobin. Chem Biol Interact 33:301–305.7460070
Perera F, Brennan T, Fouts JR. 1989. Comment of the significance of positive carcinogenicity studies using gavage as the route of exposure. Environ Health Perspect 79:315–321.2707209
*Peters JH, Gordon GR, Lin E, 1990. Polymorphic N-acetylation of sulfamethazine and benzidine by human liver: Implication for cancer risk? Anticancer Res 10:225–230.2334132
*Petry TW, Eling TE, Chiu AL, 1988. Ram seminal vesicle microsome-catalyzed activation of benzidine and related compounds: Dissociation of mutagenesis from peroxidase-catalyzed formation of DNA-reactive material. Carcinogenesis 9(1):51–57.3335047
*Petzold GL, Swenberg JA. 1978. Detection of DNA damage induced in vivo following exposure of rats to carcinogens. Cancer Res 38:1589–1594.647672
*Pfaltz and Bauer Chemicals Catalog. 1999. Chemicals for research, development, small production and other applications. Waterbury, CT: Pfaltz and Bauer, Inc.
*Phillips BJ, Tee AC, Carroll PA, 1990. Chinese hamster ovary (CHO/HPRT) cell mutation assays with EMS, benzo[a]pyrene and benzidine. Mutagenesis suppl 5:15–20.
*Phillipson CE, Ioannides C. 1983. Activation of aromatic amines to mutagens by various animal species including man. Mutat Res 124:325–330.6361543
*Pienta RJ. 1980. Transformation of Syrian hamster embryo cells by diverse chemicals and correlation with their reported carcinogenic and mutagenic activities. In: DeSerres FJ, Hollaender A, eds. Chemical mutagens. Principles and methods for their detection. Volume 6. New York, NY: Plenum Press, 175–202.
Pietri F, Clavel F. 1990. Occupational exposure and cancer of the pancreas: A review. Br J Ind Med 48:583–587.
*Piolatto G, Negri E, LaVeccha C, 1991. Bladder cancer mortality of workers exposed to aromatic amines: An updated analysis. Br J Cancer 63:457–459.2003988
*Pliss GB. 1964. [Carcinogenic properties of benzidine.] Voprosy Onkologi 5:T529–T532. (Russian).
*Prival MJ, Bell SJ, Mitchell VD, 1984. Mutagenicity of benzidine and benzidine-congener dyes and selected monoazo dyes in a modified Salmonella assay. Mutat Res 136:33–47.6371512
*Prival MJ, Mitchell VD. 1982. Analysis of a method for testing azo dyes for mutagenic activity in Salmonella typhimurium in the presence of flavin mononucleotide and hamster liver S9. Mutat Res 97:103–116.7043259
*Prival MJ, Peiperl MD, Bell SJ, 1993. Determination of combined benzidine in FD&C yellow no. 5 (tartrazine), using a highly sensitive analytical method. Food Chem Toxicol 31(10):751–758.8225134
*Quillardet P, DeBellecombe C, Hofnung M. 1985. The SOS Chromotest, a colorimetric bacterial assay for genotoxins: Validation study with 83 compounds. Mutat Res 147:79–95.3889610
Raftos JE, Stewart IM, Lovric VA. 1986. Supernatant hemoglobin determinations after prolonged blood storage. Pathology 18:123–126.3725420
*Rao KV N, Rust JH, Mihailovich N, 1971. Subacute toxicity of benzidine in the young adult mice [Abstract]. Fed Proc 30(1):444.
Rapp NS, Zenser TV, Brown WW, 1980. Metabolism of benzidine by a prostaglandin-mediated process in renal inner medullary slices. J Pharmacol Exp Ther 215:401–406.7441505
Reed GA. 1988. Oxidation of environmental carcinogens by prostaglandin H synthase. J Environ Sci Health 2:223–259.
Reynolds SH, Patterson RM, Mennear JH, 1990. ras Gene activation in rat tumors induced by benzidine congeners and derived dyes. Cancer Res 50:266–272.2403837
*Riach CG, Cattanach PJ, Howgate S, 1990. Studies on the activities of benzo[a]pyrene, benzidine and ethyl methanesulphonate in the L5178Y TK+/- mouse lymphoma mutagenicity assay using standardized and non-standardized protocols. Mutagenesis suppl 5:35–44.
Riffelmann M, Mueller G, Schmieding W, 1995. Biomonitoring of urinary aromatic amines and arylamine hemoglobin adducts in exposed workers and nonexposed control persons. Int Arch Occup Environ Health 68:36–43.8847111
*Riggin RM, Howard CC. 1979. Determination of benzidine, dichlorobenzidine, and diphenylhydrazine in aqueous media by high performance liquid chromatography. Anal Chem 51(2):210–214.
*Rinde E, Troll W. 1975. Metabolite reduction of benzidine-containing azo dyes to benzidine in the Rhesus monkey. J Natl Cancer Inst 55(1):181–182.808635
*Ringer DP, Norton TR. 1988. Hepatocarcinogen lowering of rat liver aryl sulfotransferase activity. In: King CM, Romano LJ, Schuetzle D, eds. Carcinogenic and mutagenic responses to aromatic amines and nitroarenes: Proceedings of the third international conference of carcinogenic and mutagenic N-substituted aryl compounds, April 25–28, 1987 in Dearborn, MI. New York, NY: Elsevier Science Publishing Company, 259–263.
Ringer DP, Panzeter PL, DeCicco LA. 1997. Alterations in epidermal growth factor binding to hepatic membranes following dietary exposure of rats to known hepatocarcinogens. Toxicol Lett 91:7–12.9096280
Rochkind ML. 1983. Biotransformation and mutagenicity of benzidine [Abstract]. Diss Abstr Int 45:470B.
Rooks SC F, Stern F, Stringer W, 1985. Risk assessment of a cohort exposed to aromatic amines. J Occup Med 27:115–121.3884754
Rosenkranz HS, Klopman G. 1990. Structural basis of carcinogenicity in rodents of genotoxicants and non-genotoxicants. Mutat Res 228:105–124.
Rosenkranz HS, Ennever FK, Dimayuga, 1990. Significant differences in the structural basis of the induction of sister chromatid exchanges and chromosomal aberrations in Chinese hamster ovary cells. Environ Mol Mutagen 16:149–177.2209572
*Rothman N, Bhatnagar VK, Hayes RB, 1996a. The impact of interindividual variation in NAT2 activity on benzidine urinary metabolites and urothelial DNA adducts in exposed workers. Proc Natl Acad Sci USA 93:5084–5089.8643532
*Rothman N, Hayes RB, Zenser TV, 1996b. The glutathione S-transferase M1 (GSTM1) null genotype and benzidine-associated bladder cancer, urine mutagenicity, and exfoliated urothelial cell DNA adducts. Cancer Epidemiol Biomarkers Prev 5:979–983.8959320
*Rothman N, Talaska G, Hayes RB, 1997. Acidic urine pH is associated with elevated levels of free urinary benzidine and N-acetylbenzidine and urothelial cell DNA adducts in exposed workers. Cancer Epidemiol Biomarkers Prev 6:1039–1042.9419400
*Roussel R, Gaboury A, Lariviere C. 1991. Aromatic amines in the workplace atmosphere of an aluminum smelter. In: Rooy EL, ed. Light metals. Warrendale, PA: The Minerals, Metals, and Materials Society, 503–507.
Roy SK, Kulkarni AP. 1994. Dioxygenase and co-oxidase activities of rat hepatic cytosolic lipoxygenase. J Biochem Toxicol 9:171–179.7853351
Roy SK, Kulkarni AP. 1996. Isolation and some properties of dioxygenase and co-oxidase activities of adult human liver cytosolic lipoxygenase. J Biochem Toxicol 11:161–174.9062846
*Roy WR, Griffin RA. 1985. Motility of organic solvents in water-saturated soil materials. Environmental Geology and Water Sciences 7(4):241–247.
Roy WR, Griffin RA. 1987. Vapor-phase movement of organic solvents in the unsaturated zone. Environmental Institute for Waste Management Studies. University of Alabama. Open file report no. 16.
Ruirong Q 1983. [Exfoliative cytology from the urinary tract of workers exposed to benzidine - a four years observation.] Chin J Oncology 3:189 Abstract in English. (Chinese).
Sabbioni G, Schutze D. 1998. Hemoglobin binding of bicyclic aromatic amines. Chem Res Toxicol 11:471–483.9585478
*Saffiotti U, Cefis F, Montesano R, , eds. 1967. Induction of bladder cancer in hamsters fed aromatic amines. In: Bladder cancer: A symposium. Birmingham, AL: Aesculapius Publishing Company, 129–135.
Samuels SW. 1981. The international context of carcinogen regulation: Benzidine. In: Peto R, Scheiderman M, eds. Banbury report 9: Quantification of occupational cancer. Cold Spring Harbor, NY: Cold Spring Harbor Laboratory, 497–512.
*Sanderson BJ, Clark AM. 1993. Micronuclei in adult and foetal mice exposed in vivo to heliotrine, urethane, monocrotaline and benzidine. Mutat Res 285:27–33.7678129
*Sarkar FH, Radcliff G, Callewaert DM, 1990. Mutagenic response of mouse lymphoma cells after activation of benzidine and 2-aminofluorene with purified prostaglandin H synthase. Mutat Res 242:319–328.2123966
Sax NI, Lewis RJ, eds. 1987. Hawley's condensed chemical dictionary, eleventh edition. New York, NY: Van Nostrand Reinhold Co.
*Schieferstein G. 1982. Serial sacrifice study on benzidine in mice. Jefferson, AR: National Center for Toxicological Research, Nutrition & Chemical Evaluation Branch, Division of Chemical Toxicology. PB 86–116043.
Schieferstein GJ, Sheldon WG, Allen RR, 1990. Oncogenic evaluation of 3,3'-dimethoxybenzidine dihydrochloride in BALB/c mice. J Am College Toxicol 9:71–77.
*Schmidt-Blelk F, Haberland W, Klein AW, 1982. Steps towards environmental hazard assessment of new chemicals (including a hazard ranking scheme, based upon Directive 79/S31/EEC). Chemosphere 11(4):383–415.
Schulte PA, Ringen K, Hemstreet GP, 1985. Risk assessment of a cohort exposed to aromatic amines. J Occup Med 27:115–121.3884754
Schulte PA, Ringen K, Hemstreet GP, 1986. Risk factors for bladder cancer in a cohort exposed to aromatic amines. Cancer 58:2156–2162.3756832
Schulte PA, Ward E, Boeniger M, 1988. Occupational exposure to N-substituted aryl compounds. In: King CM, Romano IJ, Schuetzle D, eds. Carcinogenic and mutagenic responses to aromatic amines and nitroarenes, 15.
*Sciarini IJ, Meigs JW. 1958. The biotransformation of benzidine (4,4'-diaminobiphenyl), and industrial carcinogen, in the dog. I. AMA Arch Ind Health 18:521–530.13593889
*Sciarini IJ, Meigs JW. 1961. The biotransformation of benzidine: II. Studies in mouse and man. Arch Environ Health 2:423–428.13749285
*Setchell BP, Waites GMH. 1975. The blood testis barrier. In: Creep RO, Astwood EB, Geiger SR, eds. Handbook of physiology: Endocrinology V. Washington, DC: American Physiological Society, 143–172.
*Shah PV, Guthrie FE. 1983. Dermal absorption of benzidine derivatives in rats. Bull Environ Contam Toxicol 31:73–78.6882943
Shear NM, Schmidt CW, Huntley SL, 1996. Evaluation of the factors relating combined sewer overflows with sediment contamination of the lower Passaic river. Mar Pollut Bull 32:288–304.
Shelby MD, Zeiger E. 1990. Activity of human carcinogens in the Salmonella and rodent bone-marrow cytogenetic tests. Mutat Res 234:257–261.2366790
Shields PG, Harris CC. 1990. Environmental causes of cancer. Environ Med 74:263–276.
Shimada T, Hayes CL, Yamazaki H, 1996. Activation of chemically diverse procarcinogens by human cytochrome P-450 1B1. Cancer Res 56:2979–2984.8674051
Shimada T, Iwasaki M, Martin MV, 1989. Human liver microsomal cytochrome P-450 enzymes involved in the bioactivation of procarcinogens detected by umu gene response in Salmonella typhimurium TA1535/pSK1002. Cancer Res 49:3218–3228.2655891
*Shinka T, Miyai M, Sawada Y, 1995. Factors affecting the occurrence of urothelial tumors in dye workers exposed to aromatic amines. Int J Urol 2:243–248.8564742
*Shinka T, Ogura H, Morita T, 1998. Relationship between glutathione S-transferase M1 deficiency and urothelial cancer in dye workers exposed to aromatic amines. J Urol 159:380–383.9649243
*Shinka T, Sawada Y, Morimoto S, 1991. Clinical study on urothelial tumors of dye workers in Wakayama City. J Urol 146:1504–1507.1942328
*Siemiatycki J, Dewar R, Nadon L, 1994. Occupational risk factors for bladder cancer: Results from a case-control study in Montreal, Quebec, Canada. Am J Epidem 140(12):1061–1080.
*Simmon VF, Shepherd GF. 1981. Mutagenic activity of 42 coded compounds in the Salmonella/microsome assay. Prog Mut Res 1:333–342.
*Sinsheimer JE, Hooberman BH, Das SK, 1992. The in vivo and in vitro genotoxicity of aromatic amines in relationship to the genotoxicity of benzidine. Mutat Res 268:255–264.1379332
*Sittig M, ed. 1991. Handbook of toxic and hazardous chemicals and carcinogens. 3rd ed. Park Ridge, NY: Noyes Publications.
Skipper PL, Tannenbaum SR. 1994. Molecular dosimetry of aromatic amines in human populations. Environ Health Perspect 102(Suppl 6):17–21.
Skipper PL, Obiedzinski MW, Tannenbaum SR, 1985. Identification of the major serum albumin adduct formed by 4-aminobiphenyl in vivo in rats. Cancer Res 45:5122–5127.4027989
*Smith BJ, Curtis JF, Eling TE. 1991. Bioactivation of xenobiotics by prostaglandin H synthase. Chem Biol Interact 79:245–264.1913972
Smith BJ, DeBruin L, Josephy PD, 1992. Mutagenic activation of benzidine requires prior bacterial acetylation and subsequent conversion by prostaglandin H synthase to 4-nitro-4'-(acetylamino)biphenyl. Chem Res Toxicol 5:431–439.1504268
Smith JN, Ioannides C. 1987. Cytosolic potentiation of the rat hepatic microsome mediated mutagenicity of benzidine. Mutagenesis 2:205–209.3325744
*Snyder RD, Matheson DW. 1985. Nick translation - A new assay for monitoring DNA damage and repair in cultured human fibroblasts. Environ Mutagen 7:267–279.3899625
Sobles FH. 1985. Comparative chemical mutagenesis; well designed and well assessed. Mutat Res 157:107–110.3927159
*Solomon DH, Loft BC, Swift JD. 1968. Reactions catalyzed by minerals IV. The mechanism of the benzidine blue reaction on silicate minerals. Clay Minerals 7:389–397.
*Sorlie T, Martel-Planche G, Hainaut P, 1998. Analysis of p53, p16MTS1, p21WAF1, and H-ras in archived bladder tumours from workers exposed to aromatic amines. Br J Cancer 77(10):1573–1579.9635831
*Speck WT, Santella RM, Rosenkranz HS. 1978. An evaluation of the prophage λ induction (inductest) for the detection of potential carcinogens. Mutat Res 54:101–104.353543
*Spitz S, Maguigan WH, Dobriner K. 1950. The carcinogenic action of benzidine. Cancer 3:789–804.14772711
Sram RJ. 1998. Effect of glutathione S-transferase M1 polymorphisms on biomarkers of exposure and effects. Environ Health Perspect 106:231–239.
*SRI. 1988. Stanford Research Institute International. Directory of chemical producers United States of America. Palo Alto, CA: SRI International, 559.
SRI. 1994. Stanford Research Institute international. Directory of chemical producers United States of America. Palo Alto, CA: SRI International, 569, 804, 978, 997–998.
*SRI. 2000. Stanford Research Institute International. Directory of chemical producers United States of America. Palo Alto, CA: SRI International.
*Staples CA, Werner AF, Hoogheem TJ. 1985. Assessment of priority pollutant concentrations in the United States using STORET database. Environ Toxicol Chem 4:131–142.
*STAPPA/ALAPCO. 1999. State and Territorial Air Pollution Program Administrators/Association of Local Air Pollution Control Officials. Washington, D.C. Http://www.4cleanair.org/states.html#NorthC. May 6, 1999.
Steenland K, Burnett C, Osorio AM. 1987. A case-control study of bladder cancer using city directories as a source of occupational data. Am J Epidemiol 126:247–257.3605053
*Steinmetz KL, Green CE, Bakke JP, 1988. Induction of unscheduled DNA synthesis in primary cultures in rat, mouse, hamster, monkey, and human hepatocytes. Mutat Res 206:91–102.3137465
Stern FB, Murthy LI, Beaumont JJ, 1985. Notification and risk assessment for bladder cancer of a cohort exposed to aromatic amines. J Occup Med 27:495–500.4032086
*Stutz DR, Janusz SJ, eds. 1988. Hazardous materials injuries, a handbook for pre-hospital care. 2nd ed. Beltsville, Maryland: Bradford Communications Corporation.
*Sung H, Araki S, Tanigawa T, 1995. Selective decrease of the suppressor-inducer (CD4^+^CD45RA^+^)T lymphocytes in workers exposed to benzidine and beta-napthylamine. Arch Environ Health 50(3):196–199.7618953
*Suter W, Negro L, Barrera I, 1992. Resistance to pseudomonas toxin A: A sensitive marker to screen for mutagenic substances using V79 cells. Mutagenesis 7(2):125–135.1579068
*Swenberg JA, Petzold GL, Harbach PR. 1976. In vitro DNA damage/alkaline evaluation assay for predicting carcinogenic potential. Biochem Biophys Res Commun 72(2):732–738.985507
*Tabak HH, Barth EF. 1978. Biodegradability of benzidine in aerobic suspended growth reactors. J Water Pollut Control Fed 50:552–558.
Takemura N, Akiyama T, Nakajima C. 1965. A survey of the pollution of the Sumida River, especially on the aromatic amines in the water. Int J Air Water Pollut 9:665–670.
*Talaska G, Au WW, Ward JB Jr, 1987. The correlation between DNA adducts and chromosomal aberrations in the target organ of benzidine exposed, partially-hepatectomized mice. Carcinogenesis 8(12):1899–1905.3677313
Talaska G, Cudnik J, Jaeger M, 1996a. Development and application of non-invasive biomarkers for carcinogen-DNA adduct analysis in occupationally exposed populations. Toxicology 111:207–212.8711736
Talaska G, Underwood P, Maier A, 1996. Polycyclic aromatic hydrocarbons (PAHs), nitro-PAHs and related environmental compounds: Biological markers of exposure and effects. Environ Health Perspect 104(Suppl 5):901–906.8933032
Tanaka KI, Marui S, Mii T. 1980. Mutagenicity of extracts of urine from rats treated with aromatic amines. Mutat Res 79:173–176.7001226
*Tanigawa T, Araki S, Abo T, 1996. Increase in CD57 + CD16-lymphocytes in workers exposed to benzidine and beta-naphthylamine: Assessment of natural killer cell subpopulations. Int Arch Occup Environ Health 69:69–72.9017438
*Tanigawa T, Araki S, Ishizu S, 1990. Natural killer cell activity in workers exposed to benzidine and β-naphthylamine. Br J Ind Med 47:338–341.1972630
*Tatematsu M, Miyata Y, Mizutani M, 1977. Summation effect of N-butyl-N-(4-hydroxybutyl) nitrosamine), N-[4-(5-nitro-2-furyl)-2-thiazolyl] formamide, N-2-fluorenylacetamide, and 3,3'-dichlorobenzidine on urinary bladder carcinogenesis in rats. Gann 68:193–202.892293
*Taylor JA, Li Y, He M, 1996. p53 mutations in bladder tumors from arylamine-exposed workers. Cancer Res 55:294–298.
*Tennakoon DT B, Thomas JB, Tricker MJ, 1974a. Surface and intercalate chemistry of layered silicates. Part I. General introduction and uptake of benzidine and related organic molecules by montmorillonite. Journal of the Chemical Society. Dalton Transactions 20:2207–2211.
*Tennakoon DT B, Thomas JM, Tricker MJ. 1974b. Surface and intercalate chemistry of layered silicates. Part II. An iron-57 Mossbauer study of the role of lattice-substituted iron in the benzidine blue reaction of montmorillonite. Journal of the Chemical Society. Dalton Transactions 20:2211–2215.
*Theng BK G. 1971. Mechanisms of formation of colored clay-organic complexes: A review. Clays and Clay Minerals 19:383–390.
*Tice RR, Erexon GL, Hilliard CJ, 1990. Effect of treatment protocol and sample time on the frequencies of micronucleate polychromatic erthrocytes in mouse bone marrow and peripheral blood. Mutagenesis 5(4):313–321.2118975
Tomatis L, Aitio A, Wilbourn J, 1989. Human carcinogens so far identified. Jpn J Cancer Res 80:795–807.2513295
*TRI87. 1989. Toxic Chemical Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
*TRI90. 1992. Toxic Chemical Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
*TRI92. 1994. Toxic Chemical Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
*TRI96. 1999. Toxic Chemical Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
*TRI99. 2001. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access. Offices of Environmental Information. U.S. Environmental Protection Agency. Toxic Release Inventory. Http://www.epa.gov/triexplorer/. May 8, 2001.
*Trippel-Schulte P, Zeiske J, Kettrup A. 1986. Trace analysis of selected benzidine and diaminodiphenylmethane derivatives in urine by means of liquid chromatography using precolumn sample preconcentration, UV and electrochemical detection. Chromatographia 22:138–146.
*Troll W, Belman S, Rinde E. 1963. N-hydroxy acetylamino compounds, urinary metabolites of aromatic amines in man. Am Assoc Cancer Res 4:68.
Truhaut R. 1990. Recent progresses in toxicological risk evaluation of chemical carcinogens. J Pharm Belg 45:131–140.2192021
*Trzos RJ, Petzold GL, Brunden MN, 1978. The evaluation of sixteen carcinogens in the rat using the micronucleus test. Mutat Res 58:79–86.362195
*Tsuchiya K, Okubo T, Ishizu S. 1975. An epidemiological study of occupational bladder tumours in the dye industry of Japan. Br J Ind Med 32:203–209.1156568
*Tsuda H, Miyata Y, Murasaki G, 1977. Synergistic effect of urinary bladder carcinogenesis in rats treated with N-butyl-N-(4-hydroxybutyl)nitrosamine, N-[14-(5-nitro-2-furyl)- 2-thiazolyl]-formamide, N-2-fluorenylacetamide, and 3,3'-dichlorobenzidine. Gann 68:183–192.892292
*UATW. 1999. Unified Air Toxics Website. U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards. Http://www.epa.gov/ttnuatw1/uatwn.html. May 6, 1999.
*USC. 2001. Hazardous air pollutants. U.S. Code. 42 USC 4712. Http://www4.law.cornell.edu/uscode/42/7412.text.html. May 02, 2001.
U.S. Congress. 1990. Clean Air Act Amendments of 1990. 42 U.S. Code 7412, Title 1, Part A, Sec. 112.53, 826–827.
Ulland BM, Maronpot RR, Lemen JK, 1989. Transplantation studies of preputial gland and epithelial skin neoplasms derived from benzidine-based dye carcinogenicity assays in Fischer 344 male rats. Toxicol Pathol 17(Part 1):50–56.2749136
*Upadhyay S, Gupta VK. 1985. A new reagent system for spectrophotometric determination of benzidine. Am Ind Hyg Assoc J 46(9):524–525.
*Urwin C, Richardson JC, Palmer AK. 1976. An evaluation of the mutagenicity of cutting oil preservative Grotan BK. Mutat Res 40:43–46.1250251
*USITC. 1986. Synthetic organic chemicals. United States production and sales, 1986. Washington DC: U.S. International Trade Commission, publication no. 2009.
USITC. 1990. Synthetic organic chemicals. United States production and sales, 1990. Washington, DC: U.S. International Trade Commission, publication no. 2470.
*USITC. 1994. Synthetic organic chemicals. United States production and sales, 1993. Washington, DC: U.S. International Trade Commission, publication no. 2810.
Uziel M, Munro NB, Katz DS, 1992. DNA adduct formation by 12 chemicals with populations potentially suitable for molecular epidemiological studies. Mutat Res 277:35–90.1376441
*Vanderlaan M, Watkins BE, Stanker L. 1988. Environmental monitoring by immunoassay. Environ Sci Technol 22(3):247–254.22288854
Veleminksy J, Gichner T. 1988. Mutagenic activity of promutagens in plants: Indirect evidence of their activation. Mutat Res 197:221–242.3277041
*Verschueren K. 1983. Handbook of environmental data on organic chemicals. New York, NY: Van Nostrand Reinhold Company, 244–245.
*Vesselinovitch SD, Rao KV, Mihailovich N. 1975. Factors modulating benzidine carcinogenicity bioassay. Cancer Res 35:2814–2819.1157051
*Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238:476–483.8681961
*Vigliani EC, Barsotti M. 1962. Environmental tumors of the bladder in some Italian dye stuff factories. Acta-Unio Internationalis Contra Cancrum 18:669–675.13997151
Vineis P. 1994. Epidemiology of cancer from exposure to arylamines. Environ Health Perspect Suppl 102(6):7–10.
Vineis P, Pirastu R. 1997. Aromatic amines and cancer. Cancer Causes Control 8:346–355.9498898
*Von der Hude W, Behm C, Gurtler R, 1988. Evaluation of the SOS chromotest. Mutat Res 203:81–94.3280989
*Vorce RL, Goodman JI. 1989. Altered methylation of ras oncogenes in benzidine-induced B6C3F1 mouse liver tumors. Toxicol Appl Pharmacol 100:398–410.2551075
Walker R. 1970. The metabolism of azo compounds. A review of the literature. Food Cosmet Toxicol 8:659–676.5500003
Wallace DM. 1988. Occupational urothelial cancer. Br J Urol 61:175–182.3282592
Wallace RE, Josephy PD. 1994. Mutational spectrum of revertants in the hisD3052 allele of Salmonella typhimurium induced by hydrogen peroxide-activated benzidine. Mutat Res 311:9–20.7526179
Walton BT, Hendericks MS, Anderson TA, 1988. Treatability of hazardous chemicals in soils: Volatile and semivolatile organics. Springfield VA: National Technical Information Service, U.S. Department of Commerce. DE89–016892.
Wang CY, Morton KC, Zukowski K, 1986. Activation of metabolites of benzidine (BZ) and 4,4'-methylene-bis(2-chloroaniline) (MDCA) by cultured urothelium of various species. Toxicol Lett 31(Suppl):219.3726898
*Wang CY, Yamada H, Morton KC, 1988. Induction of repair synthesis of DNA in mammary and urinary bladder epithelial cells by n-hydroxy derivatives of carcinogenic arylamines. Cancer Res 48:4227–4232.3390817
*Wang CY, Zukowski K, Yamada H, 1990. Production of urothelial tumors in the heterotopic bladder of rat by benzidine derivatives. Cancer Res 50:2868–2871.2110501
Wang CY, Zukowski K, Yamada H, 1991. Production of bladder tumors in the rat by benzidine metabolites. Pharmacol Clin Pharmacol 8:267–274.
Weast RC, ed. 1985. CRC handbook of chemistry and physics. 66th ed. Boca Raton, FL: CRC Press.
*Weber EJ. 1991. Studies of benzidine-based dyes in sediment-water systems. Environ Toxicol Chem 10:609–618.
Weber WW, Hein DW, Litwin A, 1983. Relationship of acetylator status to isoniazid toxicity, lupus erythematosus, and bladder cancer. FASEB, Controversy in Pharmacology, 1983.
*West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
*Whysner J, Verna L, Williams GM. 1996. Benzidine mechanistic data and risk assessment: Species-and organ-specific metabolic activation. Pharmacol Ther 71(1/2):107–126.8910951
*Widdowson EM, Dickerson JW T. 1964. Chapter 17: Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise. Volume II: The elements Part A. New York, NY: Academic Press.
*Wilkins JR, Sinks T. 1990. Parental occupation and intracranial neoplasms of childhood: Results of a case-control interview study. Am J Epidemiol 132(2):275–292.2372007
*Williams GM. 1978. Further improvements in the hepatocyte primary culture DNA repair test for carcinogens: Detection of carcinogenic biphenyl derivatives. Cancer Lett 4:69–75.647653
Williams GM, Mori H, McQueen CA. 1989. Structure-activity relationships in the rat hepatocyte DNA-repair test for 300 chemicals. Mutat Res 221:263–286.2682231
Williams MI, deRaat WK. 1985. Mutagenicity of urine and feces after treatment of rats with known genotoxins. Carcinogenesis 6:967–976.3893784
Windholz M, ed. 1983. The Merck index. Tenth edition. Rahway, NJ: Merck & Co., Inc.
Windmill KF, Mckinnon RA, Zhu X, 1997. The role of xenobiotic metabolizing enzymes in arylamine toxicity and carcinogenesis: Functional and localization studies. Mutat Res 376:153–160.9202751
Wise RW, Zenser TV, Davis BB. 1983. Prostaglandin H synthase metabolism of the urinary bladder carcinogens benzidine and ANFT. Carcinogenesis 4:285–289.6299601
Wise RW, Zenser TV, Davis BB. 1984a. Characterization of benzidinediimine: A product of peroxidase metabolism of benzidine. Carcinogenesis 5:1499–1503.6488474
Wise RW, Zenser TV, Davis BB. 1984b. Oxidation of the carcinogen benzidine to free radical cations may initiate the carcinogenic process [Abstract]. Fed Proc 43:589.
Wise RW, Zenser TV, Davis BB. 1985. Prostaglandin H synthase oxidation of benzidine and o-dianisidine: Reduction and conjugation of activated amines by thiols. Carcinogenesis 5:579–583.
*Wise RW, Zenser TV, Kadlubar FF, 1984c. Metabolic activation of carcinogenic aromatic amines by dog bladder and kidney prostaglandin H synthase. Cancer Res 44:1893–1897.6424934
Wise RW, Zenser TV, Rice JR, 1986. Peroxidatic metabolism of benzidine by intact tissue: A prostaglandin H synthase-mediated process. Carcinogenesis 7:111–115.3080249
*Wu W. 1988. Occupational cancer epidemiology in the People's Republic of China. J Occup Med 30(12):968–974.3068337
*Wyrobek A, Gordon L, Watchmaker G. 1981. Effect of 17 chemical agents including 6 carcinogen/noncarcinogen pairs on sperm shape abnormalities in mice. Prog Mut Res 1:712–717.
*Xue-Yun Y, Ji-Gang C, Yong-Ning H. 1990. Studies on the relation between bladder cancer and benzidine or its derived dyes in Shanghai. Br J Ind Med 47:544–552.2393635
Yamashita R, Tomimoto T, Nakamura Y. 1994. Acceleration of DNA cleavage by benzidine derivatives under weakly acidic conditions. Chem Pharm Bull 42:1455–1458.
Yamazoe Y, Roth RW, Kadlubar FF. 1986. Reactivity of benzidine diimine with DNA to form N-(deoxyguanosin-8-yl)-benzidine. Carcinogenesis 7:179–182.3943140
*Yamazoe Y, Zenser TV, Miller DW, 1988. Mechanism of formation and structural characterization of DNA adducts from peroxidative activation of benzidine. Carcinogenesis 9(9):1635–1641.3136947
*Yasunaga Y, Nakanishi H, Naka N, 1997. Alterations of the p53 gene in occupational bladder cancer in workers exposed to aromatic amines. Lab Invest 77(6):677–684.9426406
*Yoshida O. 1971. [Bladder cancer in workers of the dyeing industry.] Igaku No Ayumi 79:421–422. (Japanese)
*Yoshida O, Miyakawa M. 1973. Etiology of bladder cancer: Metabolic aspects. In: Analytical and experimental epidemiology of cancer. Baltimore, MD: University Park Press, 31–39.
*Yoshida O, Miyakawa M, Okada Y, 1981. The disintegration of a benzidine dye, direct deep black ex, by Escherichia coli and soil bacteria. In: Overcash MR, ed. Decomposition of toxic and nontoxic organic compounds in soil. Ann Arbor, MI: Ann Arbor Science Publication, 227–231.
Zabezhinskii MA. 1967. In: Current problems in oncology (Leningrad, USSR) 117.
*Zabezhinskii MA. 1970. Effectiveness of inhalation as a method of administration of atomized carcinogens. Bull Exp Biol Med 69:68–70.
*Zavon MR, Hoegg U, Bingham E. 1973. Benzidine exposure as a cause of bladder tumors. Arch Environ Health 27:1–7.4709106
*Zeiger E, Anderson B, Haworth S, 1992. Salmonella mutagenicity tests: V. Results from the testing of 311 chemicals. Environ Mol Mutagen 19(suppl 21):2–141.1541260
*Zenser TV, Davis BB. 1990. Oxidation of xenobiotics by prostaglandin H synthase. In: Goldstein RS, ed. Toxic interactions. San Diego, CA: Academic Press, Inc., 61–86.
*Zenser TV, Lakshmi VM, Davis BB. 1998. 1996 ASPET N-glucuronidation of xenobiotics symposium: N-glucuronidation of benzidine and its metabolites. Role in bladder cancer. Drug Metab Dispos 26(9):856–859.9733663
*Zenser TV, Lakshmi VM, Rustan TD, 1996. Human N-acetylation of benzidine: Role of NAT1 and NAT2. Cancer Res 56:3941–3947.8752161
*Zenser TV, Mattammal MB, Armbrecht HJ, 1980. Benzidine binding to nucleic acids mediated by the peroxidative activity of prostaglandin endoperoxide synthetase. Cancer Res 40:2839–2845.6771007
Zenser TV, Mattammal MB, Davis BB. 1979. Cooxidation of benzidine by renal medullary prostaglandin cyclooxygenase. J Pharmacol Exp Ther 211(3):460–464.117096
*Zenser TV, Mattammal MB, Wise RW, 1983. Prostaglandin H synthase-catalyzed activation of benzidine: A model to assess pharmacologic intervention of the initiation of chemical carcinogenesis. J Pharmacol Exp Ther 227(3):545–550.6418878
*Zhao S-L, Wei FS, Zou HF, 1998. Determination of arylamine compounds in waste water using solid-phase extraction and reversed-phase high performance liquid chromatography. J Liquid Chromatogr Rel Technol 21(5):717–724.
*Zhong S, Wyllie AH, Barnes D, 1993. Relationship between the GSTM1 genetic polymorphism and susceptibility to bladder, breast, and colon cancer. Carcinogenesis 14(9):1821–1824.8403204
*Zhou Q, Talaska G, Jaeger M, 1997. Benzidine-DNA adduct levels in human peripheral white blood cells significantly correlate with levels in exfoliated urothelial cells. Mutat Res 393:199–205.9393612
*Ziegler EE, Edwards BB, Jensen RL 1978. Absorption and retention of lead by infants. Pediatr Res 12:29–34.643372
Ziegler DM, Ansher SS, Nagata T, 1988. N-methylation: Potential mechanism for metabolic activation of carcinogenic primary arylamines. Proc Natl Acad Sci (USA) 85:2514–2517.3357879
*Zierath DL, Hassett JJ, Banwart WL, 1980. Sorption of benzidine by sediments and soils. Soil Sci 129(5):277–281.
*Zwirner-Baier I, Neumann HG. 1998. Biomonitoring of aromatic amines: V. Acetylation and deacetylation in the metabolic activation of aromatic amines as determined by haemoglobin binding. Arch Toxicol 72:499–504.9765065