# 8 REGULATIONS AND ADVISORIES

International, national, and state regulations and advisories regarding benzidine in air, water, and other media are summarized in Table 8-1. These values have been established because of benzidine’s potential to cause adverse health effects in exposed people.

The EPA (IRIS 2001) has calculated a chronic oral Reference Dose (RfD) for benzidine of 3×10^−3^ mg/kg/day based on a LOAEL of 2.7 mg/kg/day for brain cell vacuolization and liver cell alterations observed in female mice exposed for their lifetimes to 20 ppm benzidine dihydrochloride in the drinking water (Littlefield et al. 1983). A NOAEL was not established. The LOAEL of 2.7 mg/kg/day benzidine was divided by uncertainty factors of 10 for extrapolation from animals to humans, 10 for human variability in sensitivity, and 10 for the uncertainty in estimating a NOAEL from a LOAEL. The EPA (IRIS 2001) has derived an inhalation cancer slope factor of 2.3×10^2^ (mg/kg/day)^−1^ based on the incidence of bladder cancer in workers exposed to benzidine as reported by Zavon et al. (1973). An oral slope factor of 2.3×10^2^ (mg/kg/day)^−1^ was also estimated from the inhalation exposure data (IRIS 2001).

Benzidine is on the list of chemicals appearing in "The Emergency Planning and Community Right-to-Know Act of 1986" (EPCRA) (EPA 1988a). Section 313 of Title III of EPCRA requires owners and operators of certain facilities that manufacture, import, process, or otherwise use the chemicals on this list to report annually their release of those chemicals to any environmental media.

OSHA standards strictly regulate the use of a solid or liquid mixture containing less than 0.1 percent by weight or volume of benzidine (29CFR 1910.1003). No permissible exposure limit (PEL) is established.

Under the Resource Conservation and Recovery Act (RCRA), benzidine is listed as a hazardous waste when it is a discarded commercial product, off-specification species, container residue, or spill residue thereof (EPA 1980b).

Table 8-1 Regulations and Guidelines Applicable to Benzidine

Agency | Description | Information | References
[underlined: INTERNATIONAL]
Guidelines:
IARC | Carcinogenicity classification | Group 1^a^ | IARC 2001
[underlined: NATIONAL]
Regulations and Guidelines:
a. Air
ACGIH | Carcinogenicity classification^b^ | A1^c^ | ACGIH 2000
EPA | National emission standards for HAP’s for source categories—demonstration of early reduction of high-risk pollutants | | EPA 2001e 40CFR63.74
NIOSH | REL not established | potential carcinogen | NIOSH 1999
OSHA | PEL not established | carcinogen | OSHA 2001 29CFR1910.1003
USC | HAP | | USC 2001 42USC7412
b. Water
EPA | Electroplating point source category | >1×10^−2^ mg/L | EPA 2000a 40CFR413.02(i)
| Metal finishing point source category | >1×10^−2^ mg/L | EPA 2000b 40CFR433.11(e)
| Toxic pollutant effluent standards | | EPA 2000c 40CFR129.104
| Ambient water criterion | 0.1 μg/L
| Benzidine manufacturer
| calculated over 1-month | 10 μg/L
| monthly average daily loading | 0.130 kg/kkg
| sample representing any work day | 50 μg/L
| Benzidine based-dye applicators
| calculated over 1-month | 10 μg/L
| sample representing any work day | 25 μg/L
EPA | Toxic pollutant effluent standards—regulated toxic pollutant | | EPA 2001h 40CFR129.4
| Water quality criteria for human health for consumption of: | | EPA 1999a
| Water and organism | 1.2×10^−4^ μg/L^d^
| Organism only | 5.4×10^−4^ μg/L^d^
c. Food
FDA | Limit in color additives for foods | | FDA 2000a 21CFR74.705
| FD&C Yellow No. 5 | ≤1ppb | FDA 2000a 21CFR74.705
| Limit in color additives for foods | | FDA 2000b 21CFR74.706
| FD&C Yellow No. 6 | ≤1ppb | FDA 2000b 21CFR74.706
d. Other
DOT | Reportable quantity | 1 pound | DOT 2001 49CFR172.101 Appendix A
EPA | Carcinogenicity classification | Group A^e^ | EPA 2001a
| Cancer slope factor (inhalation and oral) | 2.3×10^2^ (mg/kg/day)^−1^
| Carcinogenic inhalation unit risk | 6.7×10^−2^ (μg/m^3^)^−1^ | IRIS 2001
| Carcinogenic drinking water unit risk | 6.7×10^−3^ (μg/L)^−1^
| CERCLA—toxic pollutant | Subject to section 307(a) of CERCLA | EPA 2000d 40CFR401.15
| Community Right-to-Know; toxic chemical release reporting—effective date | 01/01/87 | EPA 1999c 40CFR372.65
| Health and environmental protection standards at uranium and thorium tail millings—listed constituent | | EPA 2001b 40CFR192 Appendix I
| Health based limits for exclusion of waste-derived residues—concentration limit for residue | 1×10^−6^ mg/kg | EPA2001c 40CFR266 Appendix VII
EPA | Identification and listing of hazardous waste—discarded commercial chemical containers, off-specification species, container residues, and spill residues | U021 | EPA 2000e 40CFR261.33
| Identification and listing of hazardous waste—comparable/Syngas fuel exclusion | | EPA 2001d 40CFR261.38
| Minimum required detection limit | 2,400 mg/kg
| Reportable quantity | 1 pound | EPA 1999b 40CFR302.4
| RfD | 3×10^−3^ mg/kg/day | IRIS 2001
| Risk specific doses | | EPA 2001f 40CFR266 Appendix V
| Unit risk | 6.7×10^−2^ μg/L | EPA 2001f 40CFR266 Appendix V
| RsD | 1.5×10^−4^ μg/L | EPA 2001f 40CFR266 Appendix V
| Steam electric power generating point source category—priority pollutants | | EPA 2001g 40CFR423 Appendix A
| TSCA—health and safety data reporting | | EPA 2001i 40CFR716.120
| Effective date | 06/01/87
| Sunset date | 06/01/87
| TSCA—significant new uses of chemical substances | | EPA 2001j 40CFR721.1660
| TSD facilities—compounds with a Henry’s law constant | less than 0.1 Y/K | EPA 2001k 40CFR265 Appendix VI
[underlined: STATE]
Regulations and Guidelines:
a. Air
Georgia | Instream concentration | 5.35×10^−4^ μg/L | GDNR 2000
Kansas | Ambient air quality standard | 3×10^−4^ tons/year | CDC 1999
b. Water
Arizona | Drinking water guideline | 1×10^−4^ μg/L | HSDB 2001
Florida | Drinking water guideline | 250 μg/L | HSDB 2001
New Hampshire | Drinking water guideline | 2×10^−4^ μg/L | HSDB 2001
c. Food | | No data
d. Other | | No data

a Group A1: sufficient evidence for carcinogenicity in animals and humans

b Skin notation: danger of cutaneous absorption

c Group A: human carcinogen

d This criterion is based on carcinogenicity of 10^−6^ risk. Alternate risk levels may be obtained by moving the decimal point (e.g., for a risk level of 10^−5^, move the decimal point in the recommended criterion one place to the right).

e Group A: human carcinogen

ACGIH = American Conference of governmental Industrial Hygienists; CDC = Center for Disease Control; CERCLA = Comprehensive Environmental Response, Compensation, and Liability Act; CFR = Code of Federal Regulations; DOT = Department of Transportation; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; GDNR = Georgia Department of Natural Resources; HAP = hazardous air pollutant; HSDB = Hazardous Substances Data Bank; IARC = International Agency for Research on Cancer; IRIS = Integrated Risk Information System; NIOSH = National Institute of Occupational Safety and Health; OSHA = Occupational Safety and Health Administration; PEL = permissible exposure limit; REL = recommended exposure limit; RfD = oral reference dose; RsD = risk specific dose; TSCA = Toxic Substances Control Act; TSD = transport, storage, and disposal; USC = United States Code