# 4 CHEMICAL AND PHYSICAL INFORMATIONs

## 4.1 CHEMICAL IDENTITY

Table 4-1 lists common synonyms, trade names and other pertinent identification information for benzidine.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Table 4-2 lists important physical and chemical properties of benzidine.

Table 4-1 Chemical Identity of Benzidine

Characteristic | Information | Reference
Chemical name | Benzidine | HSDB 1999
Synonym(s) | 4,4’-Bianiline; 4,4’-Diphenyldiamine; 4,4’-Diaminobiphenyl; 4,4’-Diphenylenediamine; (1,1’-Biphenyl)-4,4’-diamine; C.I. Azoic Diazo Component 112 | IARC 1982a; HSDB 1999
Registered trade name(s) | Fast Corinth Base B | IARC 1982a
Chemical formula | C_12_H_12_N_2_ | Lide 1998
Chemical structure | [image]
Identification numbers:
CAS Registry | 92-87-5 | Lide 1998
NIOSH RTECS | DC 9625000 | NIOSH 1984c
EPA Hazardous Waste | U021 | HSDB 1999
OHM/TADS | 8100001 | HSDB 1999
DOT/UN/NA/IMCO shipping | UN 1885; IMO Class 6.1 | HSDB 1999; HSDB 1999
HSDB | 948 | HSDB 1999
NCI | C03361 | NLM1988

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECs = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of Benzidine

Property | Information | Reference
Molecular weight | 184.24 | Lide 1998
Color | Grayish-yellow, white or reddish-gray | Lewis 1993
Physical state | Crystalline powder | Budavari et al. 1996
Melting point | 120 °C | Lide 1998
Boiling point | 401 °C | Lide 1998
Specific gravity (20/4 °C) | 1.250 | Verschueren 1983
Odor | No data
Odor threshold:
Air | No data
Water | No data
pK_a_ | 4.3 (monoprotonated); 3.3 (diprotonated) | Zierath et al. 1980
Solubility:
Water at 12 °C | 400 mg/L | Verschueren 1983
at 20 °C | 276 mg/L | EPA 1987b
at 25 °C | 520 mg/L | EPA 1987b
at 100 °C | 9,346 mg/L | Budavari et al. 1996
Organic solvent(s) | 200 g/L (boiling alcohol) | Budavari et al. 1996
| 20 g/L ether | Budavari et al. 1996
Partition coefficients:
Log K_ow_ | 1.34 | Hansch et al. 1995
Log K_oc_ | 1.02–4.9 | EPA 1981b, 1987b; Johnson and Means 1986
Vapor pressure:
25 °C | 7.0×10^−7^ mmHg | Neely and Blau 1985
20 °C | 7.5×10^−9^ mmHg | Schmidt-Blelk et al. 1982
Henry’s law constant
at 25 °C | 5.2×10^−11^ atm-m^3^/mol | Meylan and Howard 1991
Autoignition temperature | No data
Flashpoint | No data
Flammability limits | Does not burn or burns with difficulty | HSDB 1999
Conversion factors at 25 °C | 1 ppm = 0.133 mg/m^3^; 1 mg/m^3^ = 7.52 ppm | IARC 1982a
Explosive limits | No data

pK_a_ = The dissociation constant of the conjugate acid