# 9 REFERENCES

Beyerbach A, Rothman N, Bhatnagar VK, 2006. Hemoglobin adducts in workers exposed to benzidine and azo dyes. Carcinogenesis 27(8):1600–06.16497705
Carreon T, Ruder AM, Schulte PA, 2006. NAT2 slow acetylation and bladder cancer in workers exposed to benzidine. Int J Cancer 118:161–68.16003747
Chen SC, Kao CM, Huang MH, 2003. Assessment of genotoxicity of benzidine and its structural analogues to human lymphocytes using Comet Assay. Toxicol Sci 72:283–88.12660362
Chung KT, Chen SC, Wong TY, 2000. Mutagenicity studies of benzidine and its analogs: structure-activity relationships. Toxicol Sci 56:351–56.10910993
Claxton LD, Hughes TJ, Chung KT. 2001. Using base-specific Salmonella tester strains to characterize the types of mutation induced by benzidine and benzidine congeners after reductive metabolism. Food Chem Toxicol 39:1253–61.11696399
Donaldson FP, Nyman MC. 2005. Sorption of benzidine and 3,3'-dichlorobenzidine to lake sediments. 1. Conceptualization and development of a multiparameter model. Environ Toxicol Chem 24(5):1022–28.16110977
Donaldson FP, Nyman MC. 2006. Short-term interactions of aniline and benzidine with three soils in both natural and artificial matrices. Chemosphere 65:854–62.16650457
Guo WC, Lin GF, Chen JG, 2004. Polymorphism in the N-acetyltransferase 1 alleles NAT1*10 and NAT1*14A and cytological gradings of exfoliated urothelial cells in benzidine-exposed Chinese workers: Discussion of ethnic differences. Arch Toxicol 78(8):425–29.15197537
Harden J, Donaldson FP, Nyman MC. 2005. Concentrations and distribution of 3,3’-dichlorobenzidine and its congeners in environmental samples from Lake Macatawa. Chemosphere 58: 767–77.15621190
Harden J, Jewell A, Donaldson FP, 2006. Benzidine transformation processes in natural sediments. Environ Toxicol Chem 25(8):1969–74.16916013
Hemstreet GP II I, Yin S, Ma Z, 2001. Biomarker risk assessment and bladder cancer detection in a cohort exposed to benzidine. J Natl Cancer Inst 93(6):427–36.11259468
Kim Y, Park J, Shin YC. 2007. Dye-manufacturing workers and bladder cancer in South Korea. Arch Toxicol 81:381–84.17151866
Lin G, Ma Q, Chen J, 2001. Dependence of Papanicolaou gradings of exfoliated urothelial cells upon GSTM1 and GSTT1 polymorphism in benzidine-exposed workers of the Shanghai dye industry. Arch Toxicol 75:544–48.11760815
Lin GF, Guo WC, Chen JG, 2005. An association of UDP-glucuronosyltransferase 2B7 C_802_T (His_268_Tyr) polymorphism with bladder cancer in benzidine-exposed workers in China. Toxicol Sci 85:502–06.15615884
Ma Q, Lin G, Qin Y, 2003. GSTP1 A^1578^G (Ile^105^Val) polymorphism in benzidine-exposed workers: An association with cytological grading of exfoliated urothelial cells. Pharmacogenetics 13:409–15.12835616
Ma QW, Lin GF, Chen JG, 2004. Polymorphism of N-acetyltransferase 2 (NAT2) gene polymorphism in Shanghai population: Occupational and non-occupational bladder cancer patient groups. Biomed Environ Sci 17:291–98.15602826
Miyakawa M, Tachibana M, Miyakawa A, 2001. Re-evaluation of the latent period of bladder cancer in dyestuff-plant workers in Japan. Int J Urol. 8:423–30.11555006
Muneer M, Singh HK, Bahnemann D. 2002. Semiconductor-mediated photocatalysed degradation of two selected priority organic pollutants, benzidine and 1,2-diphenylhydrazine, in aqueous suspension. Chemosphere 49:193–203.12375866
Patel G, Agrawal YK. 2003. Separation and trace estimation of benzidine and its macromolecular adducts using supercritical fluid chromatography. J Chromatogr B 795:157–65.
Rosenman KD, Reilly MJ. 2004. Cancer mortality and incidence among a cohort of benzidine and dichlorobenzidine dye manufacturing workers. Am J Ind Med 46:505–12.15490466
Xiang CQ, Shen CL, Wu ZR, 2007. Detection of mutant p53 protein in workers occupationally exposed to benzidine. J Occup Health 49:279–84.17690521
Zhang DS, Lin GF, Ma QW, 2002. Nonassociation of aryl hydrocarbon receptor genotypes with susceptibility to bladder cancer in Shanghai population. Acta Pharmacol Sin 23(2):188–92.11866883