# 8 REGULATIONS AND ADVISORIES

No updated data.