# 7 ANALYTICAL METHODS

## 7.1 BIOLOGICAL SAMPLES

Patel and Agrawal (2003) used the supercritical fluid chromatography to separate and make trace estimates of benzidine and its macromolecular adducts in blood plasma. Benzidine and its acetylated metabolite, N-OH-N,N’-diacetylbenzidine, were derived from plasma by use of ether. The components were divided by use of the Nucleosil 10 um, Nucleosil-RP-C_18_ column with 7.4% methanol-modified supercritical fluid carbon dioxide as mobile phase. The UV-Vis detector was used for detection. The procedure resulted in a 98.6% mean extraction recovery of benzidine. When compared with the HPLC-UV (ultraviolet) method, the supercritical fluid chromatography was found to be superior with regard to characteristics of sensitivity, specificity, and accuracy.