# 6 POTENTIAL FOR HUMAN EXPOSURE

## 6.3 ENVIRONMENTAL FATE

### 6.3.2 Transformation and Degradation

#### 6.3.2.2 Water

Harden et al. (2005) investigated the release to the environment of benzidine. The investigators conducted an 11-year field study to clarify the fate and behavior of benzidine in the Lake Macatawa sediment-water system, located in Michigan. The results of the field study established that benzidine is conveyed over long distances. In the water phase, the concentration of benzidine was detected at a level approximately 12,300 times higher than the EPA [recommended water quality] guideline (0.000086 ug/l). In the sediment phase, benzidine was detected at levels as high as ∼63 mg/kg (1994) to a low of 0.148 mg /kg (2003). The concentrations of benzidine for both phases have decreased in recent years.

Muneer et al (2002) investigated the photocatalysed degradation of benzidine under a number of conditions, employing a pH-stat technique. The substances were monitored for degradation by examining the change in substrate concentration of the model compound using high pressure liquid chromatography (HPLC) analysis and ascertaining the decrease in total carbon content, respectively, as a function of irradiation time. The degradation kinetics was investigated under different conditions (e.g., reaction pH and substrate and photocatalyst concentration). The degradation rates and the photonic efficiencies were strongly affected by the studied conditions (e.g., reaction pH). Toxicity tests were done for the irradiated samples of benzidine by measuring the luminescence of the Vibrio fischeri bacteria after 30 minutes of incubation. 4-Amino-biphenyl and hydroquinone were found to be intermediate products by GC/MS technique. The investigators are considering probable pathways for the formation of these products.

#### 6.3.2.3 Sediment and Soil

Donaldson and Nyman (2006) investigated the short-term interactions of aniline and benzidine for three soils in natural and artificial matrices. The investigators noted the importance of understanding the fate of aromatic amines in natural systems due to their persistence and toxicity. Laboratory experiments were done on silty-clay, sandy loam, and sandy soils as well as six background matrices (i.e., rainwater, 12.5 mM CaCl_2_, 25 mM CaCl_2_, passing each through soil columns). The study’s intent was to establish the validity of using CaCl_2_ as a laboratory simulation for rainwater and to determine how short-term sorption (24 hours) of aniline and benzidine transformed when passed through the soil columns. Neither of the CaCl_2_ solutions was predictive of the sorption of aniline and benzidine in a rainwater solution. This finding may be attributed to the varying soil properties that may influence sorption. Statistical analysis revealed that rainwater or CaCl_2_ solution through soil columns did not influence significantly the sorption of aniline and benzidine. Cation exchange was shown to play a role in the sorption of both aniline and benzidine under all conditions. Solubility plots demonstrated a higher association for benzidine due to its lower aqueous solubility.

Harden et al. (2006) investigated benzidine transformation processes in natural environmental sediments. The investigators collected water and sediment samples from Lake Macatawa in Michigan and spiked these samples with benzidine. The sediment samples consisted of sandy to silty-clay types. The spiked samples of sediment and water were incubated under anaerobic conditions at 4, 15, and 23° C for 211 d. Degradation of benzidine was investigated over the time-course analysis in the sediment and water mixtures. Gas chromatography/mass spectrometry and liquid chromatography/mass spectrometry revealed three possible metabolites (aniline, 2-ethyl-1-hexanol, and 1-amino-2-hexene). Because no metabolites were seen in autoclaved bottles, it was suggested that the benzidine transformation in the sediment-water mixtures was due to microbial activity. Benzidine was shown to have a higher sorption affinity for the different sediment phases than aniline, its degradation product. Aniline, microbial transformed from benzidine, would be expected to result in a greater concentration in the water phase and a greater chance of transport in the water phase.

Donaldson and Nyman (2005) investigated sorption of benzidine and 3,3’-dichlorobenzidine (DCB) in lake sediments. Benzidine and DCB batch isotherms were produced and evaluated. The sediment samples that were used ranged from sandy to silty-clay soil. The batch isotherms were examined by use of high-performance liquid chromatography. A multiparameter model (MPM) that examined partitioning, covalent bonding, and cation exchange was developed and tested. The MPM was effective in predicting sorption of aromatic amines (benzidine and DCB) to lake sediments. The results indicated that MPM can give a better understanding of the sorption process of aromatic amines than more conventional models.