# 5 PRODUCTION, IMPORT/EXPORT, USE, AND DISPOSAL

No updated data.