# 4 CHEMICAL AND PHYSICAL INFORMATION

No updated data.