# 9 REFERENCES

*Not cited in text

ACGIH. 1996. Benzene. Threshold limit values for chemical substances and physical agents. Biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists, 60, 147.
ACGIH. 2004. Benzene. Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
Adgate JL, Church TR, Ryan AD, . 2004. Outdoor, indoor and personal exposure to VOCs in children. Environ Health Perspect 112(14):1386–1392.15471730
Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27:532–537.4029526
Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
Adlkofer F, Scherer G, Conze C, . 1990. Significance of exposure to benzene and other toxic compounds through environmental tobacco smoke. J Cancer Res Clin Oncol 116(6):591–598.2254377
Agency for Toxic Substances and Disease Registry. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Atlanta, GA: Agency for Toxic Substances and Disease Registry, Division of Toxicology. Fed Regist 54(174):37618–37634.
Agency for Toxic Substances and Disease Registry. 1991. Benzene groundwater exposure study Nesmith, South Carolina. Final report technical assistance to South Carolina Department of Health and Environmental Control. Atlanta, GA: Agency for Toxic Substances and Disease Registry. Division of Health Assessment and Consultation.
Agency for Toxic Substances and Disease Registry. 1995. National exposure registry benzene subregistry baseline technical report. Atlanta, GA: U.S. Department of Health and Human Services. Agency for Toxic Substances and Disease Registry. PB95255766, 1–114.
Agency for Toxic Substances and Disease Registry. 2001. National exposure registry. Benzene subregistry. Baseline through followup 4 technical report. Atlanta, GA: U.S. Department of Health and Human Services. Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/NER/BENZENE/2001/benzene2001.html. July 11, 2005.
AIHA. 1989. Odor thresholds for chemicals with established occupational health standards. Fairfax, VA: American Industrial Hygiene Association, 1, 9, 13, 41, 46.
Aksoy M. 1980. Different types of malignancies due to occupational exposure to benzene: A review of recent observations in Turkey. Environ Res 23:181–190.7428756
Aksoy M. 1987. Chronic lymphoid leukaemia and hairy cell leukaemia due to chronic exposure to benzene: Report of three cases. Br J Haematol 66:209–211.3606957
Aksoy M. 1991. Hematotoxicity, leukemogenicity, and carcinogenicity of chronic exposure to benzene. In: Arinc E, Schenkman JB, Hodgson E, eds. Molecular aspects of monooxygenases and bioactivation of toxic compounds. NATO advanced science institutes series A: Life sciences, Vol. 202. New York, NY: Plenum Press, 415–434.
Aksoy M, Erdem S. 1978. Followup study on the mortality and the development of leukemia in 44 pancytopenic patients with chronic benzene exposure. Blood 52:285–292.667356
Aksoy M, Dincol K, Akgun T, . 1971. Haematological effects of chronic benzene poisoning in 217 workers. Br J Ind Med 28:296–302.5557851
Aksoy M, Dincol K, Erdem S, . 1972. Details of blood changes in 32 patients with pancytopenia associated with long-term exposure to benzene. Br J Ind Med 29:56–64.5060246
Aksoy M, Erdem S, Dincol G. 1974. Leukemia in shoe-workers exposed chronically to benzene. Blood 44:837–841.4529630
*Aksoy M, Erdem S, Erdogan G, . 1976. Combination of genetic factors and chronic exposure to benzene in the aetiology of leukaemia. Hum Hered 26:149–153.950241
Aksoy M, Özeris S, Sabuncu H, . 1987. Exposure to benzene in Turkey between 1983 and 1985: A haematological study on 231 workers. Br J Ind Med 44:785–787.3689711
*Alderson M, Rushton L. 1982. Mortality patterns in eight U.K. oil refineries. Ann N Y Acad Sci 381(1):139–145.6953784
Altman PL, Dittmer DS. 1974. Biological handbooks: Biology data book. Vol. III. 2nd ed. Bethesda, MD: Federation of American Societies for Experimental Biology, 1987–2008, 2041.
Amodio-Cocchieri R, Del Prete U, Cirillo T, . 2001. Evaluation of benzene exposure in children living in Campania (Italy) by urinary trans,trans-muconic acid assay. J Toxicol Environ Health A 63(2):79–87.11393801
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York: Marcel Dekker, Inc., 9–25.
Andersen ME, Clewell HJ III, Gargas ML, . 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87:185–205.3824380
Anderson D, Richardson CR. 1981. Issues relevant to the assessment of chemically induced chromosome damage in vivo and their relationship to chemical mutagenesis. Mutat Res 90:261–272.6799821
Andreoli C, Leopardi P, Crebelli R. 1997. Detection of DNA damage in human lymphocytes by alkaline single cell gel electrophoresis after exposure to benzene or benzene metabolites. Mutat Res 377(1):95–104.9219584
Andrews LS, Lee EW, Witmer CM, . 1977. Effects of toluene on metabolism, disposition, and hematopoietic toxicity of [^3^H] benzene. Biochem Pharmacol 26:293–300.849319
Andrews LS, Sasame HA, Gillette JR. 1979. ^3^H-Benzene metabolism in rabbit bone marrow. Life Sci 25:567–572.502750
Angerer J, Scherer G, Schaller KH, . 1991. The determination of benzene in human blood as an indicator of environmental exposure to volatile aromatic compounds. Fresenius J Anal Chem 339(10):740–742.
Antoine SR, DeLeon IR, O’Dell-Smith RM. 1986. Environmentally significant volatile organic pollutants in human blood. Bull Environ Contam Toxicol 36:364–371.3955247
Aoyama K. 1986. Effects of benzene inhalation on lymphocyte subpopulations and immune response in mice. Toxicol Appl Pharmacol 85:92–101.2941900
Appel BR, Guirguis G, Kim IS, . 1990. Benzene, benzo(a)pyrene, and lead in smoke from tobacco products other than cigarettes. Am J Public Health 80(5):560–564.2327532
Arfellini G, Grilli S, Colacci A, . 1985. In vivo and in vitro binding of benzene to nucleic acids and proteins of various rat and mouse organs. Cancer Lett 28:159–168.4052986
Arinc E, Adali O, Iscan M, . 1991. Stimulatory effects of benzene on rabbit liver and kidney microsomal cytochrome P-450 dependent drug metabolizing enzymes. Arch Toxicol 65(3):186–190.2053845
*Armstrong MJ, Galloway SM. 1993. Micronuclei induced in peripheral blood of E μ-PIM-1 transgenic mice by chronic oral treatment with 2-acetylaminofluorene or benzene but not with diethyl-nitrosamine or 1,2-dichloroethane. Mutat Res 302(1):61–70.7683108
Arvin E, Jensen BK, Gundersen AT. 1989. Substrate interactions during aerobic biodegradation of benzene. Appl Environ Microbiol 55:3221–3225.2619308
Ashley DL, Bonin MA, Cardinali FL. 1992. Determining volatile organic compounds in the human blood from a large sample population by using purge and trap gas chromatography/mass spectrometry. Anal Chem 64:1021–1029.1590585
Ashley DL, Bonin MA, Cardinali FL, . 1994. Blood concentrations of volatile organic compounds in a nonoccupationally exposed US population and in groups with suspected exposure. Clin Chem 40(7):1401–1404.8013127
Astier A. 1992. Simultaneous high-performance liquid chromatographic determination of urinary metabolites of benzene, nitrobenzene, toluene, xylene and styrene. J Chromatogr 573(2):318–322.1601967
Au WW, Anwar WA, Hanania E, . 1990. Antimutagenic effects of dimethyl sulfoxide on metabolism and genotoxicity of benzene in vivo. Basic Life Sci 52:389–393.2327943
Au WW, Ramanujam VM, Ward JB Jr, . 1991. Chromosome aberrations in lymphocytes of mice after sub-acute low-level inhalation exposure to benzene. Mutat Res 260(2):219–224.2046702
Aubrecht J, Rugo R, Schiestl RH. 1995. Carcinogens induce intrachromosomal recombination in human cells. Carcinogenesis 16(11):2841–2846.7586207
Austin CC, Wang D, Ecobichon DJ, . 2001. Characterization of volatile organic compounds in smoke at municipal structural fires. J Toxicol Environ Health A 63(6):437–458.11482799
Avis SP, Hutton CJ. 1993. Acute benzene poisoning: A report of three fatalities. J Forensic Sci 38(3):599–602.8515211
Baarson KA, Snyder CA. 1991. Evidence for the disruption of the bone marrow microenvironment by combined exposures to inhaled benzene and ingested ethanol. Arch Toxicol 65(5):414–420.1929858
Baarson KA, Snyder CA, Albert RE. 1984. Repeated exposures of C57B1 mice to inhaled benzene at 10 ppm markedly depressed erythropoietic colony formation. Toxicol Lett 20:337–342.6701920
Baarson K, Snyder CA, Green J, . 1982. The hematotoxic effects of inhaled benzene on peripheral blood, bone marrow, and spleen cells are increased by ingested ethanol. Toxicol Appl Pharmacol 64:393–404.7135393
Backer LC, Egeland GM, Ashley DL, . 1997. Exposure to regular gasoline and ethanol oxyfuel during refueling in Alaska. Environ Health Perspect 105(8):850–855.9347900
*Bader M, Lehnert G, Angerer J. 1994. GC/MS determination of N-phenylvaline, a possible biomarker for benzene exposure in human hemoglobin by the “N-alkyl Edman method”. Int Arch Occup Environ Health 65:411–414.8034366
Baehr AL, Stackelberg PE, Baker RJ. 1999. Evaluation of the atmosphere as a source of volatile organic compounds in shallow groundwater. Water Resour Res 35:127–136.
Bainton DF, Ullyot JL, Farquhar MG. 1971. The development of neutrophilic polymorphonuclear leukocytes in human bone marrow. J Pharmacol Exp Ther 134:907–934.
Bakoglu M, Karademir A, Ayberk S. 2004. An elevation of the occupational health risks to workers in a hazardous waste incinerator. J Occup Health 46(2):156–164.15090692
Bandow H, Washida N, Akimoto H. 1985. Ring-cleavage reactions of aromatic hydrocarbons studied by FT-IR spectroscopy: I. Photooxidation of toluene and benzene in the NO_x_-air system. Bull Chem Soc Jpn 58:2531–2540.
Barale R, Giorgelli F, Migliore L, . 1985. Benzene induces micronuclei in circulating erythrocytes of chronically treated mice. Mutat Res 144:193–196.4058438
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
Barrefors G, Petersson G. 1995. Assessment by gas chromatography and gas chromatography-mass spectrometry of volatile hydrocarbons from biomass burning. J Chromatogr 710:71–77.
Barrett RH. 1985. Assays for unscheduled DNA synthesis in HeLa S3 cells. Prog Mutat Res 5:347–352.
Bartczak A, Kline SA, Yu R, . 1994. Evaluation of assays for the identification and quantitation of muconic acid, a benzene metabolite in human urine. J Toxicol Environ Health 42:245–258.8021961
Baslo A, Aksoy M. 1982. Neurological abnormalities in chronic benzene poisoning: A study of six patients with aplastic anemia and two with preleukemia. Environ Res 27:457–465.7084168
Bauer AK, Faiola B, Abernethy DJ, . 2003. Male mice deficient in microsomal epoxide hydrolase are not susceptible to benzene-induced toxicity. Toxicol Sci 72(2):201–209.12655032
Bayer CW, Black MS, Galloway LM. 1988. Sampling and analysis techniques for trace volatile organic emissions from consumer products. J Chromatogr Sci 26:168–173.3379122
Bechtold WE, Henderson RF. 1993. Biomarkers of human exposure to benzene. J Toxicol Environ Health 40:377–386.8230308
Bechtold WE, Lucier G, Birnbaum LS, . 1991. Muconic acid determinations in urine as a biological exposure index for workers occupationally exposed to benzene. Am Ind Hyg Assoc J 52:473–478.1746409
Bechtold WE, Sabourin PJ, Henderson RF. 1988. A reverse isotope dilution method for determining benzene and metabolites in tissues. J Anal Toxicol 12:176–179.3054317
Bechtold WE, Sun JD, Birnbaum LS, . 1992a. S-phenylcysteine formation in hemoglobin as a biological exposure index to benzene. Arch Toxicol 66(5):303–309.1610291
Bechtold WE, Willis JK, Sun JD, . 1992b. Biological markers of exposure to benzene: S-phenylcysteine in albumin. Carcinogenesis 13(7):1217–1220.1638689
Bennett GF. 1987. Air quality aspects of hazardous waste landfills. Haz Waste Haz Mat 4:119–138.
Berger GS. 1994. Epidemiology of endometriosis. In: Berger GS, ed. Endometriosis: Advanced management and surgical techniques. New York, NY: Springer-Verlag, 3–7.
Berlin M, Gage JC, Gullberg B, . 1980. Breath concentration as an index to the health risk from benzene. Scand J Work Environ Health 6:104–111.7433946
Bernauer U, Vieth B, Ellrich R, . 1999. CYP2E1-dependent benzene toxicity: The role of extrahepatic benzene metabolism. Arch Toxicol 73(4–5):189–196.10463382
Bernauer U, Vieth B, Ellrich R, . 2000. CYP2E1 expression in bone marrow and its intra- and interspecies variability: Approaches for a more reliable extrapolation from one species to another in the risk assessment of chemicals. Arch Toxicol 73(12):618–624.10741472
Bezabeh S, Engel A, Morris CB, . 1996. Does benzene cause multiple myeloma? An analysis of the published case-control literature. Environ Health Perspect Suppl 104:1393–1398.9118925
Bird MG, Greim H, Snyder R, . 2005. International symposium: Recent advances in benzene toxicity. Chem Biol Interact 153–154:1–5.
Black FM, High LE, Lang JM. 1980. Composition of automobile evaporative and tailpipe hydrocarbon emissions. J Air Pollut Control Assoc 30:1216–1221.
Blanchard RD, Hardy JK. 1986. Continuous monitoring device for the collection of 23 volatile organic priority pollutants. Anal Chem 58:1529–1532.
Blank IH, McAuliffe DJ. 1985. Penetration of benzene through human skin. J Invest Dermatol 85:522–526.4067326
Bleasdale C, Kennedy G, MacGregor JO, . 1996. Chemistry of muconaldehydes of possible relevance to the toxicology of benzene. Environ Health Perspect 104(Suppl 6):1201–1209.9118894
Bloemen LJ, Youk A, Bradley TD, . 2004. Lymphohaematopoietic cancer risk among chemical workers exposed to benzene. Occup Environ Med 61(3):270–274.14985523
Bock CW, George P, Greenberg A, . 1994. An ab initio computational molecular orbital study of the conformers of muconaldehyde, and the possible role of 2-formyl-2h-pyran in bringing about the conversion of a (z,z)-muconaldehyde structure into an (e,z)-muconaldehyde structure. Chem Res Toxicol 7(4):534–543.7981418
Bodell WJ, Levay G, Pongracz K. 1993. Investigation of benzene-DNA adducts and their detection in human bone marrow. Environ Health Perspect 99:241–244.8319633
Bogadi-Šare A, Brumen V, Turk R, . 1997. Genotoxic effects in workers exposed to benzene: With special reference to exposure biomarkers and confounding factors. Ind Health 35:367–373.9248220
Bois FY, Paxman DG. 1992. An analysis of exposure rate effects for benzene using a physiologically based pharmacokinetic model. Regul Toxicol Pharmacol 15(2):122–136.1626064
Bois FY, Jackson E, Pekari K. 1996. Population toxicokinetics of benzene. Environ Health Perspect 104(Suppl 6):1405–1411.9118927
Bois FY, Smith MT, Spear RC. 1991a. Mechanisms of benzene carcinogenesis: Application of a physiological model of benzene pharmacokinetics and metabolism. Toxicol Lett 56(3):283–298.2035176
Bois FY, Woodruff TJ, Spear RC. 1991b. Comparison of three physiologically based pharmacokinetic models of benzene disposition. Toxicol Appl Pharmacol 110(1):79–88.1871774
*Bolcsak LE, Nerland DE. 1983. Inhibition of erythropoiesis by benzene and benzene metabolites. Toxicol Appl Pharmacol 69:363–368.6879607
Bond GG, McLaren EA, Baldwin CL, . 1986. An update of mortality among chemical workers exposed to benzene. Br J Ind Med 43:685–691.3465366
Boogaard PJ, van Sittert NJ. 1995. Biological monitoring of exposure to benzene: A comparison between S-phenylmercapturic acid, trans,trans-muconic acid, and phenol. Occup Environ Med 52:611–620.7550802
Boogaard PJ, van Sittert NJ. 1996. Suitability of S-phenyl mercapturic acid and trans,trans-muconic acid as biomarkers for exposure to low concentrations of benzene. Environ Health Perspect 104(Suppl 6):1151–1157.9118886
*Bordarier C, Robain O, Ponsot G. 1991. Bilateral porencephalic defect in a newborn after injection of benzol during pregnancy. Brain Dev 13(2):126–129.1892217
Bradley MO. 1985. Measurement of DNA single-strand breaks by alkaline elution in rat hepatocytes. Prog Mutat Res 5:353–357.
Brass HJ, Feige MA, Halloran T, . 1977. The national organic monitoring survey: Samplings and analyses for purgeable organic compounds. In: Pojasek RB, ed. Drinking water quality enhancement through source protection. Ann Arbor, MI: Ann Arbor Science Publishers, 393–416.
Bratton SB, Lau SS, Monks TJ. 1997. Identification of quinol thioethers in bone marrow of hydroquinone/phenol-treated rats and mice and their potential role in benzene-mediated hematotoxicity. Chem Res Toxicol 10:859–865.9282834
Brief RS, Lynch J, Bernath T, . 1980. Benzene in the workplace. Am Ind Hyg Assoc J 41:616–623.7457381
Brondeau MT, Ducos P, Gaudin R, . 1992. Evaluation of the interaction of benzene and toluene on the urinary excretion of t,t-muconic acid in rats. Toxicol Lett 61(2–3):311–316.1641876
Bronstein AC, Currance PL. 1988. Emergency care for hazardous materials exposure. Guideline 69. Washington, DC: The C.V. Mosby Company, 221–222.
Brown EA, Shelley ML, Fisher JW. 1998. A pharmacokinetic study of occupational and environmental benzene exposure with regard to gender. Risk Anal 18(2):205–213.9637076
Brugnone F, Perbellini L, Faccini GB, . 1989. Benzene in the blood and breath of normal people and occupationally exposed workers. Am J Ind Med 16:385–399.2610211
Brugnone F, Perbellini L, Maranelli G, . 1992. Reference values for blood benzene in the occupationally unexposed general population. Int Arch Occup Environ Health 64(3):179–184.1399030
Brugnone F, Perbellini L, Romeo L, . 1998. Benzene in environmental air and human blood. Int Arch Occup Environ Health 71:554–559.9860165
Brunmark A, Cadenas E. 1988. Reductive addition of glutathione to p-benzoquinone, 2-hydroxy-p-benzoquinone, and p-benzoquinone epoxides. Effect of the hydroxy- and glutathionyl substituents on p-benzohydyroquinone autoxidation. Chem Biol Interact 68:273–298.3214888
Brunnemann KD, Kagan MR, Cox JE, . 1989. Determination of benzene, toluene and 1,3-butadiene in cigarette smoke by GC-MSD. Exp Pathol 37:108–113.2637141
Brunnemann KD, Kagan MR, Cox JE, . 1990. Analysis of 1,3-butadiene and other selected gas-phase components in cigarette mainstream and sidestream smoke by gas chromatography-mass selective detection. Carcinogenesis 11:1863–1868.2208599
Bryce-Smith D, Gilbert A. 1976. The organic photochemistry of benzene. Tetrahedron 32:1309–1326.
Buckley JD, Robison LL, Swotinsky L, . 1989. Occupational exposure of parents of children with acute nonlymphocytic leukemia: A report from the Children’s Cancer Study Group. Cancer Res 49:4030–4037.2736544
Budavari S, O’Neil MJ, Smith A, ., eds. 2001. Benzene. The Merck index: An encyclopedia of chemicals, drugs, and biologicals. Whitehouse Station, NJ: Merck and Co., Inc., 182–183.
Budnick LD, Sokal DC, Falk H, . 1984. Cancer and birth defects near the Drake Superfund site, Pennsylvania. Arch Environ Health 39:409–413.6524960
*Bull RJ, Robinson M, Laurie RD. 1986. Association of carcinoma yield with early papilloma development in SENCAR mice. Environ Health Perspect 68:11–17.3780623
Burford MD, Hawthorne SB, Miller DJ. 1994. Analysis of volatile organics by supercritical fluid extraction coupled to gas chromatography II. Quantitation of petroleum hydrocarbons from environmental sample. J Chromatogr A 685:95–111.
Burgess JL, Crutchfield CD. 1995. Tucson fire fighter exposure to products of combustion: A risk assessment. Appl Occup Environ Hyg 10(1):37–42.
Burmaster DE. 1982. The new pollution-groundwater contamination. Environ 24:6–13, 33–36.
Byrd GD, Fowler KW, Hicks RD, . 1990. Isotope dilution gas chromatography-mass spectrometry in the determination of benzene, toluene, styrene and acrylonitrile in mainstream cigarette smoke. J Chromatogr 503:359–368.2185256
C&EN. 1994. Top 50 chemicals production rose modestly last year. Chem Eng News 72(15):12–13.
C&EN. 1995. Production soared in most chemical sectors. Chem Eng News 73(26):38–40.
Cal EPA. 1987. Residential population exposure to ambient benzene in California. Sacramento, CA: Air Resource Board. ARB/TS87001.
Carbonnelle P, Lison D, Leroy JY, . 1995. Effect of the benzene metabolite, hydroquinone, on interleukin-1 secretion by human monocytes in vitro. Toxicol Appl Pharmacol 132(2):220–226.7540334
Carpenter CP, Shaffer CB, Weil CS, . 1944. Studies on the inhalation of 1:3-butadiene; with a comparison of its narcotic effect with benzol, toluol, and styrene, and a note on the elimination of styrene by the human. J Ind Hyg Toxicol 26:69–78.
Cassidy MK, Houston JB. 1984. In vivo capacity of hepatic and extra hepatic enzymes to conjugate phenol. Drug Metab Dispos 12:619–624.6149914
CDC. 1994. Continued use of drinking water wells contaminated with hazardous chemical substances Virgin Islands and Minnesota 1981-1993. Centers for Disease Control. Morbid Mortal Weekly Rep 43(5):89–92.
Chan C-C, Lin S-H, Her G-R. 1993. Student’s exposure to volatile organic compounds while commuting by motorcycle and bus in Taipei City. J Air Waste Manage Assoc 43(9):1231–1238.
Chan C-C, Lin S-H, Her G-R. 1994. Office worker’s exposure to volatile organic compounds while commuting and working in Taipei City. Atmos Environ 28(14):2351–2359.
Chang D, Sui H, Pan HZ, . 2005. Effects of chronic benzene poisoning on DNA and antioxidase of mice. Zhongguo lin chuang kang fu 9(3):240–242.
Chang RL, Wong CQ, Kline SA, . 1994. Mutagenicity of trans,trans-muconaldehyde and its metabolites in V79 cells. Environ Mol Mutagen 24:112–115.7925324
Chao TC, Lo DST, Koh J, . 1993. Glue sniffing deaths in Singapore—volatile aromatic hydrocarbons in post-mortem blood by headspace gas chromatography. Med Sci Law 33(3):253–260.8366789
Chen H, Eastmond DA. 1995. Topoisomerase inhibition by phenolic metabolites: A potential mechanism for benzene’s clastogenic effects. Carcinogenesis 16(10):2301–2307.7586126
Chen H, Rupa DS, Tomar RR, . 1994. Chromosomal loss and breakage in mouse bone marrow and spleen cells exposed to benzene in vivo. Cancer Res 54:3533–3539.8012977
Chen KM, El-Bayoumy K, Cunningham J, . 2004. Detection of nitrated benzene metabolites in bone marrow of B6C3F_1_ mice treated with benzene. Chem Res Toxicol 17(3):370–377.15025507
Chenna A, Hang B, Rydberg B, . 1995. The benzene metabolite p-benzoquinone forms adducts with DNA bases that are excised by a repair activity from human cells that differs from an ethenoadenine glycosylase. Proc Natl Acad Sci USA 92(13):5890–5894.7597048
Chepiga TA, Yang CS, Snyder R. 1991. Benzene metabolism by two purified, reconstituted rat hepatic mixed function oxidase systems. Adv Exp Med Biol 283:261–265.2068993
Chertkov JL, Lutton JD, Jiang S, . 1992. Hematopoietic effects of benzene inhalation assessed by murine long-term bone marrow culture. J Lab Clin Med 119:412–419.1583393
Choy WN, MacGregor JT, Shelby MD, . 1985. Induction of micronuclei by benzene in B6C3F_1_ mice: Retrospective analysis of peripheral blood smears from the NTP carcinogenesis bioassay. Mutat Res 143:55–59.4000143
*Christian CLE, Werley B, Smith A, . 1994. Comparison of employees’ white blood cell counts in a petrochemical plant by worksite and race. J Natl Med Assoc 86(8):620–623.7932841
Ciccone G, Mirabelli D, Levis A, . 1993. Myeloid leukemias and myelodysplastic syndromes: Chemical exposure, histologic subtype and cytogenetics in a case-control study. Cancer Genet Cytogenet 68(2):135–139.8353805
*Ciranni R, Barale R, Adler ID. 1991. Dose-related clastogenic effects induced by benzene in bone marrow cells and in differentiating spermatogonia of Swiss CD1 mice. Mutagenesis 6(5):417–421.1795648
Ciranni R, Barale R, Marrazzini A, . 1988. Benzene and the genotoxicity of its metabolites I. Transplacental activity in mouse fetuses and in their dams. Mutat Res 208:61–67.3367930
Clark AI, McIntyre AE, Lester JN, . 1984. A comparison of photoionisation detection gas chromatography with a Tenax GC sampling tube procedure for the measurement of aromatic hydrocarbons in ambient air. J Environ Anal Chem 17:315–326.
Clavel J, Conso F, Limasset JC, . 1996. Hairy cell leukaemia and occupational exposure to benzene. Occup Environ Med 53(8):533–539.8983464
Clayton CA, Pellizzari ED, Whitmore RW, . 1999. National Human Exposure Assessment Survey (NHEXAS): Distributions and associations of lead, arsenic and volatile organic compounds in EPA Region 5. J Expo Anal Environ Epidemiol 9:381–392.10554141
Clewell HJ III, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Cline PV, Viste DR. 1985. Migration and degradation patterns of volatile organic compounds. Waste Manage Res 3:351–360.
Coate WB, Hoberman AM, Durloo RS. 1984. Inhalation teratology study of benzene in rats. Adv Mod Environ Toxicol 6:187–198.
Cody RP, Strawderman WW, Kipen HM. 1993. Hematologic effects of benzene. Job-specific trends during the first year of employment among a cohort of benzene-exposed rubber workers. J Occup Med 35(8):776–782.8229327
Cohen MA, Ryan PB, Yanagisawa Y, . 1989. Indoor/outdoor measurements of volatile organic compounds in Kanawha Valley of West Virginia. J Air Pollut Control Assoc 39:1086–1093.
Cole CE, Tran HT, Schlosser PM. 2001. Physiologically based pharmacokinetic modeling of benzene metabolism in mice through extrapolation from in vitro to in vivo. J Toxicol Environ Health A 62(6):439–465.11289318
Colenutt BA, Davies DN. 1980. The sampling and gas chromatographic analysis of organic vapours in landfill sites. Int J Environ Anal Chem 7:223–229.
Colenutt BA, Thorburn S. 1980. Gas chromatographic analysis of trace hydrocarbon pollutants in water samples. Int J Environ Stud 15:25–32.
Colinas RJ, Burkart PT, Lawrence DA. 1995. The effects of interleukin-1-beta and tumor necrosis factor-alpha on in vitro colony formation by human hematopoietic progenitor cells exposed to doxorubicin or hydroquinone. Exp Hematol 23(12):1247–1255.7589278
Collins CD, Bell JNB, Crews C. 2000. Benzene accumulation in horticultural crops. Chemosphere 40(1):109–114.10665452
Collins JJ, Conner P, Friedlander BR, . 1991. A study of the hematologic effects of chronic low-level exposure to benzene. J Occup Med 33(5):619–626.1870014
Collins JJ, Ireland B, Buckley CF, . 2003. Lymphohaematopoeitic cancer mortality among workers with benzene exposure. Occup Environ Med 60(9):676–679.12937190
Collins JJ, Ireland BK, Easterday PA, . 1997. Evaluation of lymphopenia among workers with low-level benzene exposure and the utility of routine data collection. J Occup Environ Med 39(3):232–237.9093975
Cornish HH, Ryan RC. 1965. Metabolism of benzene in nonfasted, fasted, and aryl-hydroxylase inhibited rats. Toxicol Appl Pharmacol 7:767–771.5895051
Corti M, Snyder CA. 1996. Influences of gender, development, pregnancy and ethanol consumption on the hematotoxicity of inhaled 10 ppm benzene. Arch Toxicol 70:209–217.8825679
Costantini AS, Quinn M, Consonni D, . 2003. Exposure to benzene and risk of leukemia among shoe factory workers. Scand J Work Environ Health 29(1):51–59.12630436
Cotton SC, Sharp I, Little J, . 2000. Glutathione S-transferase polymorphisms and colorectal cancer: A HuGE review. Am J Epidemiol 151:7–32.10625170
Cox LA Jr. 1996. Reassessing benzene risks using internal doses and Monte-Carlo uncertainty analysis. Environ Health Perspect 104(Suppl 6):1413–1429.9118928
Crawford DW, Bonnevie NL, Wenning RJ. 1995. Sources of pollution and sediment contamination in Newark Bay, New Jersey. Ecotoxicol Environ Safety 30:85–100.7540541
Crebelli R, Bellincampi D, Conti G, . 1986. A comparative study on selected chemical carcinogens for chromosome malsegregation, mitotic crossing-over and forward mutation induction in Aspergillus nidulans. Mutat Res 172:139–149.3531838
Creek MR, Mani C, Vogel JS, . 1997. Tissue distribution and macromolecular binding of extremely low doses of [^14^C]-benzene in B_6_C_3_F_1_ mice. Carcinogenesis 18(12):2421–2427.9450490
Cronin HJ. 1924. Benzol poisoning in the rubber industry. Boston Medical and Science Journal 191:1164–1166.
Cronkite EP. 1986. Benzene hematotoxicity and leukemogenesis. Blood Cells 12:129–137.3790732
Cronkite EP, Bullis JE, Inoue T, . 1984. Benzene inhalation produces leukemia in mice. Toxicol Appl Pharmacol 75:358–361.6474468
Cronkite EP, Drew RT, Inoue T, . 1985. Benzene hematotoxicity and leukemogenesis. Am J Ind Med 7:447–456.4003404
Cronkite EP, Drew RT, Inoue T, . 1989. Hematotoxicity and carcinogenicity of inhaled benzene. Environ Health Perspect 82:97–108.2792054
Cronkite EP, Inoue T, Carsten AL, . 1982. Effects of benzene inhalation on murine pluripotent stem cells. J Toxicol Environ Health 9:411–421.7097795
Daisey JM, Hodgson AT, Fisk WJ, . 1994. Volatile organic compounds in twelve California office buildings: Classes, concentrations and sources. Atmos Environ 28(22):3557–3562.
Darrall KG, Figgins JA, Brown RD, . 1998. Determination of benzene and associated volatile compounds in mainstream cigarette smoke. Analyst 123(5):1095–1101.9709493
Davis EM, Murray HE, Liehr JG, . 1981. Technical note: Basic microbial degradation rates and chemical byproducts of selected organic compounds. Water Res 15:1125–1127.
Davis JW, Klier NK, Carpenter CL. 1994. Natural biological attenuation of benzene in ground water beneath a manufacturing facility. Ground Water 32(2):215–226.
Dayal H, Gupta S, Trieff N, . 1995. Symptom clusters in a community with chronic exposure to chemicals in two superfund sites. Arch Environ Health 50(2):108–111.7786046
*Decoufle P, Blattner WA, Blair A. 1983. Mortality among Chinese workers exposed to benzene and other agents. Environ Res 30:16–25.6832104
Dees C, Travis C. 1994. Hyperphosphorylation of p53 induced by benzene, toluene, and chloroform. Cancer Lett 84(2):117–123.8076368
De Flora S, Zanacchi P, Camoirano A, . 1984. Genotoxic activity and potency for 135 compounds in the Ames reversion test and in a bacterial DNA-repair test. Mutat Res 133:161–198.6374443
de Gandarias JM, Casis O, Irazusta J, . 1992. Effect of subacute benzene exposure on the activity of two neuropeptide-degrading enzymes in the rat brain. Arch Environ Contam Toxicol 22(3):345–348.1616320
DeLeon IR, Antoine SR. 1985. Clinical screening test for toxic volatile organic chemicals in blood. Clinical Ecol 3:108–109.
Delfino JJ, Miles CJ. 1985. Aerobic and anaerobic degradation of organic contaminants in Florida groundwater. Proc Soil Crop Sci Soc Fla 44:9–14.
*Dempster AM, Snyder CA. 1990. Short term benzene exposure provides a growth advantage for granulopoietic progenitor cells over erythroid progenitor cells. Arch Toxicol 64(7):539–544.2073127
Dempster AM, Snyder CA. 1991. Kinetics of granulocytic and erythroid progenitor cells are affected differently by short-term, low-level benzene exposure. Arch Toxicol 65(7):556–561.1781737
Dempster AM, Evans HL, Snyder CA. 1984. The temporal relationship between behavioral and hematological effects of inhaled benzene. Toxicol Appl Pharmacol 76:195–203.6484989
Diaz M, Reiser A, Braier L, . 1980. Studies on benzene mutagenesis: I. The micronucleus test. Experientia 36:297–299.7371785
Dibben MJ, Thomas TC, Anderson MP. 1989. Is benzene a problem in fuel operations? A new analytical method to overcome potential interferences in the present method. LC-GC Int 2:54–58.
Ding X-J, Li Y, Ding Y, . 1983. Chromosome changes in patients with chronic benzene poisoning. Chin Med J (Engl) 96:681–685.6418466
DOE. 1992. Continuous emission monitor for incinerators. Dallas, TX: U.S. Department of Energy. ANL/CP--76118. DE92015261.
DOI. 1984. Detection and effects of aperiodic leachate discharges from landfills. Technical report. U.S. Department of the Interior. PB85242949, 23–24, 98–105.
Dor F, Le Moullec Y, Festy B. 1995. Exposure of city residents to carbon monoxide and monocyclic aromatic hydrocarbons during commuting trips in the Paris metropolitan area. J Air Waste Manage Assoc 45(2):103–110.
Dosemeci M, Li GL, Hayes RB, . 1994. Cohort study among workers exposed to benzene in China: II. Exposure assessment. Am J Ind Med 26(3):401–411.7977413
Dosemeci M, Yin SN, Linet M, . 1996. Indirect validation of benzene exposure assessment by association with benzene poisoning. Environ Health Perspect 104:1343–1347.9118918
Doskin VA. 1971. [Effect of age on the reaction to a combination of hydrocarbons.] Hyg Sanit 36:379–384. (Russian)
Douglas GR, Blakey DH, Liu-Lee VW, . 1985. Alkaline sucrose sedimentation, sister-chromatid exchange and micronucleus assays in CHO cells. Prog Mutat Res 5:359–366.
*Dow. 1980. Risks of long-term health effects of benzene absorbed via skin in laboratory animals. Dow Chemical Co. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0533863.
Dow. 1992. Effects of benzene vapor in the pig and rat. I. Pertaining to hematology and immunology with cover letter dated 05/14/92. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0539784.
Dowty BJ, Carlisle DR, Laseter JL. 1975. New Orleans drinking water sources tested by gas chromatography—mass spectrometry. Environ Sci Technol 9:762–765.
Dowty BJ, Laseter JL, Storer J. 1976. The transplacental migration and accumulation in blood of volatile organic constituents. Pediatr Res 10:696–701.934736
Dragan YP, Sargent L, Xu YD, . 1993. The initiation-promotion-progression model of rat hepatocarcinogenesis. Proc Soc Exp Biol Med 202(1):16–24.8093813
Drew RT, Fouts JR. 1974. The lack of effects of pretreatment with phenobarbital and chlorpromazine on the acute toxicity of benzene in rats. Toxicol Appl Pharmacol 27:183–193.4854929
Duarte-Davidson R, Courage C, Rushton L, . 2001. Benzene in the environment: An assessment of the potential risks to the health of the population. Occup Environ Med 58(1):2–13.11119628
Ducos P, Gaudin R, Bel J, . 1992. trans,trans-Muconic acid, a reliable biological indicator for the detection of individual benzene exposure down to the ppm level. Int Arch Occup Environ Health 64(5):309–313.1487326
Ducos P, Gaudin R, Robert A, . 1990. Improvement in HPLC analysis of urinary trans trans-muconic acid, a promising substitute for phenol in the assessment of benzene exposure. Int Arch Occup Environ Health 62:(7):529–534.2289826
Eastmond DA, Mondrala ST, Hasegawa L. 2005. Topoisomerase II inhibition by myeloperoxidase-activated hydroquinone: A potential mechanism underlying the genotoxic and carcinogenic effects of benzene. Chem Biol Interact 152–154:207–216.
Eastmond DA, Rupa DS, Hasegawa LS. 1994. Detection of hyperdiploidy and chromosome breakage in interphase human lymphocytes following exposure to the benzene metabolite hydroquinone using multicolor fluorescence in situ hybridization with DNA probes. Mutat Res 322(1):9–20.7517507
Eastmond DA, Schuler M, Frantz C, . 2001. Characterization and mechanisms of chromosomal alterations induced by benzene in mice and humans. Cambridge, MA: Health Effects Institute. Research Report 103.
Eastmond DA, Smith MT, Irons RD. 1987. An interaction of benzene metabolites reproduces the myelotoxicity observed with benzene exposure. Toxicol Appl Pharmacol 91:85–95.2823417
Edgerton SA, Shah JJ. 1992. Assessing total exposures to gasoline vapor using the source exposure model. J Expos Anal Environ Epidemiol 2(1):109–115.
Edwards EA, Grbić-Galić D. 1992. Complete mineralization of benzene by aquifer microorganisms under strictly anaerobic conditions. Appl Environ Microbiol 58(8):2663–2666.1514813
Egeghy PP, Tornero-Velez R, Rappaport SM. 2000. Environmental and biological monitoring of benzene during self-service automobile refueling. Environ Health Perspect 108(12):1195–1202.11133401
Einig T, Dehnen W. 1995. Sensitive determination of the benzene metabolite S-phenylmercapturic acid in urine by high-performance liquid chromatography with fluorescence detection. Journal of Chromatography A 697:371–375.7780578
Eisenreich SJ, Looney BB, Thornton JD. 1981. Airborne organic contaminants in the Great Lakes ecosystem. Environ Sci Technol 15:30–38.
Ellenhorn MJ, Barceloux DG. 1988. Medical toxicology: Diagnosis and treatment of human poisoning. New York, NY: Elsevier, 947–950.
EPA. 1978. Assessment of human exposures to atmospheric benzene. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards. EPA450378031. PB284203.
EPA. 1979. Environmental monitoring benzene. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. EPA560679006.
EPA. 1980a. Ambient air monitoring for benzene: 24-hour integrated sampling in six cities. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Research and Development, Environmental Monitoring Systems Laboratory. EPA600480027.
EPA. 1980b. Ambient water quality criteria for benzene. Washington, DC: U.S. Environmental Protection Agency. EPA440580018. PB81117293.
EPA. 1981. Hazardous wastes from specific sources. Identification and listing of hazardous waste. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.32.
EPA. 1982a. An exposure and risk assessment for benzene. Washington, DC: U.S. Environmental Protection Agency. EPA440485006. PB85212017, 3-1–3-32.
EPA. 1982b. U.S. EPA management of hazardous waste leachate EPA contract No. 68-03-2766. E-42, E-96, E-111, E-142, E-143. (as cited in HSDB 2007).
EPA. 1984. Guidelines for establishing test procedures for the analysis of pollutants under the Clean Water Act. U.S. Environmental Protection Agency. Fed Regist 49:43234, 43255–43256, 432272–43280, 43373–43384, 43407–43415.
*EPA. 1985a. Drinking water criteria document on benzene. Final draft. Washington, DC: U.S. Environmental Protection Agency, Office of Drinking Water. PB86118122.
EPA. 1985b. Interim quantitative cancer unit risk estimates due to inhalation of benzene. U.S. Environmental Protection Agency, Office of air quality planning and standards. EPA600X85022.
EPA. 1985c. Comparison of ambient air sampling techniques for volatile organic compounds. Research Triangle Park, NC: U.S. Environmental Protection Agency. Environmental monitoring systems laboratory. EPA600485067. PB86120953.
EPA. 1985d. Development of an optical monitor for toxic organic compounds in air. Research Triangle Park, NC: U.S. Environmental Protection Agency, Environmental Monitoring Systems Laboratory. EPA600485043. PB85225027.
EPA. 1986. Self service station vehicle refueling exposure study. Proceedings of the 1986 EPA/APCA symposium on measurements of toxic air pollutants. Raleigh, NC: U.S. Environmental Protection Agency. Air Pollution Control Association. EPA600986013, 458–466.
*EPA. 1987a. June-September, 6-9 AM, ambient air benzene concentrations in 39 U.S. cities, 1984-1986. Research Triangle Park, NC: U.S. Environmental Protection Agency, Atmospheric Sciences Research Lab. EPA600D87160.
EPA. 1987b. The total exposure assessment methodology (TEAM) study: Elizabeth and Bayonne, New Jersey, Devils Lake, North Dakota and Greensboro, North Carolina: Vol. II. Part 1. Washington, DC: U.S. Environmental Protection Agency. PB8810078, 12–13.
EPA. 1988a. Compendium of methods for the determination of toxic organic compounds in ambient air. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA600489017. PB90127374.
EPA. 1988b. Recommendations for and documentation of biological values for use in risk assessment. Cincinnati, OH: U.S. Environmental Protection Agency. EPA600687008. PB88179874.
EPA 1989. National emission standards for hazardous air pollutants; benzene emissions from maleic anhydride plants, ethylbenzene/styrene plants, benzene storage vessels, benzene equipment leaks, and coke by-products recovery plants. U.S. Environmental Protection Agency. Fed Regist 54:38044.
EPA. 1990. Interim methods for development of inhalation reference concentrations. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development, Environmental Criteria and Assessment Office. EPA600890066A. PB90238890.
EPA. 1992a. Methods for the determination of organic compounds in drinking water. Supplement II. Cincinnati, OH: U.S. Environmental Protection Agency. PB92207703.
EPA. 1992b. The time-course and sensitivity of muconic acid as a biomarker for human environmental exposure to benzene. In: Measurement of toxic and related air pollutants. Proceedings of the 1992 U.S. EPA/A&WMA International symposium. Pittsburgh, PA: U.S. Environmental Protection Agency. Air and Waste Management Association, 981–986.
EPA. 1993. Regulation of fuel and fuel additives. Renewable oxygenate requirements for reformulated gasoline: Proposed Rule. U.S. Environmental Protection Agency. Fed Regist 58:68343.
EPA. 1994a. Land disposal restrictions phase II - Universal treatment standards and treatment standards for organic toxicity characteristic wastes and newly listed wastes. U.S. Environmental Protection Agency. Fed Regist 59:47982.
EPA. 1994b. Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development, Environmental Criteria and Assessment Office. EPA600890066F.
EPA. 1994c. Test methods for evaluating solid waste method 8021a. Halogenated volatiles by gas chromatography using photoionization and electrolytic conductivity detectors in series: Capillary column technique. U.S. Environmental Protection Agency.
EPA. 1994d. Mobile source hazardous air pollutant emissions in the Seattle-Tacoma urban area. Washington, DC: U.S. Environmental Protection Agency. PB95174660.
EPA. 1995. Federal standards for marine tank vessel loading operations and national emission standards for hazardous air pollutants for marine tank vessel loading operations. U.S. Environmental Protection Agency. Fed Regist 60:48388.
EPA. 1997. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. EPA630R96012.
EPA. 1998. Carcinogenic effects of benzene: An update. Washington, DC: U.S. Environmental Protection Agency. EPA600P97001F. PB99101420.
EPA. 2001. Occurence of unregulated contaminants in public water systems - A national summary. Washington, DC: U.S. Environmental Protection Agency, Office of Water. EPA815P00002.
EPA. 2002a. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency, Office of Ground Water and Drinking Water. EPA816F02013. http://www.epa.gov/safewater/mcl.html. February 15, 2005.
EPA. 2002b. National recommended water quality criteria. Washington, DC: U.S. Environmental Protection Agency, Office of Water, Office of Science and Technology. EPA822R02047. http://www.epa.gov/waterscience/pc/revcom.pdf. February 15, 2005.
EPA. 2004a. Drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency, Office of Water. EPA822R04005. http://www.epa.gov/waterscience/drinking/standards/dwstandards.pdf. February 15, 2005.
EPA. 2004b. Hazardous air pollutants. Washington, DC: U.S. Environmental Protection Agency. United States Code 42 USC 7412. http://www.epa.gov/ttn/atw/orig189.html. February 15, 2005.
EPA. 2005a. Acute Exposure Guideline Levels (AEGLs). Washington, DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics. http://www.epa.gov/oppt/aegl/chemlist.htm. March 28, 2005.
EPA. 2005b. Designated as hazardous substances in accordance with Section 311(b)(2)(A) of the Clean Water Act. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 116.4. http://www.epa.gov/ttn/atw/orig189.html. February 15, 2005.
EPA. 2005c. Reportable quantities of hazardous substances designated pursuant to Section 311 of the Clean Water Act. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 117.3. http://www.epa.gov/epacfr40/chapt-I.info/chi-toc.htm. February 16, 2005.
EPA. 2005d. Superfund, emergency planning, and community right-to-know programs. Designation, reportable quantities, and notifications. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4. http://www.epa.gov/epacfr40/chapt-I.info/chi-toc.htm. February 15, 2005.
EPA. 2005e. Superfund, emergency planning, and community right-to-know programs. Toxic chemical release reporting. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65. http://www.epa.gov/epacfr40/chapt-I.info/chi-toc.htm. February 16, 2005.
EPA. 2005f. Benzene. STORET. STOrage and RETrieval. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/storet. March 25, 2005.
EPA. 2005g. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. Office of Environmental Information. EPA260B05001.
Erexson GL, Wilmer JL, Steinhagen WH, . 1986. Induction of cytogenetic damage in rodents after short-term inhalation of benzene. Environ Mutagen 8:29–40.3943496
Erf LA, Rhoads CP. 1939. The hematological effects of benzene (benzol) poisoning. J Ind Hyg Toxicol 20:421–435.
Etzel RA, Ashley DL. 1994. Volatile organic compounds in the blood of persons in Kuwait during the oil fires. Int Arch Occup Environ Health 66:125–129.7806395
Eutermoser M, Rusch GM, Kuna RA, . 1986. A method for repeated evaluation of benzene uptake in rats and mice during a six hour inhalation period. Am Ind Hyg Assoc J 47:37–40.3946198
Evans HL, Dempster AM, Snyder CA. 1981. Behavioral changes in mice following benzene inhalation. Neurobehav Toxicol Teratol 3:481–485.7335143
Eveleth WT. 1990. Basic and intermediate chemicals. In: Eveleth WT, eds. Kline giude to the US chemical industry. 5th ed. Fairfield, NJ: Kline & Company, Inc., 2-1 to 2-42.
Exxon. 1986. Determination of matenal toxicity and fetal toxicity of benzene in rats following oral exposure. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0536017.
Fabietti F, Ambruzzi A, Delise M, . 2004. Monitoring of the benzene and toluene contents in human milk. Environ Int 30(3):397–401.14987872
Fan XH. 1992. Effect of exposure to benzene on natural killer (NK) cell activity and interleukin-2 (IL-2) production of C57BL/6 mice. J Nippon Med Sch 59(5):393–399.
Farmer PB, Kaur B, Roach J, . 2005. The use of S-phenylmercapturic acid as a biomarker in molecular epidemiology studies of benzene. Chem Biol Interact 153–154:97–102.
Farris GM, Everitt JI, Irons RD, . 1993. Carcinogenicity of inhaled benzene in CBA mice. Fundam Appl Toxicol 20(4):503–507.8314465
Farris GM, Robinson SN, Gaido KW, . 1997a. Benzene-induced hematotoxicity and bone marrow compensation in B6C3F1 mice. Fundam Appl Toxicol 36(2):119–129.9143481
Farris GM, Robinson SN, Wong BA, . 1997b. Effects of benzene on splenic, thymic, and femoral lymphocytes in mice. Toxicology 118(2–3):137–148.9129168
Farris GM, Wong VA, Wong BA, . 1996. Benzene-induced micronuclei in erythrocytes: An inhalation concentration-response study in B6C3F1 mice. Mutagenesis 11(5):455–462.8921506
FDA. 1977. Indirect food additives. Adhesives coatings and components. Food and Drug Administration. Fed Regist 42:14534–14554.
FDA. 2004. Beverages. Bottled water. Washington, DC: Food and Drug Administration. Code of Federal Regulations. 21 CFR 165.110. http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfcfr/CFRSearch.cfm. February 15, 2005.
FEDRIP. 2005. FEDRIP literature search for benzene. Palo Alto, CA: Federal Research in Progress. Dialog Information Service.
Ferrario JB, Lawler GC, DeLeon IR, . 1985. Volatile organic pollutants in biota and sediments of Lake Pontchartrain. Bull Environ Contam Toxicol 34:246–255.3978262
Finkelstein MM. 2000. Leukemia after exposure to benzene: Temporal trends and implications for standards. Am J Ind Med 38(1):1–7.10861761
Fishbeck WA, Townsend JC, Swank MG. 1978. Effect of chronic occupational exposure to measured concentrations of benzene. J Occup Med 20:539–542.690738
Fishbein L. 1988. Benzene: Uses, occurrence, and exposure. In: Fishbein L, O’Neill IK, eds. Environmental carcinogens methods of analysis and exposure measurement: Vol. 10—benzene and alkylated benzene. IARC Scientific Publications No. 85. Lyon, France: World Health Organization, International Agency for Research on Cancer, 67–96.
Fishbein L. 1992. Exposure from occupational versus other sources. Scand J Work Environ Health 18(Suppl 1):5–16.
Fisher J, Mahle D, Bankston L, . 1997. Lactational transfer of volatile chemicals in breast milk. Am Ind Hyg Assoc J 58(6):425–431.9183837
Fleming AF. 1990. Benzene in petrol: A continuing hazard [letter; comment]. Lancet 336(8722):1076–1077.
Fleming-Jones ME, Smith RE. 2003. Volatile organic compounds in foods: A five year study. J Agric Food Chem 51(27):8120–8127.14690406
Flury F. 1928. [II. Toxicities in modern industry. IIa. Pharmacological-toxicological aspects of intoxicants in modern industry.] Arch Exp Pathol Pharmakol 138:65–82. (German)
Fomon SJ. 1966. Body composition of the infant: Part I: The male reference infant. In: Falkner F, ed. Human development. Philadelphia, PA:WB Saunders, 239–246.
Fomon SJ, Haschke F, Ziegler EE, . 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35:1169–1175.7081099
Forni A, Moreo L. 1967. Cytogenetic studies in a case of benzene leukaemia. Eur J Cancer 3:251–255.
Forni A, Moreo L. 1969. Chromosome studies in a case of benzene-induced erythroleukaemia. Eur J Cancer 5:459–463.
Forni A, Cappellini A, Pacifico E, . 1971a. Chromosome changes and their evolution in subjects with past exposure to benzene. Arch Environ Health 23:385–391.5133800
Forni AM, Pacifico E, Limonta A. 1971b. Chromosome studies in workers exposed to benzene or toluene or both. Arch Environ Health 22:373–378.
Frantik E, Hornychova M, Horvath M. 1994. Relative acute neurotoxicity of solvents: Isoeffective air concentrations of 48 compounds evaluated in rats and mice. Environ Res 66:173–185.8055839
Franz TJ. 1984. Percutaneous absorption of benzene. In: MacFarland HN, Holdsworth CE, MacGregor JA, ., eds. Advances in modern environmental toxicology. Vol. VI. Applied toxicology of petroleum hydrocarbons. Princeton, NJ: Princeton Scientific Publishers, Inc., 61–70.
Fraser MP, Cass GR, Simoneit BRT. 1998. Gas-phase and particle-phase organic compounds emitted from motor vehicle traffic in a Los Angeles roadway tunnel. Environ Sci Technol 32:2051–2060.
Froom P, Dyerassi L, Cassel A, . 1994. Erythropoietin-independent colonies of red blood cells and leukocyotisis in a worker exposed to low levels of benzene. Scand J Work Environ Health 20:306–308.7801077
Fruin SA, St. Denis M, Winer AM, . 2001. Reductions in human benzene exposure in the California South Coast Air Basin. Atmos Environ 35:1069–1077.
Fruscella W. 1992. Benzene. In: Kroschwitz JI, Howe-Grant M, eds. Kirk-Othmer encyclopedia of chemical toxicology. Fourth edition. New York: John & Wiley & Sons, 73–103.
Fujie K, Ito Y, Maeda S. 1992. Acute cytogenetic effect of benzene on rat bone marrow cells in vivo and the effect of inducers or inhibitors of drug-metabolizing enzymes. Mutat Res 298(2):81–90.1282215
Funes-Cravioto F, Zapata-Gayon C, Kolmodin-Hedman B, . 1977. Chromosome aberrations and sister chromatid exchange in workers in chemical laboratories and a rotoprinting factory and in children of women laboratory workers. Lancet 2:322–325.69934
Fung KK, Wright BJ. 1986. Monitoring of benzene in ambient air with organic vapor badges. J Air Pollut Control Assoc 36:819–821.
Fuselli S, Benigni R, Conti L. 1995. Volatile organic compounds (VOCs) and air mutagenicity: Results of one year monitoring at an urban site. Int J Environ Health Res 5(2):123–132.
Fustinoni S, Buratti M, Campo L, . 2005. Urinary t,t-muconic acid, S-phenylmercapturic acid and benzene as biomarkers of low benzene exposure. Chem Biol Interact 153–154:253–256.
Fustinoni S, Buratti M, Giampiccolo R, . 1995. Biological and environmental monitoring of exposure to airborne benzene and other aromatic hydrocarbons in Milan traffic wardens. Toxicol Lett 77:387–392.7618166
*Gad-El Karim MM, Ramanujam VMS, Legator MS. 1985. trans,trans-Muconic acid, an open chain urinary metabolite of benzene in mice: Quantification by high-pressure liquid chromatography. Xenobiotica 15:211–220.4024657
Gad-El Karim MM, Ramanujam VMS, Legator MS. 1986. Correlation between the induction of micronuclei in bone marrow by benzene exposure and the excretion of metabolites in urine of CD-1 mice. Toxicol Appl Pharmacol 85:464–477.3764927
Ganousis LG, Goon D, Zyglewska T, . 1992. Cell-specific metabolism in mouse bone marrow stroma: Studies of activation and detoxification of benzene metabolites. Mol Pharmacol 42(6):1118–1125.1480134
Geist CR, Drew KL, Schoenheit CM, . 1983. Learning impairments following postnatal exposures to benzene. Percept Mot Skills 57:1083–1086.6664789
Gerner-Smidt P, Friedrich U. 1978. The mutagenic effect of benzene, toluene and xylene studied by the SCE technique. Mutat Res 58:313–316.370577
Geyer H, Politzki G, Freitag D. 1984. Prediction of ecotoxicological behavior of chemicals: Relationship between n-octanol/water coefficient and bioaccumulation of organic chemicals by alga Chlorella. Chemosphere 13(2):269–284.
Ghantous H, Danielsson BRG. 1986. Placental transfer and distribution of toluene, xylene and benzene, and their metabolites during gestation in mice. Biol Res Pregnancy 7:98–105.
Ghittori S, Fiorentino ML, Maestri L, . 1993. Urinary excretion of unmetabolized benzene as an indicator of benzene exposure. J Toxicol Environ Health 38(3):233–243.8450555
Ghittori S, Maestri L, Fiorentino ML, . 1995. Evaluation of occupational exposure to benzene by urinalysis. Int Arch Occup Environ Health 67:195–200.7591178
Ghoos Y, Claus D, Geypens B, . 1994. Screening method for the determination of volatiles in biomedical samples by means of an off-line closed-loop trapping system and high-resolution gas chromatography-ion trap detection. J Chromatogr 665:333–345.
Gibson DT. 1977. Biodegradation of aromatic petroleum hydrocarbons. In: Wolfe DA, ed. Fate and effects of petroleum hydrocarbons in marine ecosystems and organisms. New York, NY: Pergamon, 36–46.
Gibson DT. 1980. Microbial metabolism. In: Hutzinger O, ed. The handbook of environmental chemistry. New York, NY: Springer-Verlag, 161–192.
Gill DP, Jenkins VK, Kempen RR, . 1980. The importance of pluripotential stem cells in benzene toxicity. Toxicology 16:163–171.7414616
Gill DP, Kempen RR, Nash JB, . 1979. Modifications of benzene myelotoxicity and metabolism by phenobarbital, SKF-525A and 3-methylcholanthrene. Life Sci 25:1633–1640.513970
Gilli G, Scursatone E, Bono R. 1994. Benzene, toluene and xylenes in air, geographical distribution in the piedmont region (Italy) and personal exposure. Sci Total Environ 148(1):49–56.8016638
Giver CR, Wong R, Moore DH II, . 2001. Persistence of aneuploid immature/primitive hemopoietic sub-populations in mice 8 months after benzene exposure in vivo. Mutat Res 491(1–2):127–138.11287306
Giwercman A, Carlsen E, Keiding N, . 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl 101(2):65–71.
Glass LR, Connor TH, Thiess JC, . 1986. Genotoxic evaluation of the offgassing products of particle boards. Toxicol Lett 31:75–83.3520959
Glatt H, Witz G. 1990. Studies on the induction of gene mutations in bacterial and mammalian cells by the ring-opened benzene metabolites trans,trans-muconaldehyde and trans,trans-muconic acid. Mutagenesis 5:263–266.2200946
Glatt H, Padykula R, Berchtold GA, . 1989. Multiple activation pathways of benzene leading to products with varying genotoxic characteristics. Environ Health Perspect 82:81–89.2676505
Glauert HP, Kennan WS, Sattler GL, . 1985. Assays to measure the induction of unscheduled DNA synthesis in cultured hepatocytes. Progress in Mutation Research 5:371–373.
Gofmekler VA. 1968. [Effect on embryonic development of benzene and formaldehyde in inhalation experiments.] Hyg Sanit 33:327–332. (Russian)
Goldfrank LR, Flomenbaum NE, Lewin NA, ., eds. 1998. Goldfrank’s toxicologic emergencies. 6th edition. Stamford: Appleton & Lange, 1384–1398.
Goldman LR, Paigen B, Magnant MM, . 1985. Low birth weight, prematurity and birth defects in children living near the hazardous waste site, Love Canal. Hazard Waste Hazard Mater 2:209–223.
Goldstein BD, Warren J. 1993. HEI’s mobile air toxics project. Environ Health Perspect 101(3):256–258.7691592
Goldwater LJ. 1941. Disturbances in the blood following exposure to benzol. J Lab Clin Med 26:957–973.
Gonasun LM, Witmer C, Kocsis J, . 1973. Benzene metabolism in mouse liver microsomes. Toxicol Appl Pharmacol 26:398–406.4148939
Gonzalez J, Levine SP. 1986. The development and evaluation of a thermally-desorbable miniature passive dosimeter for the monitoring of organic vapors. Am Ind Hyg Assoc J 47:339–346.3739902
Goon D, Cheng X, Ruth JA, . 1992. Metabolism of trans,trans-muconaldehyde by aldehyde and alcohol dehydrogenases: Identification of a novel metabolite. Toxicol Appl Pharmacol 114:147–155.1585367
Goon D, Matsuura J, Ross D. 1993. Metabolism and cytotoxicity of trans,trans-muconaldehyde and its derivatives: Potential markers of benzene ring cleavage reactions. Chem Biol Interact 88(1):37–53.8330323
Gordian ME, Guay G. 1995. Benzene in Alaska. J Alaska Med 37(1):25–36.
Gosepath J, Grebneva N, Brieger J, . 2003. Evaluation of inflammatory reactions and genotoxic effects after exposure of nasal respiratory epithelia to benzene. ORL J Otorhinolaryngol Relat Spec 65(6):348–352.14981328
Gossett RW, Brown DA, Young DR. 1983. Predicting the bioaccumulation of organic compounds in marine organisms using octanol/water partition coefficients. Marine Poll Bull 14(10):387–392.
Graedel TE. 1978. Chemical compounds in the atmosphere. New York, NY: Academic Press, 105–107.
Grbić-Galić D, Vogel TM. 1987. Transformation of toluene and benzene by mixed methanogenic cultures. Appl Environ Microbiol 53(2):254–260.3105454
Greek BF. 1990. Prices and demand for aromatics reverse earlier gains. Chem Eng News 68:11–12.
Green JD, Leong BKJ, Laskin S. 1978. Inhaled benzene fetotoxicity in rats. Toxicol Appl Pharmacol 46:9–18.725954
Green JD, Snyder CA, LoBue J, . 1981a. Acute and chronic dose/response effects of inhaled benzene on multipotential hematopoietic stem (CFU-S) and granulocyte/macrophage progenitor (GM-CFU-C) cells in CD-1 mice. Toxicol Appl Pharmacol 58:492–503.7245216
Green JD, Snyder CA, LoBue J, . 1981b. Acute and chronic dose/response effect of benzene inhalation on the peripheral blood, bone marrow, and spleen cell of CD-1 male mice. Toxicol Appl Pharmacol 59:204–214.7256764
Greenburg L. 1926. Benzol poisoning as an industrial hazard. Public Health Reports 41:1357–1375.
Greenburg L, Mayers MR, Goldwater L, . 1939. Benzene (benzol) poisoning in the rotogravure printing industry in New York City. J Ind Hyg Toxicol 21:395–420.
*Greenland S, Salvan A, Wegman DH, . 1994. A case-control study of cancer mortality at a transformer-assembly facility. Int Arch Occup Environ Health 66:49–54.7927843
Grob K, Frauenfelder C, Artho A. 1990. Uptake by foods of tetrachloroethylene, trichlorethylene, toluene, and benzene from air. Z Lebensm Unters Forsch 191:435–441.2103659
Grotz VL, Ji S, Kline SA, . 1994. Metabolism of benzene and trans,trans-muconaldehyde in the isolated perfused rat liver. Toxicol Lett 70(3):281–290.8284795
Gruenke LD, Craig JC, Wester RC, . 1986. Quantitative analysis of benzene by selected ion monitoring/gas chromatography/mass spectrometry. J Anal Toxicol 10:225–232.3807320
Guerra G, Lemma A, Lerda D, . 1995. Benzene emissions from motor vehicle traffic in the urban area of Milan: Hypothesis of health impact assessment. Atmos Environ 29(23):3559–3569.
Gulati DK, Witt K, Anderson B, . 1989. Chromosome aberration and sister chromatid exchange tests in Chinese hamster ovary cells in vitro: III: Results with 27 chemicals. Environ Mol Mutagen 13:133–193.2917552
Gut I, Nedelcheva V, Soucek P, . 1996a. Cytochromes P450 in benzene metabolism and involvement of their metabolites and reactive oxygen species in toxicity. Environ Health Perspect 104(Suppl 6):1211–1218.9118895
Gut I, Nedelcheva V, Soucek P, . 1996b. The role of CYP2E1 and 2B1 in metabolic activation of benzene derivatives. Arch Toxicol 71:45–56.9010585
Gut I, Terelius Y, Frantik E, . 1993. Exposure to various benzene derivatives differently induces cytochromes P450 2B1 and P450 2E1 in rat liver. Arch Toxicol 67(4):237–243.8517779
*Guy RL, Dimitriadis EA, Hu PD, . 1990. Interactive inhibition of erythroid ^59^Fe utilization by benzene metabolites in female mice. Chem Biol Interact 74(1–2):55–62.2322953
Guy RL, Hu P, Witz G, . 1991. Depression of iron uptake into erythrocytes in mice by treatment with the combined benzene metabolites p-benzoquinone, muconaldehyde and hydroquinone. J Appl Toxicol 11(6):443–446.1761802
Guzelian PS, Henry CJ, Olin SS, eds. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences Institute Press.
Haddad LM, Shannon MW, Winchester JF. 1998. Clinical management of poisoning and drug overdose. 3rd edition. Philadelphia, PA: W.B Saunders Company, 940–941.
Haider K, Jagnow G, Kohnen R, . 1981. Degradation of chlorinated benzene, phenols and cyclohexane derivatives by benzene- and phenol-utilizing soil bacteria under aerobic conditions. In: Overcash MR, ed. Decomposition of toxic and nontoxic organic compounds in soils. Ann Arbor, MI: Ann Arbor Science, 207–223.
Hajimiragha H, Ewers U, Brockhaus A, . 1989. Levels of benzene and other volatile aromatic compounds in the blood of non-smokers and smokers. Int Arch Occup Environ Health 61:513–518.2807569
Hallberg LM, El Zein R, Grossman L, . 1996. Measurement of DNA repair deficiency in workers exposed to benzene. Environ Health Perspect 104:529–534.8781377
Hamilton A. 1922. The growing menace of benzene (benzol) poisoning in American industry. J Am Med Assoc 78:627–630.
Hammond JW, Hermann ER. 1960. Industrial hygiene features of a petro-chemical benzene plant design and operation. Am Ind Hyg Assoc J 21:173–177.14399359
Hanke J, Dutkiewicz T, Piotrowski J. 1961. [The absorption of benzene through the skin in men.] Medycyna Pracy 12:413–426. (Polish)
Hanway R, Cavicchioli A, Kaur B, . 2000. Analysis of S-phenol-L-cysteine in globin as a marker of benzene exposure. Biomarkers 5(4):252–262.23885978
Hanzlick R. 1995. National association of medical examiners pediatric toxicology (PedTox) registry report 3: Case submission summary and data for acetaminophen, benzene, carboxyhemoglobin, dextromethorphan, ethanol, phenobarbital, and pseudoephedrine. Am J Forensic Med Pathol 16(4):270–277.8599337
Harkov R, Gianti SJ Jr, Bozzelli JW, . 1985. Monitoring volatile organic compounds at hazardous and sanitary landfills in New Jersey. J Environ Sci Health A20:491–501.
Harland BJ, Whitby FJ, Comber MHI. 1985. Measurement of volatile aromatic hydrocarbons in an industrial estuary. Int J Environ Anal Chem 20:295–311.
Harper BL, Sadagopa Ramanujam VM, Gad-El-Karim MM, . 1984. The influence of simple aromatics on benzene clastogenicity. Mutat Res 128:105–114.6472309
Harrison I, Leader RU, Higgo JJW, . 1994. Determination of organic pollutants in small samples of groundwaters by liquid-liquid extraction and capillary gas chromatography. J Chromatogr A688:181–188.
Hartwich G, Schwanitz G, Becker J. 1969. Chromosome anomalies in a case of benzene leukaemia. German Medical Monthly 14:449–450.5260587
Hatakeyama Y, Nakajima E, Atai H, . 1992. Effects of benzene in a micronucleus test on peripheral blood utilizing acridine orange-coated slides. Mutat Res 278(2–3):193–195.1372705
Hattemer-Frey HA, Travis CC, Land ML. 1990. Benzene: Environmental partitioning and human exposure. Environ Res 53:221–232.2253601
Hayashi M, Norppa H, Sofuni T, . 1992. Flow cytometric micronucleus test with mouse peripheral erythrocytes. Mutagenesis 7(4):257–264.1518408
Hayes RB. 1992. Biomarkers in occupational cancer epidemiology: Considerations in study design. Environ Health Perspect 98:149–154.1486844
Hayes RB, Songnian Y, Dosemeci M, . 2001. Benzene and lymphohematopoietic malignancies in humans. Am J Ind Med 40(2):117–126.11494338
Hayes RB, Yin SN, Dosemeci M, . 1996. Mortality among benzene-exposed workers in China. Environ Health Perspect 104(Suppl 6):1349–1352.9118919
Hayes, RB, Yin SN, Dosemeci M, . 1997. Benzene and the dose-related incidence of hematologic neoplasms in China. J Natl Cancer Inst 89(14):1065–1071.9230889
HazDat. 2006. HazDat Database: ATSDR’s Hazardous Substance Release and Health Effects Database. Atlanta, GA: Agency for Toxic Substances and Disease Registry. www.atsdr.cdc.gov/hazdat.html. December 18, 2006.
*Hazel BA, O’Connor A, Niculescu R, . 1995. Benzene and its metabolite, hydroquinone, induce granulocytic differentiation in myeloblasts by interacting with cellular signaling pathways activated by granulocyte colony-stimulating factor. Stem Cells 13(3):295–310.7542115
Healy LN, Pluta LJ, James RA, . 2001. Induction and time-dependent accumulation of micronuclei in peripheral blood of transgenic p53 +/− mice, TgAC (v-HA-ras) and parental wild-type (C57BL/6 and FVB/N) mice exposed to benzene by inhalation. Mutagenesis 16(2):163–168.11230560
Heath CW. 1983. Field epidemiologic studies of populations exposed to waste dumps. Environ Health Perspect 48:3–7.6825633
Heavner DL, Morgan WT, Ogden MW. 1995. Determination of volatile organic compounds and ETS apportionment in 49 homes. Environ Int 21(1):3–21.
Hedli CC, Snyder R, Witmer CM. 1991. Bone marrow DNA adducts and bone marrow cellularity following treatment with benzene metabolites in vivo. Adv Exp Med Biol 283:745–748.2069051
Heineman EF, Olsen JH, Pottern LM, . 1992. Occupational risk factors for multiple myeloma among Danish men. Cancer Causes Control 3:555–568.1420859
Hellmér L, Bolcsfoldi G. 1992a. An evaluation of the E. coli K-12 uvrB/recA DNA repair host-mediated assay: II. In vivo results for 36 compounds tested in the mouse. Mutat Res 272(2):161–173.1383748
Hellmér L, Bolcsfoldi G. 1992b. An evaluation of the E. coli k-12 uvrB/recA DNA repair host-mediated assay: I. In vitro sensitivity of the bacteria to 61 compounds. Mutat Res 272(2):145–160.1383747
Henderson RF, Sabourin PJ, Bechtold WE, . 1989. The effect of dose, dose rate, route of administration, and species on tissue and blood levels of benzene metabolites. Environ Health Perspect 82:9–17.2792053
Henderson RF, Sabourin PJ, Medinsky MA, . 1992. Benzene dosimetry in experimental animals: Relevance for risk assessment. In: D’Amato R, Slaga TJ, Farland WH, ., eds. Relevance of animal studies to the evaluation of human cancer risk. New York, NY: Wiley-Liss Inc., 93–105.
Hendrickson HP, Sahafayen M, Bell MA, . 1994. Relationship of flavonoid oxidation potential and effect on rat hepatic microsomal metabolism of benzene and phenol. J Pharm Biomed Anal 12(3):335–341.8031932
Hengstler JG, Arand M, Herrero ME, . 1998. Polymorphisms of N-acetyltransferases, glutathione S-transferases, microsomal epoxide hydrolase and sulfotransferases: Influence on cancer susceptibility. Recent Results Cancer Res 154:47–85.10026993
Henschler R, Glatt HR. 1995. Induction of cytochrome p4501a1 in haemopoietic stem cells by hydroxylated metabolites of benzene. Toxicol In Vitro 9(4):453–457.20650112
Hiraku Y, Kawanishi S. 1996. Oxidative DNA damage and apoptosis induced by benzene metabolites. Cancer Res 56(22):5172–5178.8912853
Hite M, Pecharo M, Smith I, . 1980. The effect of benzene in the micronucleus test. Mutat Res 77:149–155.6990240
Hoechst. 1977. Initial submission: Mutagenicity evaluation of benzene in Salmonella typhimurium, Saccharomyces cerevisiae, and mice (final report) with attachment. Hoechst Celanese Corporation. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0539838.
*Hoechst. 1978. Chronic toxicity with benzene in Sprague-Dawley rats. Hoechst Celanese Corporation. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0539825.
Hoel DG, Davis DL, Miller AB, . 1992. Trends in cancer mortality in 15 industrialized countries, 1969-1986. J Natl Cancer Inst 84(5):313–320.1738181
Hoffmann K, Krause C, Seifert B, . 2000. The German Environmental Survey 1990/92 (GERES II) Sources of Personal exposure to volatile organic compounds. J Expo Anal Environ Epidemiol 10:115–125.10791593
Holmberg B, Lundberg P. 1985. Benzene: Standards, occurrence, and exposure. Am J Ind Med 7:375–383.4003400
Hopper DJ. 1978. Microbial degradation of aromatic hydrocarbons. In: Watkinson RJ, ed. Developments in biodegradation of hydrocarbons. London, England: Applied Science Publishers LTD, 85–112.
HSDB. 2007. Benzene. Hazardous Substances Data Bank. National Library of Medicine. http://toxnet.nlm.nih.gov. May 1, 2007.
Hsieh GC, Parker RDR, Sharma RP. 1988a. Subclinical effects of groundwater contaminants: II. Alteration of regional brain monoamine neurotransmitters by benzene in CD-1 mice. Arch Environ Contam Toxicol 17:799–805.2906531
Hsieh GC, Parker RDR, Sharma RP, . 1990. Subclinical effects of groundwater contaminants. III. Effects of repeated oral exposure to combinations of benzene and toluene on immunologic responses in mice. Arch Toxicol 64(4):320–328.2143647
Hsieh GC, Sharma RP, Parker RDR. 1988b. Subclinical effects of groundwater contaminants: I. Alteration of humoral and cellular immunity by benzene in CD-1 mice. Arch Environ Contam Toxicol 17:151–158.3355230
Hsieh GC, Sharma RP, Parker RD. 1991. Hypothalamic-pituitary-adrenocortical axis activity and immune function after oral exposure to benzene and toluene. Immunopharmacology 21(1):23–31.1650334
Huff JE, Haseman JK, DeMarini DM, . 1989. Multiple-site carcinogenicity of benzene in Fischer 344 rats and B6C3F_1_ mice. Environ Health Perspect 82:125–163.2676495
*Hunter CG. 1968. Solvents with reference to studies on the pharmacodynamics of benzene. Proc R Soc Med 61:913–915.5679013
Hunting KL, Longbottom H, Kalavar SS, . 1995. Haematopoietic cancer mortality among vehicle mechanics. Occup Environ Med 52:673–678.7489058
*Hurley JF, Cherrie JW, Maclaren W. 1991. Exposure to benzene and mortality from leukaemia: Results from coke oven and other coal product workers [letter]. Br J Ind Med 48(7):502–503.1854653
Hustert K, Mansour H, Korte F. 1981. The “EPA Test”: A method for the determination the photo-chemical degradation of organic compounds in aquatic systems. Chemosphere 10(9):995–998.
IARC. 1982. IARC monographs on the evaluation of the carcinogenic risk of chemicals to humans. Vol. 29: Some industrial chemical and dyestuffs. Benzene. Lyon, France: World Health Organization, International Agency for Research on Cancer, 93–148.
IARC. 1987. IARC monographs on the evaluation of carcinogenic risks to humans. Overall evaluations of carcinogenicity: An updating of IARC Monographs Volumes 1 to 42. Suppl 7. Lyons, France: World Health Organization, International Agency for Research on Cancer, 38–74.
IARC. 1988. Determination of phenol and its glucurono- and sulfoconjugates in urine by gas chromatography. In: Fishbein L, O’Neill JK, eds. Environmental carcinogens method of analysis and exposure measurement: Vol. 10. Benzene and alkylated benzene. IARC Scientific Publications No. 85. Lyon, France: World Health Organization, International Agency for Research on Cancer, 281–286.
IARC. 2004. Overall evaluations of carcinogenicity to humans: As evaluated in IARC Monographs volumes 1-82 (a total of 900 agents, mixtures and exposures). Lyon, France: International Agency for Research on Cancer. http://www-cie.iarc.fr/monoeval/crthall.html. February 15, 2005.
IARC. 2007. Agents reviewed by the IARC monographs. Volumes 1-96. (alphabetical order). Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Classification/Listagentsalphorder.pdf. May 1, 2007.
Ikeda M, Ohtsuji H. 1971. Phenobarbital-induced protection against toxicity of toluene and benzene in the rat. Toxicol Appl Pharmacol 20:30–43.5110825
Ikeda M, Ohtsuji H, Imamura T. 1972. In vivo suppression of benzene and styrene oxidation by co-administered toluene in rats and effects of phenobarbital. Xenobiotica 2:101–106.5056809
Infante PF. 1978. Leukemia among workers exposed to benzene. Tex Rep Biol Med 37:153–161.752975
Infante PF, Rinsky RA, Wagoner JK, . 1977. Leukemia in benzene workers. Lancet 2:76–78.69157
Infante-Rivard C, Siemiatycki J, Lakhani R, . 2005. Maternal exposure to occupational solvents and childhood leukemia. Environ Health Perspect 113(6):787–792.
Inoue O, Kanno E, Kakizaki M, . 2000. Urinary phenylmercapturic acid as a marker of occupational exposure to benzene. Ind Health 38(2):195–204.10812842
Inoue O, Seiji K, Kasahara M, . 1986. Quantitative relation of urinary phenol levels to breathzone benzene concentrations: A factory survey. Br J Ind Med 43:692–697.3778839
Inoue O, Seiji K, Kasahara M, . 1988a. Determination of catechol and quinol in the urine of workers exposed to benzene. Br J Ind Med 45:487–492.3395585
*Inoue O, Seiji K, Nakatsuka H, . 1989a. Excretion of 1,2,4-benzenetriol in the urine of workers exposed to benzene. Br J Ind Med 46:559–565.2775675
Inoue O, Seiji K, Nakatsuka H, . 1989b. Urinary t,t-muconic acid as an indicator of exposure to benzene. Br J Ind Med 46:122–127.2923822
Inoue O, Seiji K, Watanabe T, . 1988b. Mutual metabolic suppression between benzene and toluene in man. Int Arch Occup Environ Health 60:15–20.3350599
Ireland B, Collins JJ, Buckley CF, . 1997. Cancer mortality among workers with benzene exposure. Epidemiology 8(3):318–320.9115030
IRIS. 2007. Benzene. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/iris/subst/index.html. May 1, 2007.
Irons RD. 2000. Molecular models of benzene leukemogenesis. J Toxicol Environ Health A 61(5–6):391–397.11086945
Irons RD, Neptune DA. 1980. Effects of the principal hydroxy metabolism of benzene on microtubule polymerization. Arch Toxicol 45:297–305.7447702
Irons RD, Dent JG, Baker TS, . 1980. Benzene is metabolized and covalently bound in bone marrow in situ. Chem Biol Interact 30:241–245.7389002
*Irons RD, Heck Hd’A, Moore BJ, . 1979. Effects of short-term benzene administration on bone marrow cell cycle kinetics in the rat. Toxicol Appl Pharmacol 51:399–409.538752
IRPTC. 1985. Treatment and disposal methods for waste chemicals. Data Profile Series No. 5. International Register of Potentially Toxic Chemicals. Geneva, Switzerland. United Nations Environment Programme.
ITII. 1975. Toxic and hazardous industrial chemicals safety manual for handling and disposal, with toxicity and hazard data. Tokyo, Japan: International Technical Information Institute, 62–64.
*Jakobsson R, Ahlbom A, Bellander T, . 1993. Acute myeloid leukemia among petrol station attendants. Arch Environ Health 48(4):255–259.8357276
Jen J-F, Tsai M-Y. 1994. Determination of phenol in urine by high-performance liquid chromatography with on-line precolumn enzymatic hydrolysis of the conjugates. J Chromatogr 658:87–92.
Jerina D, Daly J, Witkop B, . 1968. Role of arene oxide-oxepin system in the metabolism of aromatic substances. I. In vitro conversion of benzene oxide to a premercapturic acid and a dihydrodiol. Arch Biochem Biophys 128:176–183.
Jirka AM, Bourne S. 1982. Gas-chromatographic analysis for benzene in blood. Clin Chem 28:1492–1494.7083561
Jo WK, Kim SH. 2001. Worker exposure to aromatic volatile organic compounds in dry cleaning. Am Ind Hyg Assoc J 62(4):466–471.
Jo WK, Moon KC. 1999. Housewives’ exposure to volatile organic compounds relative to proximity to roadside service stations. Atmos Environ 33:2921–2928.
Johanson CE. 1980. Permeability and vascularity of the developing brain: Cerebellum vs cerebral cortex. Brain Res 190:3–16.6769537
Johansson I, Ingelman-Sundberg M. 1988. Benzene metabolism by ethanol-, acetone-, and benzene-inducible cytochrome P-450(IIE1) in rat and rabbit liver microsomes. Cancer Res 48:5387–5390.3416296
*Jonek J, Olkowski Z, Zieleznik B. 1965. Histochemical studies on the spinal cord of mice poisoned with benzene. Acta Histochem Suppl 20:286–296.
Jongeneelen FJ, Dirven HAAM, Leijdekkers C-M, . 1987. S-phenyl-n-acetylcysteine in urine of rats and workers after exposure to benzene. J Anal Toxicol 11:100–104.3599915
Kaden DA, Hites RA, Thilly WG. 1979. Mutagenicity of soot and associated polycyclic aromatic hydrocarbons to Salmonella typhimurium. Cancer Res 39:4152–4159.383281
Kahn H, Muzyka V. 1973. The chronic effect of benzene on porphyrin metabolism. Work Environ Health 10:140–143.
Kale PG, Baum JW. 1983. Genetic effects of benzene in Drosophila melanogaster males. Environ Mutagen 5:223–226.6407826
Kalf GF, Rushmore T, Snyder R. 1982. Benzene inhibits RNA synthesis in mitochondria from liver and bone marrow. Chem Biol Interact 42:353–370.6185244
Kalf GF, Schlosser MJ, Renz JF, . 1989. Prevention of benzene-induced myelotoxicity by nonsteroidal anti-inflammatory drugs. Environ Health Perspect 82:57–64.2792051
Kanada M, Miyagawa M, Sato M, . 1994. Neurochemical profile of effects of 28 neurotoxic chemicals on the central nervous system in rats (1) effects of oral administration on brain contents of biogenic amines and metabolites. Ind Health 32:145–164.7698903
Karacic V, Skender L, Bosner-Cucancic B, . 1995. Possible genotoxicity in low level benzene exposure. Am J Ind Med 27:379–388.7747744
Karacic V, Skender L, Prpic -Majic D. 1987. Occupational exposure to benzene in the shoe industry. Am J Ind Med 12:531–536.3687950
Karickhoff SW. 1981. Semi-empirical estimation of sorption of hydrophobic pollutants on natural sediments and soils. Chemosphere 10:833–846.
Karlson U, Frankenberger WT Jr. 1989. Microbial degradation of benzene and toluene in groundwater. Bull Environ Contam Toxicol 43:505–510.2804391
Kasai H, Nishimura S. 1986. Hydroxylation of guanine in nucleosides and DNA at the C-8 position by heated glucose and oxygen radical-forming agents. Environ Health Perspect 67:111–116.3757945
Kašuba V, Rozgaj R, Sentija K. 2000. Cytogenic changes in subjects occupationally exposed to benzene. Chemosphere 40(3):307–310.10665421
Kawai T, Yamaoka K, Uchida Y, . 1990. Benzene exposure in a Japanese petroleum refinery. Toxicol Lett 52(2):135–139.2377997
Kawai T, Yamaoka K, Uchida Y, . 1991. Exposure to vapors of benzene and other aromatic solvents in tank truck loading and delivery. Bull Environ Contam Toxicol 46(1):1–8.2001480
Keener WK, Arp DJ. 1994. Transformations of aromatic compounds by Nitrosomonas europaea. Appl Environ Microbiol 60(6):1914–1920.16349282
Keller KA, Snyder CA. 1986. Mice exposed in utero to low concentrations of benzene exhibit enduring changes in their colony forming hematopoietic cells. Toxicology 42:171–181.3798466
Keller KA, Snyder CA. 1988. Mice exposed in utero to 20 ppm benzene exhibit altered numbers of recognizable hematopoietic cells up to seven weeks after exposure. Fundam Appl Toxicol 10:224–232.3356309
Kelly TJ, Callahan PJ, Pleil J, Evans GF. 1993. Method development and field measurements for polar volatile organic compounds in ambient air. Environ Sci Technol 27(6):1146–1152.
Kelsey KT, Ross D, Traver RD, . 1997. Ethnic variation in the prevalence of a common HAD(P)H quinone oxidoreductase polymorphism and its implications for anticancer chemotherapy. Br J Cancer 76:852–854.9328142
Kenaga EE. 1980. Predicted bioconcentration factors and soil sorption coefficients of pesticides and other chemicals. Ecotoxicol Environ Safety 4:26–38.7379718
Kennedy LG, Hutchins SR. 1992. Applied geologic, microbiological, and engineering constraints of in-situ BTEX bioremediation. Remediation 3:83–110.
Kenyon EM, Seaton MJ, Himmelstein MW, . 1998. Influence of gender and acetone pretreatment on benzene metabolism in mice exposed by nose-only inhalation. J Toxicol Environ Health A 55(6):421–443.9833972
Kenyon EM, Seeley ME, Janszen D, . 1995. Dose-, route-, and sex-dependent urinary excretion of phenol metabolites of B6C3F_1_ mice. J Toxicol Environ Health 44:219–233.7853423
*Khuder SA, Youngdale MC, Schaub EA. 1999. Assessment of complete blood count variations among workers exposed to low levels of benzene. J Occup Environ Med 41(9):821–826.
Kiang PH, Grob RL. 1986. A headspace technique for the determination of volatile compounds in soil. J Environ Sci Health, Part A 21:71–100.
Kimmel CA, Wilson JG. 1973. Skeletal deviations in rats: Malformations or variations? Teratology 8:309–316.
Kinney PL, Chillrud SN, Ramstrom S, . 2002. Exposures to multiple air toxics in New York City. Environ Health Perspect 110(Suppl 4):539–546.
Kipen HM, Cody RP, Goldstein BD. 1989. Use of longitudinal analysis of peripheral blood counts to validate historical reconstructions of benzene exposure. Environ Health Perspect 82:199–206.2792041
Kirschner EM. 1995. Production of top 50 chemicals increased substantially in 1994. Chem Eng News (April 10, 1995):16–20.
Kissling M, Speck B. 1972. Further studies on experimental benzene induced aplastic anemia. Blut 25:97–103.5050160
Kissling M, Speck B. 1973. Chromosome aberrations in experimental benzene intoxication. Helv Med Acta 36:59–66.
*Klan MJ, Adams DO, Lewis JG. 1990. Effects of exposure to benzene in vivo on the murine mononuclear phagocyte system. Toxicol Appl Pharmacol 103(2):198–205.2158675
Kok PW, Ong CN. 1994. Blood and urinary benzene determined by headspace gas chromatography with photoionization detection: Application in biological monitoring of low-level nonoccupational exposure. Int Arch Occup Environ Health 66(3):195–201.7814100
Kolachana P, Subrahmanyam VV, Meyer KB, . 1993. Benzene and its phenolic metabolites produce oxidative DNA damage in HL60 cells in vitro and in the bone marrow in vivo. Cancer Res 53(5):1023–1026.8439949
Komori M, Nishio K, Kitada M, . 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29:4430–4433.2350547
Koop DR, Laethem CL. 1992. Inhibition of rabbit microsomal cytochrome P-450 2E1-dependent p-nitrophenol hydroxylation by substituted benzene derivatives. Drug Metab Dispos 20(5):775–777.
*Koop DR, Laethem CL, Schnier GG. 1989. Identification of ethanol-inducible P450 isozyme 3a (P45011E1) as a benzene and phenol hydroxylase. Toxicol Appl Pharmacol 98:278–288.2711391
Korte F, Klein W. 1982. Degradation of benzene in the environment. Ecotoxicol Environ Safety 6:311–327.7117183
Kouniali A, Cicolella A, Gonzalez-Flesca N, . 2003. Environmental benzene exposure assessment for parent-child pairs in Rouen, France. Sci Total Environ 308:73–82.
Kowalski JD, Shkiya JM, Tsou G. 1985. Ambient sampling and analysis of halogenated hydrocarbons and benzene. In: APCA Annual Meeting, June 16-21. Detroit, MI: Air Pollution Control Association, 2–13.
Kozioski RP. 1985. Determination of benzene and toluene in soils and plant material by azeotropic distillation. Bull Environ Contam Toxicol 34:10–16.
Kraut A, Lilis R, Marcus M, . 1988. Neurotoxic effects of solvent exposure on sewage treatment workers. Arch Environ Health 43:263–268.3415351
Krishnan K, Andersen ME. 1994. Physiologically-based pharmacokinetic modeling in toxicology. In: Hayes W, ed. Principles and methods of toxicology. 3rd ed. New York, NY: Raven Press, Ltd., 149–188.
Krishnan K, Andersen ME, Clewell HJ III, . 1994. Physiologically-based pharmacokinetic modeling of chemical mixtures. In: Yang RSA, ed. Toxicology of chemical mixtures. New York, NY: Academic Press, 399–437.
Kuna RA, Kapp RW. 1981. Embryotoxic/teratogenic potential of benzene vapor in rats. Toxicol Appl Pharmacol 57:1–7.7209981
Kuna RA, Nicolich MJ, Schroeder RE, . 1992. A female rat fertility study with inhaled benzene. J Am Coll Toxicol 11(3):275–282.
Kunisaki TA, Augenstein WL. 1994. Drug-and toxin-induced seizures. Emerg Med Clin North Am 12(4):1027–1056.7956886
*Laerum OD. 1973. Reticulum cell neoplasms in normal and benzene treated hairless mice. Acta Pathol Microbiol Scand Sect A 81(1):57–63.4569534
Lagorio S, Forastiere F, Iavarone I, . 1994b. Mortality of filling station attendants. Scand J Work Environ Health 20:331–338.7863296
Lagorio S, Tagesson C, Forastiere F, . 1994a. Exposure to benzene and urinary concentrations of 8hydroxydeoxyguanosine, a biological marker of oxidative damage to DNA. Occup Environ Med 51:739–743.7849850
Laitinen J, Kangas J, Pekari K, . 1994. Short time exposure to benzene and gasoline at garages. Chemosphere 28:197–205.
Lakhanisky TH, Hendrickx B. 1985. Induction of DNA single-strand breaks in CHO cells in culture. Prog Mutat Res 5:367–370.
Lan Q, Zhang L, Li G, . 2004a. Hematotoxicity in workers exposed to low levels of benzene. Science 306:1774–1776.15576619
Lan Q, Zhang L, Li G, . 2004b. Hematotoxicity in workers exposed to low levels of benzene: Supporting online material. Science 306:1774–1776. http://www.sciencemag.org/cgi/data/306/5702/1774/DC1/1. August 2, 2005.15576619
Lange A, Smolik R, Zatonski W, . 1973a. Leukocyte agglutinins in workers exposed to benzene, toluene and xylene. Int Arch Arbeitsmed 31:45–40.4692815
Lange A, Smolik R, Zatonski W, . 1973b. Serum immunoglobulin levels in workers exposed to benzene, toluene and xylene. Int Arch Arbeitsmed 31:37–44.4692814
Larson TV, Koenig JQ. 1994. Wood smoke: Emissions and noncancer respiratory effects. Annu Rev Public Health 15:133–156.8054078
Latriano L, Goldstein BD, Witz G. 1986. Formation of muconaldehyde, an open-ring metabolite of benzene, in mouse liver microsomes: An additional pathway for toxic metabolites. Proc Natl Acad Sci USA 83:8356–8360.3464956
Lauwerys RR, Buchet JP, Adrien F. 1994. Muconic acid in urine: A reliable indicator of occupational exposure to benzene. Am J Ind Med 25:297–300.8147402
*Lee EW, Garner CD. 1991. Effects of benzene on DNA strand breaks in vivo versus benzene metabolite-induced DNA strand breaks in vitro in mouse bone marrow cells. Toxicol Appl Pharmacol 108(3):497–508.2020971
Lee B-L, New A-L, Kok P-W, . 1993. Urinary trans,trans-muconic acid determined by liquid chromatography: Application in biological monitoring of benzene exposure. Clin Chem 39:1788–1792.8375048
Lee E, Im H, Oh E, . 2005. DNA damage in T and B lymphocytes, bone marrow, spleens, and livers of rats exposed to benzene. Inhal Toxicol 17(7–8):401–408.16020036
Lee EW, Garner CD, Johnson JT. 1988. A proposed role played by benzene itself in the induction of acute cytopenia: Inhibition of DNA synthesis. Res Commun Chem Pathol Pharmacol 60:27–46.3381009
Lee EW, Johnson JT, Garner CD. 1989. Inhibitory effect of benzene metabolites on nuclear DNA synthesis in bone marrow cells. J Toxicol Environ Health 26:277–291.2926830
Leeder JS, Kearns GL. 1997. Pharmcogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
Lemire S, Ashley D, Olaya P, . 2004. Environmental exposure of commuters in Mexico City to volatile organic compounds as assessed by blood concentrationas, 1998. Salud Pub Mexico Jan–Feb(1):32–38.
Leung H. 1993. Physiologically-based pharmacokinetic modeling. In: Ballantine B, Marro T, Turner T, eds. General and applied toxicology. Vol. I. New York, NY: Stockton Press, 153–164.
Levy A. 1973. The photochemical smog reactivity of organic solvents. In: Solvent theory and practices. Adv Chem Ser 124:70–94.
Lévay G, Bodell WJ. 1992. Potentiation of DNA adduct formation in HL-60 cells by combinations of benzene metabolites. Proc Natl Acad Sci USA 89(15):7105–7109.1496006
Lévay G, Pathak DN, Bodell WJ. 1996. Detection of DNA adducts in the white blood cells of B6C3F1 mice treated with benzene. Carcinogenesis 17(1):151–153.8565125
Lewis SJ, Bell GM, Cordingley N, . 1997. Retrospective estimation of exposure to benzene in a leukaemia case-control study of petroleum marketing and distribution workers in the United Kingdom. Occup Environ Med 54(3):167–175.9155777
Lewis JG, Stewart W, Adams DO. 1988. Role of oxygen radicals in induction of DNA damage by metabolites of benzene. Cancer Res 48:4762–4765.2842037
Li G-L, Linet MS, Hayes RB, . 1994. Gender differences in hematopoietic and lymphoproliferative disorders and other cancer risks by major occupational group among workers exposed to benzene in China. J Occup Med 36(8):875–881.7807268
Li G-L, Yin S-N, Watanabe T, . 1986. Benzene-specific increase in leukocyte alkaline phosphatase activity in rats exposed to vapors of various organic solvents. J Toxicol Environ Health 19:581–589.3783773
Li L, Sun W, Gong Z, . 1992. Effect of low benzene exposure on neurobehavioral function, AChE in blood and brain and bone marrow picture in mice. Biomed Environ Sci 5(4):349–354.1489529
Li Q, Aubrey MT, Christian T, . 1997. Differential inhibition of DNA synthesis in human T cells by the cigarette tar components hydroquinone and catechol. Fundam Appl Toxicol 38(2):158–165.9299189
Li Q, Kasten-Jolly J, Yen Y, . 1998. Reversal of hydroquinone-mediated suppression of T cell proliferation by transfection of the M2 subunit of ribonucleotide reductase. Toxicol Appl Pharmacol 150(1):154–157.9630464
Li Y, Kuppusamy P, Zweier JL, . 1995. ESR evidence for the generation of reactive oxygen species from the copper-mediated oxidation of the benzene metabolite, hydroquinone: Role in DNA damage. Chem Biol Interact 94(2):101–120.7828218
Lin T-F, Little JC, Nazaroff WW. 1994. Transport and sorption of volatile organic compounds and water vapor within dry soil grains. Environ Sci Technol 28:322–330.22176179
Lindstrom AB, Highsmith VR, Buckley TJ, . 1994. Gasoline-contaminated ground water as a source of residential benzene exposure: A case study. J Expos Anal Environ Epidemiol 4(2):183–195.
Lindstrom AB, Yeowell-O’Connell K, Waidyanatha S, . 1997. Measurement of benzene oxide in the blood of rats following administration of benzene. Carcinogenesis 18(8):1637–1641.9276641
Lindstrom AB, Yeowell-O’Connell K, Waidyanatha S, . 1999. Investigation of benzene oxide in bone marrow and other tissues of F344 rats following metabolism of benzene in vitro and in vivo. Chem Biol Interact 122(1):45–58.
Linet MS, Harlow SD, McLaughlin JK. 1987. A case-control study of muliple myeloma in whites: Chronic antigenic stimulation, occupation, and drug use. Cancer Res 47:2978–2981.3567914
Linet MS, Yin S-N, Travis LB, . 1996. Clinical features of hematopoietic malignancies and related disorders among benzene-exposed workers in China. Environ Health Perspect 104(Suppl 6):1353–1364.9118920
Lioy PJ, Pellizzari E. 1995. Conceptual framework for designing a national survey of human exposure. J Expos Anal Environ Epidemiol 5(3):425–444.
Liu L, Zhang Q, Feng J, . 1996. The study of DNA oxidative damage in benzene-exposed workers. Mutat Res 370(3–4):45–50.
Livingston, AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4:301–324.351201
Lodén M. 1986. The in vitro permeability of human skin to benzene, ethylene glycol, formaldehyde, and n-hexane. Acta Pharmacol Toxicol 58:382–389.
Longacre SL, Kocsis JJ, Snyder R. 1981a. Influence of strain differences in mice on the metabolism and toxicity of benzene. Toxicol Appl Pharmacol 60:398–409.7292478
Longacre SL, Kocsis JJ, Witmer CM, . 1981b. Toxicological and biochemical effects of repeated administration of benzene in mice. J Toxicol Environ Health 7:223–237.7230271
Lovern MR, Maris ME, Schlosser PM. 1999. Use of a mathematical model of rodent in vitro benzene metabolism to predict human in vitro metabolism data. Carcinogenesis 20(8):1511–1520.10426800
Lovern MR, Turner MJ, Meyer M, . 1997. Identification of benzene oxide as a product of benzene metabolism by mouse, rat, and human liver microsomes. Carcinogenesis 18(9):1695–1700.9328163
Low LK, Meeks JR, Norris KJ, . 1989. Pharmacokinetics and metabolism of benzene in Zymbal gland and other key target tissues after oral administration in rats. Environ Health Perspect 82:215–222.2792043
Lowry WT, Juarez L, Petty CS, . 1985. Studies of toxic gas production during actual structural fires in the Dallas area. J Forensic Sci 30:59–72.3981122
Ludwig RC, Eksteen R. 1988. LC column switching for the rapid analysis of benzene in unleaded gasoline. LC-GC 6:250–252.
Luke CA, Tice RR, Drew RT. 1988a. The effect of exposure regimen and duration on benzene-induced bone-marrow damage in mice: I. Sex comparison in DBA/2 mice. Mutat Res 203:251–271.3405235
Luke CA, Tice RR, Drew RT. 1988b. The effect of exposure regimen and duration on benzene-induced bone marrow damage in mice: II. Strain comparisons involving B6C3F_1_, C57BL/6 and DBA/2 male mice. Mutat Res 203:273–295.3405236
Lumley M, Barker H, Murray JA. 1990. Benzene in petrol [letter; comment]. Lancet 336(8726):1318–1319.
Lutz WK, Schlatter CH. 1977. Mechanism of the carcinogenic action of benzene: Irreversible binding to rat liver DNA. Chem Biol Interact 18:241–245.890848
Lyman WJ. 1982. Atmospheric residence time. In: Lyman WJ, Reehl WF, Rosenblatt DH, eds. Handbook of chemical property estimation methods: Environmental behavior of organic compounds. New York, NY: McGraw-Hill.
Lysyj I, Perkins G, Farlow JS. 1980. Trace analysis for aromatic hydrocarbons in natural waters. Environ Int 4:407–416.
*MacEachern L, Laskin DL. 1992. Increased production of tumor necrosis factor-α by bone marrow leukocytes following benzene treatment of mice. Toxicol Appl Pharmacol 113(2):260–266.1561635
*MacEachern L, Snyder R, Laskin DL. 1992. Alterations in the morphology and functional activity of bone marrow phagocytes following benzene treatment of mice. Toxicol Appl Pharmacol 117(2):147–154.1471147
MacIntosh DL, Xue J, Ozkaynak H, . 1995. Population-based exposure model for benzene. J Expos Anal Environ Epidemiol 5(3):375–403.
Mackay D, Leinonen PJ. 1975. Rate of evaporation of low-solubility contaminants from water bodies to atmosphere. Environ Sci Technol 9:1178–1180.
MacLeod M, Mackay D. 1999. An assessment of the environmental fate and exposure of benzene and the chlorobenzenes in Canada. Chemosphere 38(8):1777–1796.10101848
Magos GA, Lorenzana-Jimenez M, Vidrio H. 1990. Toluene and benzene inhalation influences on ventricular arrhythmias in the rat. Neurotoxicol Teratol 12(2):119–124.2333062
Maibach HI, Anjo DM. 1981. Percutaneous penetration of benzene and benzene contained in solvents in the rubber industry. Arch Environ Health 36:256–260.7294890
Major J, Jakab M, Kiss G, . 1994. Chromosome aberration, sister-chromatid exchange, proliferative rate index, and serum thiocyanate concentration in smokers exposed to low-dose benzene. Environ Mol Mutagen 23:137–142.8143702
Major J, Kemeny G, Tompa A. 1992. Genotoxic effects of occupational exposure in the peripheral blood lymphocytes of pesticide preparing workers in Hungary. Acta Med Hung 49(1–2):79–90.1296189
Malachowsky KJ, Phelps TJ, Teboli AB, . 1994. Aerobic mineralization of trichloroethylene, vinyl chloride, and aromatic compounds by Rhodococcus species. Appl Environ Microbiol 60(2):542–548.16349184
Maltoni C, Ciliberti A, Cotti G, . 1989. Benzene, an experimental multipotential carcinogen: Results of the long-term bioassays performed at the Bologna Institute of Oncology. Environ Health Perspect 82:109–124.2792037
Maltoni C, Conti B, Cotti G. 1983. Benzene: A multipotential carcinogen: Results of long-term bioassays performed at the Bologna Institute of Oncology. Am J Ind Med 4:589–630.6353911
Maltoni C, Conti B, Cotti G, . 1985. Experimental studies on benzene carcinogenicity at the Bologna Institute of Oncology: Current results and ongoing research. Am J Ind Med 7:415–446.4003403
Maltoni C, Cotti G, Valgimigli L, . 1982a. Hepatocarcinomas in Sprague-Dawley rats following exposure to benzene by inhalation: First experimental demonstration. Med Lav 4:446–450.
Maltoni C, Cotti G, Valgimigli L, . 1982b. Zymbal gland carcinomas in rats following exposure to benzene by inhalation. Am J Ind Med 3:11–16.7124739
Mani C, Freeman S, Nelson DO, . 1999. Species and strain comparisons in the macromolecular binding of extremely low doses of [^14^C]benzene in rodents, using accelerator mass spectrometry. Toxicol Appl Pharmacol 159(2):83–90.10495771
Mannino DM, Schreiber J, Aldous K, . 1995. Human exposure to volatile organic compounds: A comparison of organic vapor monitoring badge levels with blood levels. Int Arch Occup Environ Health 67:59–64.7622282
Marrazzini A, Chelotti L, Barrai I, . 1994. In vivo genotoxic interactions among three phenolic benzene metabolites. Mutat Res 341(1):29–46.7523941
Mathews JM, Etheridge AS, Matthews HB. 1998. Dose-dependent metabolism of benzene in hamsters, rats and mice. Toxicol Sci 44(1):14–21.9720136
Mattie DR, Bates G D JR, Jepson GW, . 1994. Determination of skin:air partition coefficients for volatile chemicals: Experimental method and applications. Fundam Appl Toxicol 22(1):51–57.8125213
Mayer GJ, Cheng IS, Pau P, . 1994. Emissions of air toxics from wastewater treatment plants. Water Environ Res 66:140–144.
Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74:135–149.1387742
Mazzullo M, Bartoli S, Bonora B, . 1989. Benzene adducts with rat nucleic acids and proteins: Dose-response relationship after treatment in vivo. Environ Health Perspect 82:259–266.2477240
McAllister PM, Chiang CY. 1994. A practical approach to evaluating natural attenuation of contaminants in ground water. Ground Water Monit Remed 14:161–173.
McDonald TA, Yeowell-O’Connell K, Rappaport SM. 1994. Comparison of protein adducts of benzene oxide and benzoquinone in the blood and bone marrow of rats and mice exposed to [^14^C/^13^C_6_] benzene. Cancer Res 54:4907–4914.8069856
McDougal JN, Jepson GW, Clewell HJ III, . 1990. Dermal absorption of organic chemical vapors in rats and humans. Fundam Appl Toxicol 14:299–308.2318354
McKinney PA, Alexandria FE, Cartwright RA, . 1991. Parental occupations of children with leukaemia in West Cumbria, North Humberside, and Gateshead. Br Med J 302(6778):681–687.2021741
McMahon TF, Birnbaum LS. 1991. Age-related changes in disposition and metabolism of benzene in male C57BL/6N mice. Drug Metab Dispos 19(6):1052–1057.1687010
*McMurry ST, Lochmiller RL, Vestey MR, . 1991. Acute effects of benzene and cyclophosphamide exposure on cellular and humoral immunity of cotton rats, Sigmodon hispidus. Bull Environ Contam Toxicol 46(6):937–945.1863803
McNeal TP, Nyman PJ, Diachenko GW, . 1993. Survey of benzene in foods by using headspace concentration techniques and capillary gas chromatography. J AOAC Int 76:1213–1219.8286958
Medinsky MA. 1995. The application of physiologically based pharmacokinetic-pharmacodynamic (PBPK-PD) modeling to understanding the mechanism of action of hazardous substances. Toxicology Lett 79:185–191.
Medinsky MA, Sabourin PJ, Henderson RF, . 1989b. Differences in the pathways for metabolism of benzene in rats and mice simulated by a physiological model. Environ Health Perspect 82:43–49.2792050
Medinsky MA, Sabourin PJ, Lucier G, . 1989a. A physiological model for simulation of benzene metabolism by rats and mice. Toxicol Appl Pharmacol 99:193–206.2734786
Medinsky MA, Sabourin PJ, Lucier G, . 1989c. A toxicokinetic model for simulation of benzene metabolism. Exp Pathol 37:150–154.2637146
Melikian AA, Prahalad AK, Hoffmann D. 1993. Urinary trans,trans-muconic acid as an indicator of exposure to benzene in cigarette smokers. Cancer Epidemiol Biomarkers Prev 2(1):47–51.8420612
Melikian AA, Prahalad AK, Secker-Waker RH. 1994. Comparison of the levels of the urinary benzene metabolite trans,trans-muconic acid in smokers and nonsmokers, and the effects of pregnancy. Cancer Epidemiol 3:239–244.
Meyne J, Legator MS. 1980. Sex-related differences in cytogenetic effects of benzene in the bone marrow of Swiss mice. Environ Mutagen 2:43–50.7327159
Michael LC, Erickson MD, Parks SP, . 1980. Volatile environmental pollutants in biological matrices with a headspace purge technique. Anal Chem 52:1836–1841.7435989
Michael LC, Pellizzari ED, Wiseman RW. 1988. Development and evaluation of a procedure for determining volatile organics in water. Environ Sci Technol 22:565–570.22195629
Michon S. 1965. [Disturbances of menstruation in women working in an atmosphere polluted with aromatic hydrocarbons.] Pol Tyg Lek 20:1648–1649. (Polish)
Midzenski MA, McDiarmid MA, Rothman N, . 1992. Acute high dose exposure to benzene in shipyard workers. Am J Ind Med 22:553–565.1442788
Miller MM, Wasik SP, Huang G-L, . 1985. Relationships between octanol-water partition coefficients and aqueous solubility. Environ Sci Technol 19:522–529.22257354
Mohamed MF, Kang D, Aneja VP. 2002. Volatile organic compounds in some urban locations in United States. Chemosphere 47:863–882.12079081
Money CD, Gray CN. 1989. Exhaled breath analysis as a measure of workplace exposure to benzene ppm. Ann Occup Hyg 33:257–262.2757325
Morello-Frosch RA, Woodruff TJ, Axelrad DA, . 2000. Air toxics and health risks in California: The public health implications of outdoor concentrations. Risk Anal 20(2):273–291.10859786
Morgan GJ, Alvares CL. 2005. Benzene and the hemopoietic stem cell. Chem Biol Interact 153–154:217–222.
Morikawa M, Imanaka T. 1993. Isolation of a new mixotrophic bacterium which can fix CO_2_ and assimilate aliphatic and aromatic hydrocarbons anaerobically. J Ferment Bioengin 76(4):280–283.
Morimoto K. 1976. Analysis of combined effects of benzene with radiation on chromosomes in cultured human leukocytes. Jpn J Ind Health 18:23–34.
Morimoto K. 1983. Induction of sister chromatid exchanges and cell division delays in human lymphocytes by microsomal activation of benzene. Cancer Res 43:1330–1334.6825102
Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokin 5:485–527.
*Moszczynski P. 1981. Organic solvents and T lymphocytes. Lancet 1:438.6110061
Mukhametova IM, Vozovaya MA. 1972. [Reproductive power and the incidence of gynecological affections in female workers exposed to the combined effect of benzene and chlorinated hydrocarbons.] Gig Tr Prof Zabol 16:6–9. (Russian)
Mullin AH, Nataraj D, Ren JJ, . 1998. Inhaled benzene increases the frequency and length of lacI deletion mutations in lung tissue of mice. Carcinogenesis 19(10):1723–1733.9806151
Mullin AH, Rando R, Esmundo F, . 1995. Inhalation of benzene leads to an increase in the mutant frequencies of a lacI transgene in lung and spleen tissues of mice. Mutat Res 327:121–129.7870081
Murray FJ, John JA, Rampy LW, . 1979. Embryotoxicity of inhaled benzene in mice and rabbits. Am Ind Hyg Assoc J 40:993–998.532786
Mushrush GW, Mose DG, Sullivan KT. 1994. Soil vapor and groundwater analysis from a recent oil spill. Bull Environ Contam Toxicol 52:31–38.8130414
Naft BN. 1992. Removing benzene from wastewater. Environ Protect 3(2):47–54.
Nahum LH, Hoff HE. 1934. The mechanism of sudden death in experimental acute benzol poisoning. J Pharmacol Exp Ther 50:336–345.
Nakai JS, Chu I, Li-Muller A, . 1997. Effect of environmental conditions on the penetration of benzene through human skin. J Toxicol Environ Health 51(5):447–462.9233379
Nakajima T, Okino T, Sato A. 1987. Kinetic studies on benzene metabolism in rat liver—possible presence of three forms of benzene metabolizing enzymes in the liver. Biochem Pharmacol 36:2799–2804.3632707
Nakajima T, Okuyama S, Yonekura I, . 1985. Effects of ethanol and phenobarbital administration on the metabolism and toxicity of benzene. Chem Biol Interact 55:23–38.4064192
NAS/NRC. 1989. Report of the oversight committee. In: Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press.
NCI. 2003. Cancer progress report. Prevention: Environmental. Benzene in the air. National Cancer Institute. http://progressreport.cancer.gov/doc.asp?pid=1&did=21&chid=9&coid=54&mid=vpco. February 08, 2005.
Nebert DW, Roe AL, Vandale SE, . 2002. NAD(P)H:quinone oxidoreductase (NQO1) polymorphism, exposure to benzene, and predisposition to disease: A huGE review. Genet Med 4(2):62–70.11882782
Nedelcheva V, Gut I, Soucek P, . 1999. Metabolism of benzene in human liver microsomes: Individual variations in relation to CYP2E1 expression. Arch Toxicol 73(1):33–40.10207612
NEMI. 2005a. Method number 602. Purgeable aromatics via GC with photoionization detector (PID) Washington, DC: U.S. Environmental Protection Agency. National Environmental Methods Index.
NEMI. 2005b. Method number 624. Purgeable organic compounds via GC/MS. Washington, DC: U.S. Environmental Protection Agency. National Environmental Methods Index.
NEMI. 2005c. Method number 1624. Volatile organic compounds by GS/MS. Washington, DC: U.S. Environmental Protection Agency. National Environmental Methods Index.
*Nerland DE, Pierce WM Jr. 1990. Identification of N-acetyl-S-(2,5-dihydroxyphenyl)-L-cysteine as a urinary metabolite of benzene, phenol, and hydroquinone. Drug Metab Dispos 18(6):958–961.1981544
NESCAUM. 1989. Evaluation of the health effects from exposure to gasoline and gasoline vapors. Final Report. Northeast States for Coordinated Air Use Management, Air Toxics Committee. 3-1 – 3-16, 5-1 – 5-33.
Neun DJ, Penn A, Snyder CA. 1992. Evidence for strain-specific differences in benzene toxicity as a function of host target cell susceptibility. Arch Toxicol 66(1):11–17.1580791
Neun DJ, Penn A, Snyder CA. 1994. Erythroid progenitor cells that survive benzene exposure exhibit greater resistance to the toxic benzene metabolites benzoquinone and hydroquinone. Arch Toxicol 68:535–540.7998818
NFPA. 1994. Benzene. Fire protection guide to hazardous materials. 11th edition. Quincy, MA: National Fire Protection Association.
Nilsson RI, Nordlinder RG, Tagesson C, . 1996. Genotoxic effects in workers exposed to low levels of benzene from gasoline. Am J Ind Med 30(3):317–324.8876800
*Ning H, Kado NY, Kuzmicky PA, . 1991. Benzene-induced micronuclei formation in mouse fetal liver blood, peripheral blood, and maternal bone marrow cells. Environ Mol Mutagen 18(1):1–5.1864264
NIOSH. 1974. Criteria for a recommended standard. Occupational exposure to benzene. Washington, DC: U.S. Department of Health, Education, and Welfare, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health. NIOSH 74-137.
NIOSH. 1984. NIOSH manual of analytical methods, Vol. 2, 3rd ed. Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health, 1501–1506.
NIOSH. 1990. National occupational exposure survey 1981-1983. U.S. Department of Health and Human Services. Cincinnati, OH: National Institute for Occupational Safety and Health.
NIOSH. 1992. NIOSH recommendations for occupational safety and health: Compendium of policy documents and statements. Table 1. NIOSH recommended safety and health standards for hazardous agents in the workplace. U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health.
NIOSH. 1994. Method 3700. Benzene by portable GC. NIOSH manual of analytical methods. Fourth ed. National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/nmam/. July 06, 2005.
NIOSH. 2005. Benzene. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. http://www.cdc.gov/niosh/npg/npgdname.html. February 15, 2004.
*Nojima K, Fukaya K, Fukui S, . 1975. Studies on photochemistry of aromatic hydrocarbons: II. The formation of nitrophenols and nitrobenzene by the photochemical reaction of benzene in the presence of nitrogen monoxide. Chemosphere 2:77–82.
Nomiyama K, Nomiyama H. 1974a. Respiratory retention, uptake and excretion of organic solvents in man: Benzene, toluene, n-hexane, trichloroethylene, acetone, ethyl acetate and ethyl alcohol. Int Arch Arbeitsmed 32:75–83.4813696
Nomiyama K, Nomiyama H. 1974b. Respiratory elimination of organic solvents in man: Benzene, toluene, n-hexane, trichloroethylene, acetone, ethyl acetate and ethyl alcohol. Int Arch Arbeitsmed 32:85–91.4813697
Norpoth K, Stuker W, Krewet E, . 1988. Biomonitoring of benzene exposure by trace analyses of phenylguanine. Int Arch Occup Environ Health 60:163–168.3384481
NRC. 1993. National Research Council. Pesticides in the diets of infants and children. Washington, DC: National Academy Press.
NTP. 1986. Toxicology and carcinogenesis studies of benzene (CAS No. 71-43-2) in F344/N rats and B6C3F_1_ mice (gavage studies). Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Institute of Health. National Toxicology Program--technical report series no. 289. NIH publication no. 86-2545.
NTP. 1994. Seventh annual report on carcinogens: 1994 summary. National Toxicology Program. Benzene. U.S. Department of Health and Human Services, Public Health Service.
NTP. 2005. Report on carcinogens. 11th ed. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. http://ntp-server.niehs.nih.gov/ntp/roc/toc11.html. February 15, 2004.
Nutmagul W, Cronn DR. 1985. Determination of selected atmospheric aromatic hydrocarbons at remote continental and oceanic locations using photoionization/flame-ionization detection. J Atmos Chem 2:415–433.
NYSDOH. 2005. Study of volatile organic chemicals in air of fuel oil heated homes. New York State Department of Health. http://www.health.state.ny.us/nysdoh/indoor/fuel_oil.html. March 04, 2005.
O’Bryan TR, Ross RH. 1988. Chemical scoring system for hazard and exposure identification. J Toxicol Environ Health 1:119–134.
Oberly TJ, Bewsey BJ, Probst GS. 1984. An evaluation of the L5178Y TK^+^/^−^ mouse lymphoma forward mutation assay using 42 chemicals. Mutat Res 125:291–306.6700611
Ogata M, Taguchi T. 1987. Quantitation of urinary metabolites of toluene, xylene, styrene, ethylbenzene, benzene and phenol by automated high performance liquid chromatography. Int Arch Occup Environ Health 59:263–272.3570490
Ogata M, Fujisawa K, Ogino Y, . 1984. Partition coefficients as a measure of bioconcentration potential of crude oil compounds in fish and shellfish. Bull Environ Contam Toxicol 33:561–567.6498361
Olsen J. 1983. Organic solvents as possible risk factors of low birthweight. J Occup Med 25:854–855.6655519
Omiecinski CJ, Hassett, Hosagrahara V. 2000. Epoxide hydrolase–polymorphism and role in toxicology. Toxicol Lett 112–113:365–370.
Ong CN, Lee BL. 1994. Determination of benzene and its metabolites: Application in biological monitoring of environmental and occupational exposure to benzene. J Chromatogr B Biomed Appl 660(1):1–22.7858701
Ong CN, Kok PW, Lee BL, . 1995. Evaluation of biomarkers for occupational exposure to benzene. Occup Environ Med 52(8):528–533.7663638
Orzechowski A, Schwarz LR, Schwegler U, . 1995. Benzene metabolism in rodent hepatocytes: Role of sulphate conjugation. Xenobiotica 25(10):1093–1102.8578765
OSHA. 1977. Final environmental impact statement: Benzene. U.S. Department of Labor, Occupational Safety and Health Administration. Fed Regist 42:22516–22529, 27460–27464.
OSHA. 1985. Occupational exposure to benzene. Proposed rule and notice of hearing. U.S. Department of Labor, Occupational Safety and Health Administration. Fed Regist 50:50512–50517, 50540, 50528–50529, 50577–50582.
OSHA. 1987. Occupational exposure to benzene. Final Rule. U.S. Department of Labor, Occupational Safety and Health Administration. Fed Regist 52:34460–34578.
OSHA. 2003. Benzene. U.S. Department of Labor, Occupational Safety and Health Administration. Code of Federal Regulations. 29CFR1910.1028.
OSHA. 2005a. Air contaminants. Occupational safety and health standards for shipyard employment. 1000 Washington, DC: U.S. Department of Labor, Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915. http://www.osha.gov/comp-links.html. February 15, 2005.
OSHA. 2005b. Air contaminants. Occupational safety and health standards for shipyard employment. Washington, DC: U.S. Department of Labor, Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1028. http://www.osha.gov/comp-links.html. February 15, 2005.
OSHA. 2005c. Benzene. Limits for air contaminants. Occupational safety and health standards. Washington, DC: U.S. Department of Labor, Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1028. http://www.osha.gov/comp-links.html. February 15, 2005.
OSHA. 2005d. Gases, vapors, fumes, dusts, and mists. Safety and health regulations for construction. Washington, DC: U.S. Department of Labor, Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55, Appendix A. http://www.osha.gov/comp-links.html. February 15, 2005.
OSHA. 2005e. Limits for air contaminants. Occupational safety and health standards. Washington, DC: U.S. Department of Labor, Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. http://www.osha.gov/comp-links.html. February 15, 2005.
OSHA. 2005f. Safety and Health Regulations for Construction. Toxic and Hazardous Substances. Washington, DC: U.S. Department of Labor, Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.1128. http://www.osha.gov/comp-links.html. March 31, 2005.
Ott MG, Townsend JC, Fishbeck WA, . 1978. Mortality among workers occupationally exposed to benzene. Arch Environ Health 33:3–10.629594
Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
Paci E, Buiatti E, Costantini AS, . 1989. Aplastic anemia, leukemia and other cancer mortality in a cohort of shoe workers exposed to benzene. Scand J Work Environ Health 15:313–318.2799316
Page BD, Conacher HBS, Salminen J, . 1993. Survey of bottled drinking water sold in Canada. II. Selected volatile organic compounds. J AOAC Int 76:26–31.8448439
Pagnotto LD, Elkins HB, Brugsch HG, . 1961. Industrial benzene exposure from petroleum naphtha: I. Rubber coating industry. Am Ind Hyg Assoc J 22:417–421.14483199
Painter RB, Howard R. 1982. The HeLa DNA-synthesis inhibition test as a rapid screen for mutagenic carcinogens. Mutat Res 92:427–437.7088012
*Pandya KP, Rao GS, Khan S, . 1990. Accumulation of low molecular weight (bleomycin detectable) iron in bone marrow cells of rats after benzene exposure. Arch Toxicol 64(4):339–342.1696804
Parke DV. 1989. Introduction: Session on metabolism. Environ Health Perspect 82:7–8.
*Parke DV, Williams RT. 1953b. Studies in detoxication 54. The metabolism of benzene. (a) The formation of phenylglucuronide and phenylsulphuric acid from [^14^C] benzene (b) the metabolism of [^14^C_1_]phenol. Biochem J 54:337–340.13058881
Parke DV, Williams RT. 1953a. Studies in detoxication 49. The metabolism of benzene containing [^14^C1] benzene. Biochem J 54:231–238.13058864
Pate CT, Atkinson R, Pitts JN Jr. 1976. The gas phase reaction of O_3_ with a series of aromatic hydrocarbons. J Environ Sci Health A II:1–10.
Paterson S, Mackay D. 1989. Correlation of tissue, blood and air partition coefficients of volatile organic chemicals. Brit J Ind Med 46:321–314.2751930
Pathak DN, Levay G, Bodell WJ. 1995. DNA adduct formation in the bone marrow of B6C3F_1_ mice treated with benzene. Carcinogenesis 16(8):1803–1808.7634407
Paustenbach DJ, Price PS, Ollison W, . 1992. Reevaluation of benzene exposure for the pliofilm (rubberworker) cohort (1936-1976). J Toxicol Environ Health 36(3):177–231.1629933
Pawar SS, Mungikar AM. 1975. Changes in the activities of hepatic drug metabolizing enzymes and lipid peroxidation caused by benzene and toluene. Indian J Biochem Biophys 12:133–134.1218876
Paxton MB, Chinchilli VM, Brett SM, . 1994a. Leukemia risk associated with benzene exposure in the pliofilm cohort: I. mortality update and exposure distribution. Risk Analysis 14(2):147–154.8008923
Paxton MB, Chinchilli VM, Brett SM, . 1994b. Leukemia risk associated with benzene exposure in the pliofilm cohort. II. Risk estimates. Risk Anal 14(2):155–161.8008924
Pekari K, Riekkola M-L, Aitio A. 1989. Simultaneous determination of benzene and toluene in blood using head-space gas chromatography. J Chromatogr 491:309–320.2808617
Pekari K, Vainiotalo S, Heikkila P, . 1992. Biological monitoring of occupational exposure to low levels of benzene. Scand J Work Environ Health 18(5):317–322.1439659
Pellack-Walker P, Blumer JL. 1986. DNA damage in L5178YS cells following exposure to benzene metabolites. Mol Pharmacol 30:42–47.3724744
Pellizzari ED, Lioy P, Quackenboss J, . 1995. Population-based exposure measurements in EPA region 5: A phase I field study in support of the national human exposure assessment survey. J Expos Anal Environ Epidemiol 15(3):327–358.
Pellizzari ED. 1982. Analysis for organic vapor emissions near industrial and chemical waste disposal sites. Environ Sci Technol 16:781–785.22299786
Pellizzari ED, Zweidinger RA, Sheldon LS. 1988. Method 5-Determination of benzene, toluene and xylene in breath samples by gas chromatography/mass spectrometry. IARC Sci Publ 85:267–279.
Pendleton DR. 1995. Environmental health issues. Environ Health Perspect Suppl 103(supp 6):223–228.
Perbellini L, Faccini GB, Pasini F, . 1988. Environmental and occupational exposure to benzene by analysis of breath and blood. Br J Ind Med 45:345–352.3378016
Pereira WE, Hughes BA. 1980. Determination of selected volatile organic priority pollutants in water by computerized gas chromatography-quadrupole mass spectrometry. J Am Water Works Assoc 72:220–230.
Pezzagno G, Maestri L, Fiorentino ML. 1999. Trans,trans-muconic acid, a biological indicator to low levels of environmental benzene: Some aspects of its specificity. Am J Ind Med 35(5):511–518.10212704
Philip P, Jensen MK. 1970. Benzene induced chromosome abnormalities in rat bone marrow cells. Acta Pathol Microbiol Scand Sect A 78:489–490.5476626
Picciano D. 1979. Cytogenetic study of workers exposed to benzene. Environ Res 19:33–38.510268
Pitarque M, Carbonell E, Lape-na N, . 1996. No increase in micronuclei frequency in cultured blood lymphocytes from a group of filling station attendents. Mutat Res 367(3):161–167.8600372
Pitarque M, Carbonell E, Lape-na E, . 1997. SCE analysis in peripheral blood lymphocytes of a group of filling station attendants. Mutat Res 390(1–2):153–159.9150763
Plappert U, Barthel E, Raddatz K, . 1994a. Early effects of benzene exposure in mice. Haematological versus genotoxic effects. Arch Toxicol 68:284–290.8085938
Plappert U, Barthel E, Seidel HJ, . 1994b. Reduction of benzene toxicity by toluene. Environ Mol Mutagen 24:283–292.7851340
Plumb RH Jr. 1987. A comparison of groundwater monitoring data from CERCLA and RCRA sites. Ground Water Monit Rev 7:94–100.
Poole SK, Furton KG, Poole CF. 1988. Determination of benzene and toluene in gasoline by gas chromatography using a liquid organic salt column. J Chromatogr Sci 26:67–73.
Popp W, Rauscher D, Muller G, . 1994. Concentrations of benzene in blood and S-phenylmercapturic and t,t-muconic acid in urine in car mechanics. Int Arch Occup Environ Health 66(1):1–6.7523309
Popp W, Vahrenholz C, Yaman S, . 1992. Investigations of the frequency of DNA strand breakage and cross-linking and of sister chromatid exchange frequency in the lymphocytes of female workers exposed to benzene and toluene. Carcinogenesis 13(1):57–61.1733574
Post GB, Snyder R, Kalf GF. 1985. Inhibition of RNA synthesis and interleukin-2 production in lymphocytes in vitro by benzene and its metabolites, hydroquinone and p-benzoquinone. Toxicol Lett 29:161–167.2418539
Poulin P, Krishnan K. 1995. A biologically-based algorithm for predicting human tissue:blood partition coefficients of orgasnic chemicals. Hum Exp Toxicol 14:273–280.7779458
Powley MW, Carlson GP. 1999. Species comparison of hepatic and pulmonary metabolism of benzene. Toxicology 139:207–217.10647921
Powley MW, Carlson GP. 2000. Cytochromes P450 involved with benzene metabolism in hepatic and pulmonary microsomes. J Biochem Mol Toxicol 14(6):303–309.11083083
Powley MW, Carlson GP. 2001. Hepatic and pulmonary microsomal benzene metabolism in CYP2E1 knockout mice. Toxicology 169(3):187–194.11718959
Powley MW, Carlson GP. 2002. Benzene metabolism by the isolated perfused lung. Inhal Toxicol 14(6):569–584.12119069
Probst GS, Hill LE. 1985. Tests for the induction of DNA-repair synthesis in primary cultures of adult rat hepatocytes. Prog Mutat Res 5:381–386.
Purcell KJ, Cason GH, Gargas ML, . 1990. In vivo metabolic interactions of benzene and toluene. Toxicol Lett 52(2):141–152.2377998
Qu Q, Shore R, Li G, . 2002. Hematological changes among Chinese workers with a broad range of benzene exposures. Am J Ind Med 42(4):275–285.12271475
Qu Q, Shore R, Li G, . 2003a. Validation and evaluation of biomarkers in workers exposed to benzene in China. Boston, MA: Health Effects Institute, 1–84. Research number 115.
Qu Q, Shore R, Li G, . 2003b. Appendix A: Analyses of the combined data for year 1 and year 2. Validation and evaluation of biomarkers in workers exposed to benzene in China. Boston, MA: Health Effects Institute, 1–54. Research number 115. http://pubs.healtheffects.org/getfile.php?u=34. January 18, 2007.
Qu Q, Shore R, Li G, . 2005. Biomarkers of benzene: Urinary metabolites in relation to individual genotype and personal exposure. Chem Biol Interact 153–154:85–95.
Raabe GK, Wong O. 1996. Leukemia mortality by cell type in petroleum workers with potential exposure to benzene. Environ Health Perspect 104(Suppl 6):1381–1392.9118924
Rajganesh B, Selvaraj PT, Manning FS, . 1995. Biotreatment of produced water for removal of sulfides, organics, and toxicity. Appl Biochem Biotech 51/52:735–746.
Ranaldi R, Bassani B, Villani P, . 1998. Measurement and characterization of micronuclei in cultured primary lung cells of mice following inhalation exposure to benzene. Mutagenesis 13(5):453–460.9800190
Rao GS. 1996. Glutathionyl hydroquinone: A potent pro-oxidant and a possible toxic metabolite of benzene. Toxicology 106:49–54.8571401
Rao RR, Snyder R. 1995. Oxidative modifications produced in HL-60 cells on exposure to benzene metabolites. J Appl Toxicol 15(5):403–409.8666725
Rappaport SM, Kupper LL. 2004. Variability of environmental exposures to volatile organic compounds. J Expo Anal Environ Epidemiol 14(1):92–107.14726948
Rappaport SM, McDonald TA, Yeowell-O-Connell K. 1996. The use of protein adducts to investigate the disposition of reactive metabolites of benzene. Environ Health Perspect 104:1235–1237.9118898
Rappaport SM, Waidyanatha S, Qu Q, . 2002a. Albumin adducts of benzene oxide and 1,4-benzoquinone as measures of human benzene metabolism. Cancer Res 62(5):1330–1337.11888901
Rappaport SM, Yeowell-O’Connor K, Smith MT, . 2002b. Non-linear production of benzene oxide–albumin adducts with human exposure to benzene. J Chromatogr B Analyt Technol Biomed Life Sci 778(1–2):367–374.
Rauscher D, Lehnert G, Angerer J. 1994. Biomonitoring of occupational and environmental exposures to benzene by measuring trans,trans-muconic acid in urine. Clin Chem 40:1468–1470.
Reddy MV, Blackburn GR, Irwin SE, . 1989. A method for in vitro culture of rat Zymbal gland: Use in mechanistic studies of benzene carcinogenesis in combination with ^32^P-postlabeling. Environ Health Perspect 82:239–247.2507309
Reineke FJ, Bachmann K. 1985. Gas chromatographic determination of C_2_-C_8_ hydrocarbons and halocarbons in ambient air by simultaneous use of three detectors. J Chromatogr 323:323–329.
Reisch MS. 1994. Top 50 chemicals production rose modestly last year. Chem Eng News (April 11):12–15.
Renz JF, Kalf GF. 1991. Role for interleukin-1 (IL-1) in benzene-induced hematotoxicity: Inhibition of conversion of pre-IL-1 alpha to mature cytokine in murine macrophages by hydroquinone and prevention of benzene-induced hematotoxicity in mice by IL-1 alpha. Blood 78(4):938–944.1868253
Rickert DE, Baker TS, Bus JS, . 1979. Benzene disposition in the rat after exposure by inhalation. Toxicol Appl Pharmacol 49:417–423.473208
Rinsky RA, Hornung RW, Silver SR, . 2002. Benzene exposure and hematopoietic mortality: A long-term epidemiologic risk assessment. Am J Ind Med 42(6):474–480.12439870
Rinsky RA, Smith AB, Hornung R, . 1987. Benzene and leukemia: An epidemiological risk assessment. N Eng J Med 316:1044–1050.
Rinsky RA, Young RJ, Smith AB. 1981. Leukemia in benzene workers. Am J Ind Med 2:217–245.7345926
Rithidech K, Au WW, Ramanujam VMS, . 1987. Induction of chromosome aberrations in lymphocytes of mice after subchronic exposure to benzene. Mutat Res 188:135–140.3587261
Rithidech K, Au WW, Ramanujam VMS, . 1988. Persistence of micronuclei in peripheral blood normochromatic erythrocytes of subchronically benzene-treated male mice. Environ Mol Mutagen 12:319–329.3169010
Rivedal E, Witz G. 2005. Benzene metabolites block gap junction intercellular communication. Role in hematotoxicity and leukemia? Chem Biol Interact 153–154:257–260.
Roberts JM, Fehsenfeld FC, Liu SC, . 1984. Measurements of aromatic hydrocarbon ratios and NO_x_ concentrations in the rural troposphere: Observation of air mass photochemical aging and NO_x_ removal. Atmos Environ 18:2421–2432.
Roberts JM, Hutte RS, Fehsenfeld FC, . 1985. Measurements of anthropogenic hydrocarbon concentration ratios in the rural troposphere: Discrimination between background and urban sources. Atmos Environ 19:1945–1950.
Robertson ML, Eastmond DA, Smith MT. 1991. Two benzene metabolites, catechol and hydroquinone, produce a synergistic induction of micronuclei and toxicity in cultured human lymphocytes. Mutat Res 249(1):201–210.2067533
Robinson SN, Shah R, Wong BA, . 1997. Immunotoxicological effects of benzene inhalation in male Sprague-Dawley rats. Toxicology 119(3):227–237.9152018
Rosenthal GJ, Snyder CA. 1985. Modulation of the immune response to Listeria monocytogenes by benzene inhalation. Toxicol Appl Pharmacol 80:502–510.2863880
Rosenthal GJ, Snyder CA. 1987. Inhaled benzene reduces aspects of cell-mediated tumor surveillance in mice. Toxicol Appl Pharmacol 88:35–43.2951897
Ross D. 1996. Metabolic basis of benzene toxicity. Eur J Haematol Suppl 60:111–118.8987252
Ross D. 2000. The role of metabolism and specific metabolites in benzene-induced toxicity: Evidence and issues. J Toxicol Environ Health A 61(5–6):357–372.11086940
Ross D. 2005. Functions and distribution of NQO1 in human bone marrow: Potential clues to enzene toxicity. Chem Biol Interact 153–154:137–146.
Rothman N, Bechtold WE, Yin SN, . 1998. Urinary excretion of phenol, catechol, hydroquinone, and muconic acid by workers occupationally exposed to benzene. Occup Environ Med 55(10):705–711.9930093
Rothman N, Haas R, Hayes RB, . 1995. Benzene induces gene-duplicating but not gene-inactivating mutations at the glycophorin A locus in exposed humans. Proc Natl Acad Sci 92:4069–4073.7732033
Rothman N, Li Gl, Dosemeci M, . 1996a. Hematotoxicity among Chinese workers heavily exposed to benzene. Am J Med 29(3):236–246.
Rothman N, Smith MT, Hayes RB, . 1996b. An epidemiological study of early biologic effects in Chinese workers. Environ Health Perspect 104(Suppl 6):1365–1370.9118921
Rothman N, Smith MT, Hayes RB, . 1997. Benzene poisioning, a risk factor for hematological malignancy, is associated with the NQ01 609C-T mutation and rapid fractional excretion of chlozoxazone. Cancer Res 57(14):2839–2842.9230185
Roush GJ, Ott MG. 1977. A study of benzene exposure versus urinary phenol levels. Am Ind Hyg Assoc J 38:67–75.848428
Rozen MG, Snyder CA. 1985. Protracted exposure of C57BL/6 mice to 300 ppm benzene depresses B- and T-lymphocyte numbers and mitogen responses. Evidence for thymic and bone marrow proliferation in response to the exposures. Toxicology 37:13–26.3877353
Rozen MG, Snyder CA, Albert RE. 1984. Depression in B- and T-lymphocyte mitogen-induced blastogenesis in mice exposed to low concentrations of benzene. Toxicol Lett 20:343–349.6608167
Ruiz MA, Augusto LGS, Vassallo J, . 1994. Bone marrow morphology in patients with neutropenia due to chronic exposure to organic solvents (benzene): Early lesions. Path Res Pract 190:151–154.8058569
*Ruiz MA, Vassallo J, De Souza CA. 1991. Morphologic study of the bone marrow of neutropenic patients exposed to benzene of the metallurgical industry of Cubatao, Sao Paulo, Brazil [letter]. J Occup Med 33(1):83.
Ruppert T, Scherer G, Tricker AR, . 1995. Determination of urinary trans,trans-muconic acid by gas chromatography-mass spectrometry. J Chromatogr B 666:71–76.
Ruppert T, Scherer G, Tricker AR, . 1997. trans trans-Muconic acid as a biomarker of non-occupational environmental exposure to benzene. Int Arch Occup Environ Health 69(4):247–251.9137998
Rushmore T, Snyder R, Kalf G. 1984. Covalent binding of benzene and its metabolites to DNA in rabbit bone marrow mitochondria in vitro. Chem Biol Interact 49:133–154.6202430
Rushton L, Romaniuk H. 1997. A case-control study to investigate the risk of leukaemia associated with exposure to benzene in petroleum marketing and distribution workers in the United Kingdom. Occup Environ Med 54(3):152–166.9155776
Sabourin PJ, Bechtold WE, Birnbaum LS, . 1988. Differences in the metabolism and disposition of inhaled [^3^H]benzene by F344/N rats and B6C3F_1_ mice. Toxicol Appl Pharmacol 94:128–140.3376110
Sabourin PJ, Bechtold WE, Griffith WC, . 1989a. Effect of exposure concentration, exposure rate, and route of administration on metabolism of benzene by F344 rats and B6C3F_1_ mice. Toxicol Appl Pharmacol 99:421–444.2749731
Sabourin PJ, Chen BT, Lucier G, . 1987. Effect of dose on the absorption and excretion of [^14^C]benzene administered orally or by inhalation in rats and mice. Toxicol Appl Pharmacol 87:325–336.3824388
Sabourin PJ, Muggenburg BA, Couch RC, . 1992. Metabolism of [^14^C]benzene by cynomolgus monkeys and chimpanzees. Toxicol Appl Pharmacol 114(2):277–284.1609420
Sabourin PJ, Sun JD, Birnbaum LS, . 1989b. Effect of repeated benzene inhalation exposures on subsequent metabolism of benzene. Exp Pathol 37:155–157.2637147
Sabourin PJ, Sun JD, MacGregor JT, . 1990. Effect of repeated benzene inhalation exposures on benzene metabolism, binding to hemoglobin, and induction of micronuclei. Toxicol Appl Pharmacol 103:452–462.2339418
Saito FU, Kocsis JJ, Snyder R. 1973. Effect of benzene on hepatic drug metabolism and ultrastructure. Toxicol Appl Pharmacol 26:209–217.4751099
Salanitro JP. 1993. The role of bioattenuation in the management of aromatic hydrocarbon plumes in aquifers. Ground Water Monit Remed 13:150–161.
Sammett D, Lee EW, Kocsis JJ, . 1979. Partial hepatectomy reduces both the metabolism and toxicity of benzene. J Toxicol Environ Health 5:785–792.513147
Sandmeyer EE. 1981. Aromatic hydrocarbons. In: Clayton GD, Clayton FE, eds. Patty’s industrial hygiene and toxicology. Vol. 2B. 3rd rev. ed. New York, NY: John Wiley & Sons, 3253–3283.
Sanguinetti G, Accorsi A, Barbieri A, . 2001. Failure of urinary trans trans-muconic acid as a biomarker for indoor environmental benzene exposure at PPB levels. J Toxicol Environ Health A 63(8):599–604.11549119
*Santesson CG. 1897. Chronic poisoning with benzene. Arch Hyg 31:336.
Sardas S, Karakaya AE, Furtun Y. 1994. Sister chromatid exchanges in workers employed in car painting workshops. Int Arch Occup Environ Health 66:33–35.7927840
Sasiadek M. 1992. Nonrandom distribution of breakpoints in the karyotypes of workers occupationally exposed to benzene. Environ Health Perspect 97:255–257.1396464
Sasiadek M, Jagielski J. 1990. Genotoxic effects observed in workers occupationally exposed to organic solvents. Pol J Occup Med 3(1):103–108.2132930
Sasiadek M, Jagielski J, Smolik R. 1989. Localization of breakpoints in the karyotype of workers professionally exposed to benzene. Mutat Res 224:235–240.2797038
Sato A, Nakajima T. 1979. Dose-dependent metabolic integration between benzene and toluene in vivo and in vitro. Toxicol Appl Pharmacol 48:249–256.473174
Sato A, Nakajima T, Fujiwara Y, . 1975. Kinetic studies on sex differences in susceptibility to chronic benzene intoxication - with special reference to body fat content. Br J Ind Med 32:321–328.1103957
Sauer TC Jr. 1981. Volatile organic compounds in open ocean and coastal surface waters. Org Geochem 3:91–101.
Sawahata T, Neal RA. 1983. Biotransformation of phenol to hydroquinone and catechol by rat liver microsomes. Mol Pharmacol 23:453–460.6835203
Saxton J, Narkus-Kramer M. 1975. EPA findings of solid waste from industrial chemicals. Chem Eng 82:107–112.
Schad H, Schafer F, Weber L, . 1992. Determination of benzene metabolites in urine of mice by solid-phase extraction and high-performance liquid chromatography. J Chromatog 593:147–151.1639898
Schafer F, Schad H, Weber L. 1993. Determination of phenylmercapturic acid in urine of benzene-exposed BDF-1 mice. J Chromatog 620:239–242.8300792
Scherer G, Ruppert T, Daube H, . 1995. Contribution of tobacco smoke to environmental benzene exposure in Germany. Environ Int 21(6):779–789.
Scheunert I, Topp E, Schmitzer J, . 1985. Formation and fate of bound residues on [^14^C]benzene and [^14^C]chlorobenzenes in soil and plants. Ecotox Environ Safety 9:159–170.
Schiestl RH, Aubrecht J, Khogali F. 1997. Carcinogens induce reversion of the mouse pink-eyed unstable mutation. Proc Natl Acad Sci USA 94(9):4576–4581.9114032
Schlosser PM, Bond JA, Medinsky MA. 1993. Benzene and phenol metabolism by mouse and rat liver microsomes. Carcinogenesis 14:2477–2486.8269615
Schnatter AR, Armstrong TW, Nicolich MJ, . 1996b. Lymphohaematopoietic malignancies and quantitative estimates of exposure to benzene in Canadian petroleum distribution workers. Occup Environ Med 53(11):773–781.9038803
Schnatter AR, Armstrong TW, Thompson LS, . 1996c. The relationship between the low-level benzene exposure and leukemia in Canadian petroleum distribution workers. Environ Health Perspect Suppl 104:1375–1379.9118923
Schnatter AR, Katz AM, Nicolich MJ, . 1993. A retrospective mortality study among Canadian petroleum marketing and distribution workers. Environ Health Perspect Suppl 101(Suppl 6):85–99.8020452
Schnatter AR, Nicolich MJ, Bird MG. 1996a. Determination of leukemogenic benzene exposure concentrations: Refined analyses of the Pliofilm cohort. Risk Anal 16(6):833–840.8972111
Schnatter AR, Rosamilia K, Wojcik NC. 2005. Review of the literature on benzene exposure and leukemia subtypes. Chem Biol Interact 153–154:9–21.
Schnier GG, Laethem CL, Koop DR. 1989. Identification and induction of cytochromes P450, P450IIE1 and P450IA1 in rabbit bone marrow. J Pharmacol Exp Ther 251:790–796.2509684
Schreiber JS. 1993. Predicted infant exposure to tetrachloroethylene in human breastmilk. Risk Analysis 13:515–424.8259441
Schrenk D, Bock KW. 1990. Metabolism of benzene in rat hepatocytes. Influence of inducers on phenol glucuronidation. Drug Metab Dispos 18(5):720–725.1981726
Schrenk D, Ingelman-Sundberg M, Bock KW. 1992. Influence of P-4502E1 induction on benzene metabolism in rat hepatocytes and on biliary metabolite excretion. Drug Metab Dispos 20(2):137–141.1352201
Schrenk HH, Yant WP, Pearce SJ, . 1941. Absorption, distribution and elimination of benzene by body tissues and fluids of dogs exposed to benzene vapor. J Ind Hyg Toxicol 23:20–34.
Schuberth J. 1994. Joint use of retention index and mass spectrum in post-mortem test for volatile organics by headspace capillary gas chromatography with ion-trap detection. J Chromatogr A 674:63–71.
Schultz B, Kjeldsen P. 1986. Screening of organic matter in leachates from sanitary landfills using gas chromatography combined with mass spectrometry. Water Res 20:965–970.
Schwartz CS, Snyder R, Kalf GF. 1985. The inhibition of mitochondrial DNA replication in vitro by the metabolites of benzene, hydroquinone and p-benzoquinone. Chem Biol Interact 53(3):327–350.4006011
Seaton MJ, Schlosser PM, Bond JA, . 1994. Benzene metabolism by human liver microsomes in relation to cytochrome P450 2E1 activity. Carcinogenesis 15:1799–1806.7923572
Seaton MJ, Schlosser PM, Medinsky MA. 1995. In vitro conjugation of benzene metabolites by human liver: Potential influence of interindividual variability on benzene toxicity. Carcinogenesis 16:1519–1527.7614685
Seidel HJ, Bader R, Weber L, . 1990. The influence of ethanol on the stem cell toxicity of benzene in mice. Toxicol Appl Pharmacol 105(1):13–18.2392801
Seidel HJ, Beyvers G, Pape M, . 1989. The influence of benzene on the erythroid cell system in mice. Exp Hematol 17:760–764.2753084
Seidenberg JM, Anderson DG, Becker RA. 1986. Validation of an in vivo developmental toxicity screen in the mouse. Teratog Carcinog Mutagen 6:361–374.2878502
Seiji K, Jin C, Watanabe T, . 1990. Sister chromatid exchanges in peripheral lymphocytes of workers exposed to benzene, trichloroethylene, or tetrachloroethylene, with reference to smoking habits. Int Arch Occup Environ Health 62:171–176.2323835
Seixas GM, Andon BM, Hollingshead PG, . 1982. The aza-arenes as mutagens for Salmonella typhimurium. Mutat Res 102:201–212.6755231
Selling L. 1916. Benzol as leucotoxin--Studies on the degeneration and regeneration of the blood hematopoietic organs. Johns Hopkins Hosp Rep 17:83–142.
Sellyei M, Kelemen E. 1971. Chromosome study in a case of granulocytic leukemia with “pelgerisation” 7 years after benzene pancytopenia. Eur J Cancer 7:83–85.
*Serraino D, Franceschi S, LeVecchio C, . 1992. Occupation and soft-tissue sarcoma in northeastern Italy. Cancer Causes Controls 3:25–30.
Setchell BP, Waites GMH. 1975. The blood-testis barrier. In: Creep RO, Astwood EB, Geiger SR, eds. Handbook of physiology: Endocrinology V. Washington, DC: American Physiological Society.
Shah JJ, Singh HB. 1988. Distribution of volatile organic chemicals in outdoor and indoor air. Environ Sci Technol 22:1381–1388.22200458
Shamy MY, El Gazzar RME, El Sayed MA, . 1994. Study of some biochemical changes among workers occupationally exposed to phenol, alone or in combination with other organic solvents. Ind Health 32:207–214.7591850
Shankar U, Kumar A, Rao GS, . 1993. Modulation of benzene induced toxicity by protein A. Biochem Pharmacol 46(3):517–524.8347175
Sharma RK, Jacobsen-Kram D, Lemmon M, . 1985. Sister-chromatid exchange and cell replication kinetics in fetal and maternal cells after treatment with chemical teratogens. Mutat Res 158:217–231.4079953
Shaw G, Lavey R, Jackson R, . 1984. Association of childhood leukemia with maternal age, birth order, and paternal occupation. A case-control study. Am J Epidemiol 119(5):788–795.6720675
Sheets PL, Carlson GP. 2004. Kinetic factors involved in the metabolism of benzene in mouse lung and liver. J Toxicol Environ Health A 67(5):421–430.14718178
Sheets PL, Yost GS, Carlson GP. 2004. Benzene metabolism in human lung cell lines BEAS-2B and A549 and cells overexpressing CYP2F1. J Biochem Mol Toxicol 18(2):92–99.15122651
Shelby MD, Witt KL. 1995. Comparison of results from mouse bone marrow chromosome aberration and micronucleus test. Environ Mol Mutagen 25:302–313.7607185
Shelby MD, Erexson GL, Hook GJ, . 1993. Evaluation of a three-exposure mouse bone marrow micronucleus protocol: Results with 49 chemicals. Environ Mol Mutagen 21(2):160–179.8444144
Shell. 1980. A dominant-lethal inhalation study with benzene in rats. Shell Oil Co. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0539136.
Shell. 1992. Immunosuppression of B6C3F_1_ female mice following subchronic exposure to benzene from drinking water. Submitted to the U.S Environmental Protection Agency under TSCA Section 8E. OTS0536214.
Sherwood RJ. 1972. Benzene: The interpretation of monitoring results. Ann Occup Hyg 15:409–421.4648250
Sherwood RJ. 1988. Pharmacokinetics of benzene in a human after exposure at about the permissible limit. Ann NY Acad Sci 534:635–647.3389682
Sherwood RJ, Carter FWG. 1970. The measurement of occupational exposure to benzene vapour. Ann Occup Hyg 13:125–146.5431895
Shu XO, Gao YT, Brinton LA, . 1988. A population based case-control study of childhood leukemia in Shanghai. Cancer 62:635–644.3164642
Sidhu KS, Chadzynski L. 1994. Risk communication: Health risks associated with environmentally contaminated private wells versus chloroform in a public water supply. J Environ Health 56(10):13–16.
Sinclair GC, Gray CN, Sherwood RJ. 1999. Structure and validation of a pharmacokinetic model for benzene. Am Ind Hyg Assoc J 60(2):249–258.10222576
Singh GB, Salas LJ, Cantrell BK, . 1985. Distribution of aromatic hydrocarbons in ambient air. Atmos Environ 19:1911–1919.
Siou G, Conan L, el Haitem M. 1981. Evaluation of the clastogenic action of benzene by oral administration with 2 cytogenetic techniques in mouse and Chinese hamster. Mutat Res 90:273–278.7329437
Skowronski GA, Turkall RM, Abdel-Rahman MS. 1988. Soil adsorption alters bioavailability of benzene in dermally exposed male rats. Am Ind Hyg Assoc J 49:506–511.3189159
Smith MT. 1996a. Overview of benzene-induced aplastic anaemia. Eur J Haematol Suppl 60:107–110.8987251
Smith MT. 1996b. The mechanism of benzene-induced leukemia: A hypothesis and speculations on the causes of leukemia. Environ Health Perspect 104:1219–1225.9118896
Smith MT, Rothman N. 2000. Biomarkers in the molecular epidemiology of benzene-exposed workers. J Toxicol Environ Health A 61(5–6):439–445.11086950
Smith MT, Zhang L. 1998. Biomarkers of leukemia risk: Benzene as a model. Environ Health Perspect Suppl 106:937–946.9703476
Smith MT, Zhang L, Jeng M, . 2000. Hydroquinone, a benzene metabolite, increases the level of aneusomy of chromosomes 7 and 8 in human CD34-positive blood progenitor cells. Carcinogenesis 21(8):1485–1490.10910948
Smith MT, Zhang L, Wang Y, . 1998. Increased translocations and aneusomy in chromosomes 8 and 21 among workers exposed to benzene. Cancer Res 58(10):2176–2181.9605763
Smyth HF, Carpenter CP, Weil CS, . 1962. Range-finding toxicity data: List VI. Am Ind Hyg Assoc J 23:95–107.13914538
Snyder R. 2000a. Overview of the toxicology of benzene. J Toxicol Environ Health A 61(5–6):339–346.11086937
Snyder R. 2000b. Recent developments in the understanding of benzene toxicity and leukemogenesis. Drug Chem Toxicol 23(1):13–25.10711386
Snyder R. 2002. Benzene and leukemia. Crit Rev Toxicol 32(3):155–210.12071572
Snyder R, Hedli CC. 1996. An overview of benzene metabolism. Environ Health Perspect 104(Suppl 6):1165–1171.9118888
Snyder R, Kalf GF. 1994. A perspective on benzene leukemogenesis. Crit Rev Toxicol 24(3):177–209.7945890
Snyder CA, Goldstein BD, Sellakumar A. 1978a. Hematotoxicity of inhaled benzene to Sprague-Dawley rats and AKR mice at 300 ppm. J Toxicol Environ Health 4:605–618.682210
Snyder CA, Goldstein BD, Sellakumar A, . 1982. Toxicity of chronic benzene inhalation: CD-1 mice exposed to 300 ppm. Bull Environ Contam Toxicol 29:385–391.7171847
Snyder CA, Goldstein BD, Sellakumar AR. 1984. Evidence for hematotoxicity and tumorigenesis in rats exposed to 100 ppm benzene. Am J Ind Med 5:429–434.6731444
Snyder CA, Goldstein BD, Sellakumar AR, . 1980. The inhalation toxicology of benzene: Incidence of hematopoietic neoplasms and hematotoxicity in AKR/J and C57BL/6J mice. Toxicol Appl Pharmacol 54:323–331.6893503
Snyder CA, Green JD, LoBue J, . 1981. Protracted benzene exposure causes a proliferation of myeloblasts and/or promyelocytes in CD-1 mice. Bull Environ Contam Toxicol 27:17–22.7296032
Snyder CA, Sellakumar AR, James DJ, . 1988. The carcinogenicity of discontinuous inhaled benzene exposures in CD-1 and C57BL/6 mice. Arch Toxicol 62:331–335.3242441
Snyder R, Chepiga T, Yang CS, . 1993a. Benzene metabolism by reconstituted cytochromes P450, 2B1, and 2E1 and its modulation by cytochrome b5, microsomal epoxide hydrolase, and glutathione transferases: Evidence for an important role of microsomal epoxide hydrolase in the formation of hydroquinone. Toxicol Appl Pharmacol 122(2):172–181.8211999
Snyder R, Dimitriadis E, Guy R, . 1989. Studies on the mechanism of benzene toxicity. Environ Health Perspect 82:31–35.2792049
Snyder R, Jowa L, Witz G, . 1987. Formation of reactive metabolites from benzene. Arch Toxicol 60:61–64.3619644
Snyder R, Lee EW, Kocsis JJ. 1978b. Binding of labeled metabolites to mouse liver and bone marrow. Res Commun Chem Pathol Pharmacol 20:191–194.663402
Snyder R, Witz G, Goldstein BD. 1993b. The toxicology of benzene. Environ Health Perspect 100:293–306.8354177
*Sole F, Caballin MR, Coll MD, . 1990. Acute lymphoblastic leukemia with t(4;11) in a patient previously exposed to a carcinogen. Cancer Genet Cytogenet 49(1):133–136.2397467
Songnian Y, Quilan L, Yuxiang L. 1982. Significance of leukocyte alkaline phosphates in the diagnosis of chronic benzene poisioning. Regul Toxicol Pharmacol 2:209–212.7186168
Sonoda T, Nagata Y, Mori M, . 2001. Meta-analysis of multiple myeloma and benzene exposure. J Epidemiol 11(6):249–254.11769942
Sporstol S, Urdal K, Drangsholt H, . 1985. Description of a method for automated determination of organic pollutants in water. Int J Environ Anal Chem 21:129–138.
Srbova J, Teisinger J, Skramovsky S. 1950. Absorption and elimination of inhaled benzene in man. Arch Ind Hyg Occup Med 2:1–8.15433511
SRI. 1995. 1995 Directory of chemical producers. United States of America. Menlo Park, CA: Stanford Research Institute International, 466.
SRI. 2004. Benzene. 2004 Directory of chemical producers: United States. Menlo Park, CA: SRI Consulting, 460–461.
St-Germain F, Mamer O, Brunet J, . 1995. Volatile organic compound analysis by an inertial spray extraction interface coupled to an ion trap mass spectrometer. Anal Chem 67:4536–4541.
Staples CA, Werner AF, Hoogheem TJ. 1985. Assessment of priority pollutant concentrations in the United States using STORET database. Environ Toxicol Chem 4:131–142.
*Steineck G, Plato N, Gerhardsson M, . 1990. Increased risk of urothelial cancer in Stockholm during 1985-87 after exposure to benzene and exhausts. Int J Cancer 45:1012–1017.1693598
Stetter JR, Jurs PC, Rose SL. 1986. Detection of hazardous gases and vapors: Pattern recognition analysis of data from an electrochemical sensor array. Anal Chem 58:860–866.
Stillman WS, Varella-Garcia M, Gruntmeir JJ, . 1997. The benzene metabolite, hydroquinone, induces dose-dependent hypoploidy in a human cell line. Leukemia 11(9):1540–1545.9305610
Stoner RD, Drew RT, Bernstein DM. 1981. Benzene-inhalation effects upon tetanus antitoxin responses and leukemogenesis in mice. In: Mahlum DD, Gray RH, Felix WD, eds. Coal conversion and the environment. Oak Ridge, TN: U.S. Department of Energy, Technical Information Center, 445–461.
Strange RC, Fryer AA. 1999. The glutathione S-transferases: Influence of polymorphism on cancer susceptibility. IARC Sci Pub 148:231–249.
Stucker I, Mandereau L, Aubert-Berleur MP, . 1994. Occupational paternal exposure to benzene and risk of spontaneous abortion. Occup Environ Med 51:475–478.8044247
Stutz DR, Janusz SJ. 1988. Hazardous materials injuries: A handbook for pre-hospital care. Beltsville, MD: Bradford Communications Corporation, 298–299.
Styles JA, Richardson CR. 1984. Cytogenetic effects of benzene: Dosimetric studies on rats exposed to benzene vapour. Mutat Res 135:203–209.6708961
Subrahmanyam VV, Doane-Setzer P, Steinmetz KL, . 1990. Phenol-induced stimulation of hydroquinone bioactivation in mouse bone marrow in vivo: Possible implications in benzene myelotoxicity. Toxicology 62(1):107–116.2343455
Subrahmanyam VV, Sadler A, Suba E, . 1989. Stimulation of in vitro bioactivation of hydroquinone by phenol in bone marrow cells. Drug Metab Dispos 17:348–350.2568920
Sul D, Lee D, Im H, . 2002. Single strand DNA breaks in T- and B-lymphocytes and granulocytes in workers exposed to benzene. Toxicol Lett 134:87–95.12191865
*Sun. 1971. Initial Submission. Subacute inhalation study of benzene on monkeys (final report) with attachment and cover letter dated 022892. Sun Company, Inc. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0539115.
Sun JD, Medinsky MA, Birnbaum LS, . 1990. Benzene hemoglobin adducts in mice and rats: Characterization of formation and physiological modeling. Fundam Appl Toxicol 15:468–475.2258011
Surrallés J, Autio K, Nylund L, . 1997. Molecular cytogenetic analysis of buccal cells and lymphocytes from benzene-exposed workers. Carcinogenesis 18(4):817–823.9111220
Susten A, Dames B, Burg J, . 1985. Percutaneous penetration of benzene in hairless mice: An estimate of dermal absorption during tire-building operations. Am J Ind Med 7:323–335.3993649
Suzuki S, Atai H, Hatakeyama Y, . 1989. Administration-route-related differences in the micronucleus test with benzene. Mutat Res 223:407–410.2747728
Swenberg JA, Petzold GL, Harbach PR. 1976. In vitro DNA damage/alkaline elution assay for predicting carcinogenic potential. Biochem Biophys Res Commun 72:732–738.985507
Sze CC, Shi CY, Ong CN. 1996. Cytotoxicity and DNA strand breaks induced by benzene and its metabolites in Chinese hamster ovary cells. J Appl Toxicol 16(3):259–264.8818868
Tabak HH, Quave SA, Mashni CI, . 1981. Biodegradability studies with organic priority pollutant compounds. J Water Pollut Control Fed 53:1503–1518.
Taningher M, Perrotta A, Malacarne D, . 1995. Lack of significant promoting activity by benzene in the rat liver model of carcinogenesis. J Toxicol Environ Health 45:481–488.7643434
Tannoka H. 1977. Development and application of Bacillus subtilis test systems for mutagens, involving DNA-repair deficiency and suppressible auxotrophic mutations. Mutat Res 42:19–32.191747
Tatrai E, Rodics K, Ungvary G. 1980a. Embryotoxic effects of simultaneously applied exposure of benzene and toluene. Folia Morphol (Praha) 28:286–289.7409692
Tatrai E, Ungvary GY, Hudak A, . 1980b. Concentration dependence of the embryotoxic effects of benzene inhalation in CFY rats. J Hyg Epidemiol Microbiol Immunol 24:363–371.
Tauber J. 1970. Instant benzol death. J Occup Med 12:91–92.5434858
Taylor L, Morris SS. 1995. Final report on the operations and findings of the Anchorage volatile organic compounds (VOC) monitoring project. Proceedings of the 88th Annual Meeting and Exhibition, San Antonio, TX, June 1995. Pittsburgh, PA: Air and Waste Management Association, 1–15.
Teisinger J, Fišerová-Bergerová B. 1955. Valeus camparée de la détermination des sulfates et du phénol contenus dans l’urine pour l’évaluation de la concentration du benzène dans l’air. Arch Mal Prof 16:221–232.14388875
Thienes H, Haley TJ. 1972. Clinical toxicology. 5th ed. Philadelphia, PA: Lea & Febiger, 124–127.
Thomas K, Colborn T. 1992. Organochlorine endocrine disruptors in human tissue. In: Colborn T, Clement C, eds. Chemically induced alterations in sexual and functional development: The wildlife/human connection. Princeton, NJ: Princeton Scientific Publishing, 365–394.
Thomas KW, Pellizzari ED, Clayton CA, . 1993. Temporal variability of benzene exposures for residents in several New Jersey homes with attached garages or tobacco smoke. J Expo Anal Environ Epidemiol 3(1):49–73.7686062
Thomas KW, Pellizzari ED, Cooper SD. 1991. A canister-based method for collection and GC/MS analysis of volatile organic compounds in human breath. J Anal Toxicol 15:54–59.2051745
Tice RR, Costa DL, Drew RT. 1980. Cytogenetic effects of inhaled benzene in murine bone marrow: Induction of sister chromatid exchanges, chromosomal aberrations, and cellular proliferation inhibition in DBA/2 mice. Proc Natl Acad Sci USA 77:2148–2152.6929542
Tice RR, Vogt TF, Costa DL. 1982. Cytogenetic effects of inhaled benzene in murine bone marrow. Environ Sci Res 25:257–275.
Toft K, Olofsson T, Tunek A, . 1982. Toxic effects on mouse bone marrow caused by inhalation of benzene. Arch Toxicol 51:295–302.
Tompa A, Major J, Jakab MG. 1994. Monitoring of benzene-exposed workers for genotoxic effects of benzene: Improved-working-condition-related decrease in the frequencies of chromosomal aberrations in peripheral blood lymphocytes. Mutat Res 304(2):159–165.7506358
Tondel M, Persson B, Carstensen J. 1995. Myelofibrosis and benzene exposure. Occup Med 45(1):51–52.
Topham JC. 1980. Do induced sperm-head abnormalities in mice specifically identify mammalian mutagens rather than carcinogens? Mutat Res 74:379–387.7207475
Topp E, Scheunert I, Korte F. 1989. Kinetics of the uptake of ^14^C-labeled chlorinated benzene from soil by plants. Ecotox Environ Safety 17:157–166.
Tough IM, Court Brown WM. 1965. Chromosome aberrations and exposure to ambient benzene. Lancet 1:684.14258551
Tough IM, Smith PG, Brown WMC. 1970. Chromosome studies on workers exposed to atmospheric benzene. Eur J Cancer 6:49–55.
Townsend JC, Ott MG, Fishbeck WA. 1978. Health exam findings among individuals occupationally exposed to benzene. J Occup Med 20:543–548.690739
Travis CC, Bowers JC. 1989. Protein binding of benzene under ambient exposure conditions. Toxicol Ind Health 5(6):1017–1024.2626754
Travis CC, Quillen JL, Arms AD. 1990. Pharmacokinetics of benzene. Toxicol Appl Pharmacol 102:400–420.2315912
Travis LB, Li CY, Zhang ZN, . 1994. Hematopoietic malignancies and related disorders among benzene-exposed workers in China. Leuk Lymphoma 14:91–102.7920231
TRI90. 1992. Toxics Chemical Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
TRI92. 1994. Toxics Chemical Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
TRI02. 2005. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access. Office of Environmental Information. U.S. Environmental Protection Agency. Toxics Release Inventory. http://www.epa.gov/triexplorer/. April 11, 2005.
TRI04. 2006. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access. Office of Environmental Information. U.S. Environmental Protection Agency. Toxics Release Inventory. http://www.epa.gov/triexplorer/. January 29, 2007.
Tsai SP, Fox EE, Ransdell JD, . 2004. A hematology surveillance study of petrochemical workers exposed to benzene. Regul Toxicol Pharmacol 40:67–73.15265607
Tsai SP, Wen CP, Weiss NS, . 1983. Retrospective mortality and medical surveillance studies of workers in benzene areas of refineries. J Occup Med 25:685–692.6631569
Tsuruta H. 1989. Skin absorption of organic solvent vapors in nude mice in vivo. Ind Health 27:37–47.2745160
Tsutsui T, Hayashi N, Maizumi H, . 1997. Benzene-, catechol-, hydroquinone- and phenol-induced cell transformation, gene mutations, chromosome aberrations, aneuploidy, sister chromatid exchanges and unscheduled DNA synthesis in Syrian hamster embryo cells. Mutat Res 373(1):113–123.9015160
Tucker WA, Huang C, Bral JM. 1986. Validation of transport model. Benzene in Florida groundwater: An assessment of the significance to human health. Washington, DC: American Petroleum Council, Flordia Petroleum Council, 93–108.
Tuo J, Loft S, Thomsen MS, . 1996. Benzene-induced genotoxicity in mice in vivo detection by the alkaline comet assay: Reduction by CYP2E21 inhibition. Mutat Res 368(3–4):213–219.8692227
*Turk R, Fuchs R, Momcilovic B. 1991. Granulocyte reserve in chronic experimental benzene poisoning in rats. Arh Hig Rada Toksikol 42(1):37–42.1854263
Turkall RM, Skowronski G, Gerges S, . 1988. Soil absorption alters kinetics and bioavailability of benzene in orally exposed male rats. Arch Environ Contam Toxicol 17:159–164.3355231
*Türkel B, Egeli U. 1994. Analysis of chromosomal aberrations in shoe workers exposed long term to benzene. Occup Environ Med 51:50–53.8124464
Turtletaub KW, Mani C. 2003. Benzene metabolism in rodents at doses relevant to human exposure from urban air. Boston, MA: Health Effects Institute. Research Report 113.
U.S. Congress. 1986. Superfund Amendments and Reauthorization Act of 1986. 99th Congress, 2nd Session, October, 17, 1986.
Uchrin CG, Mangels G. 1987. Sorption equilibria of benzene and toluene on two New Jersey coastal plain ground water aquifer solids. J Environ Sci Health [A] 22:743–758.
Ugrekhelidze D, Korte F, Kvesitadze G. 1997. Uptake and transformation of benzene and toluene by plant leaves. Ecotoxicol Environ Saf 37:24–29.9212332
Ungvary G, Tatrai E. 1985. On the embryotoxic effects of benzene and its alkyl derivatives in mice, rats and rabbits. Arch Toxicol Suppl 8:425–430.3868373
USGS. 2005. Benzene. Group: VOC. Schedule: Volatile organic compounds. U.S. Geological Survey. http://infotrek.er.usgs.gov/docs/nawqa_www/nwq_paramx.htm. April 13, 2005.
USITC. 2005. Benzene. First unit of quantity by country name and first unit of quanity. United States International Trade Commission. http://dataweb.usitc.gov/scripts/REPORT.asp. March 03, 2005.
Utterback DF, Rinsky RA. 1995. Benzene exposure assessment in rubber hydrochloride workers: A critical evaluation of previous estimates. Am J Ind Med 27(5):661–676.7611304
Vacha J, Znojil V, Seidel HJ, . 1990. Ferrokinetics and erythropoiesis in mice after long-term inhalation of benzene. Blut 60(1):41–47.2297584
Vaishnav DD, Babeu L. 1987. Comparison of occurrence and rates of chemical biodegradation in natural waters. Bull Environ Contam Toxicol 39:237–244.3663976
Valentine JL, Lee SS, Seaton MJ, . 1996a. Reduction of benzene metabolism and toxicity in mice that lack CYP2E1 expression. Toxicol Appl Pharmacol 141(1):205–213.8917693
Valentine JL, Seaton MJ, Asgharian B. 1996b. Benzene metabolism and toxicity in transgenic CYP2E1 knockout mice. Toxicologist 30(1):73.
Van den Berghe H, Louwagie A, Broeckaert-Van Orshoven A, . 1979. Chromosome analysis in two unusual malignant blood disorders presumably induced by benzene. Blood 53:558–566.426907
Van Emon JM, Gerlach CL. 1995. A status report on field-portable immunoassay. Environ Sci Tech 29(7):312–317.
van Sittert NJ, Boogaard PJ, Beulink GD. 1993. Application of the urinary S-phenylmercapturic acid test as a biomarker for low levels of exposure to benzene in industry. Br J Ind Med 50(5):460–469.8507599
van Wijnen JH, Verhoeff AP, Jans HWA, . 1995. The exposure of cyclists, car drivers and pedestrians to traffic-related air pollutants. Int Arch Occup Environ Health 67(3):187–193.7591177
van Wijngaarden E, Stewart PA. 2003. Critical literature review of determinants and levels of occupational benzene exposure for United States community-based case-control studies. Appl Occup Environ Hyg 18(9):678–693.12909536
Vara P, Kinnunen O. 1946. Benzene toxicity as a gynecologic problem. Acta Obstet Gynecol Scand 26:433–452.
Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238:476–483.8681961
Vigliani EC, Forni A. 1976. Benzene and leukemia. Environ Res 11:122–127.767102
*Vigliani EC, Saita G. 1964. Benzene and leukemia. N Engl J Med 271(1):872–876.14185112
Vogel E, Günther H. 1967. Benzene oxide-oxepin valence tautomerism. Angew Chem Int Ed Engl 6(5):385–476.
Vogel TM, Grbić-Galić D. 1986. Incorporation of oxygen from water into toluene and benzene during anaerobic fermentative transformation. Appl Environ Microbiol 52:200–202.16347109
Von Oettingen WF. 1940. Toxicity and potential dangers of aliphatic and aromatic hydrocarbons: A critical review of the literature. Washington, DC: U.S. Public Health Service, Division of Industrial Hygiene, National Institute of Health, Public Health Bulletin No. 255, 66–97, 125–135.
Waidyanatha S, Rothman N, Fustinoni S, . 2001. Urinary benzene as a biomarker of exposure among occupationally exposed and unexposed subjects. Carcinogenesis 22(2):279–286.11181449
Wallace LA. 1989a. Major sources of benzene exposure. Environ Health Perspect 82:165–169.2477239
Wallace LA. 1989b. The exposure of the general population to benzene. Cell Biol Toxicol 5:297–314.2598086
Wallace LA. 1995. Human exposure to environmental pollutants: A decade of experience. Clin Exp Allergy 25:4–9.7728623
Wallace LA, Pellizzari ED. 1986. Personal air exposure and breath concentrations of benzene and other volatile hydrocarbons for smokers and nonsmokers. Toxicol Lett 35:113–116.
Wallace LA, Nelson WC, Ziegenfus R, . 1991. The Los Angeles team study: Personal exposures, indoor-outdoor air concentrations, and breath concentrations of 25 volatile organic compounds. J Exp Anal Environ Epidemiol 1(2):157–192.
Wallace LA, Pellizzari ED, Hartwell TD, . 1986. Total exposure assessment methodology (TEAM) study: Personal exposures, indoor-outdoor relationships, and breath levels of volatile organic compounds in New Jersey. Environ Int 12:369–387.
Wallace LA, Pellizzari ED, Hartwell TD, . 1985. Personal exposures, indoor-outdoor relationships, and breath levels of toxic air pollutants measured for 355 persons in New Jersey. Atmos Environ 19:1651–1661.
Wallace LA, Pellizzari ED, Hartwell TD, . 1987. Exposures to benzene and other volatile compounds from active and passive smoking. Arch Environ Health 42:272–279.3452294
Ward CO, Kuna RA, Snyder NK, . 1985. Subchronic inhalation toxicity of benzene in rats and mice. Am J Ind Med 7:457–473.4003405
Ward E, Hornung R, Morris J, . 1996. Risk of low red or white blood cell count related to estimated benzene exposure in a rubberworker cohort (1940-1975). Am J Ind Med 29(3):247–257.8833777
Ward JB Jr, Ammenheuser MM, Ramanujam VMS, . 1992. The mutagenic effects of low level sub-acute inhalation exposure to benzene in CD-1 mice. Mutat Res 268(1):49–57.1378186
Weaver VM, Buckley T, Groopman JD. 2000. Lack of specificity of trans,trans-muconic acid as a benzene biomarker after ingestion of sorbic acid-preserved foods. Cancer Epidemiol Biomarkers Prev 9(7):749–755.10919747
Wells MS, Nerland DE. 1991. Hematotoxicity and concentration-dependent conjugation of phenol in mice following inhalation exposure to benzene. Toxicol Lett 56(1–2):159–166.2017773
West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
Wester RC, Maibach HI, Gruenke LD, . 1986. Benzene levels in ambient air and breath of smokers and nonsmokers in urban and pristine environments. J Toxicol Environ Health 18:567–573.3735457
White MC, Johnson CA, Ashley, . 1993. Exposure to methyl tertiary-butyl ether from oxygenated gasoline in Stamford, Connecticut. Arch Environ Health 50(3):183–189.
WHO. 2000. Air quality guidelines. 2nd ed. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/air/Activities/20050104_1. February 15, 2005.
WHO. 2004. Guidelines for drinking-water quality. 3rd ed. Geneva, Switzerland: World Health Organization. http://www.who.int/water_sanitation_health/dwq/gdwq3/en/. February 15, 2005.
Widdowson EM, Dickerson JWT. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise. Volume II: The elements Part A. New York: Academic Press, 1–247.
Wiester MJ, Winsett DW, Richards JH, . 2002. Partitioning of benzene in blood: Influence of hemoglobin type in humans and animals. Environ Health Perspect 110(3):255–261.11882476
Williams JA. 2001. Single-nucleotide polymorphisms, metabolic activation and environmental carcinogenesis: Why molecular epidemiologists should think about enzyme expression. Carcinogenesis 22:209–214.11181440
Williams GM, Tong C, Ved Brat S. 1985. Tests with the rat hepatocyte primary culture/DNA-repair test. Prog Mutat Res 5:341–345.
*Wilson RH. 1942. Benzene poisoning in industry. J Lab Clin Med 27:1517–1521.
Wilson BH, Smith GB, Rees JF. 1986. Biotransformation of selected alkylbenzenes and halogenated hydrocarbons in methanogenic aquifer material: A microcosm study. Environ Sci Technol 20:997–1002.22257397
Winek CL, Collom WD. 1971. Benzene and toluene fatalities. J Occup Med 13:259–261.5103143
Winek CL, Collom WD, Wecht CH. 1967. Fatal benzene exposure by glue sniffing. Lancet (March 25):683.4163939
Winn LM. 2003. Homologous recombination initiated by benzene metabolites: A potential role of oxidative stress. Toxicol Sci 72:143–149.12604843
Witz G, Gad SC, Tice RR, . 1990a. Genetic toxicity of the benzene metabolite trans,trans-muconaldehyde in mammalian and bacterial cells. Mutat Res 240:295–306.2184354
Witz G, Kirley TA, Maniara WM, . 1990b. The metabolism of benzene to muconic acid, a potential biological marker of benzene exposure. Biol React Intermed IV 283:613–618.
Witz G, Maniara W, Mylavarapu V, . 1990c. Comparative metabolism of benzene and trans,trans-muconaldehyde to trans,trans-muconic acid in DBA/2N and C57BL/6 mice. Biochem Pharmacol 40:1275–1280.2403381
Witz G, Rao GS, Goldstein BD. 1985. Short-term toxicity of trans,trans-mucondialdehyde. Toxicol Appl Pharmacol 80:511–516.4035700
Witz G, Zhang Z, Goldstein BD. 1996. Reactive ring-opened aldehyde metabolites in benzene toxicity. Environ Health Perspect 104(Suppl 6):1195–1199.9118893
Wolf MA, Rowe VK, McCollister DD, . 1956. Toxicological studies of certain alkylated benzene and benzene. AMA Arch Ind Health 14:387–398.13361560
*Wolff SP. 1992. Correlation between car ownership and leukaemia: Is non-occupational exposure to benzene from petrol and motor vehicle exhaust a causative factor in leukaemia and lymphoma? Experientia 48(3):301–304.1372266
*Wong O. 1987. An industry wide mortality study of chemical workers occupationally exposed to benzene: II. Dose response analyses. Br J Ind Med 44:382–395.3606967
Wong O. 1995. Risk of acute myeloid leukaemia and multiple myeloma in workers exposed to benzene. Occup Environ Med 52:380–384.7627314
Wong O. 1999. A critique of the exposure assessment in the epidemiologic study of benzene-exposed workers in China conducted by the Chinese Academy of Preventive Medicine and the US National Cancer Institute. Regul Toxicol Pharmacol 30(3):259–267.10620475
Wong O, Raabe GK. 1997. Multiple myeloma and benzene exposure in a multinational cohort of more than 250,000 petroleum workers. Regul Toxicol Pharmacol 26:188–199.9356282
Wong O, Raabe GK. 2000. Non-Hodgkin’s lymphoma and exposure to benzene in a multinational cohort of more then 308,000 petroleum workers, 1937-1996. J Occup Environ Med 42(5):554–568.10824308
*Wong O, Morgan RW, Whorton MD. 1983. Comments on the NIOSH study of leukemia in benzene workers. Technical report submitted to Gulf Canada Ltd., by Environmental Health Associates, August 31.
Wood JA, Porter ML. 1987. Hazardous pollutants in Class II landfills. J Air Pollut Control Assoc 37:609–615.
Xia Z-L, Xi-Peng J, Pei-Lian L, . 1995. Ascertainment corrected prevalence rate (ACPR) of leukopenia in workers exposed to benzene in small-scale industries calculated wit capture-recapture methods. Biomed Environ Sci 8:30–34.7605597
*Xing SG, Shi X, Wu ZL, . 1992. Transplacental genotoxicity of triethylenemelamine, benzene, and vinblastine in mice. Teratog Carcinog Mutagen 12(5):223–230.1363495
Yardley-Jones A, Anderson D, Jenkinson PC, . 1988. Genotoxic effects in peripheral blood and urine of workers exposed to low level benzene. Br J Ind Med 45:694–700.3196663
Yardley-Jones A, Anderson D, Lovell DP, . 1990. Analysis of chromosomal aberrations in workers exposed to low level benzene. Br J Ind Med 47(1):48–51.2310707
Yeowell-O’Connell K, Rothman N, Smith MT, . 1998. Hemoglobin and albumin adducts of benzene oxide among workers exposed to high levels of benzene. Carcinogenesis 19(9):1565–1571.9771926
Yeowell-O’Connor K, Rothman N, Waidyanatha S, . 2001. Protein adducts of 1,4-benzoquinone and benzene oxide among smokers and nonsmokers exposed to benzene in China. Cancer Epidemiol Biomarkers Prev 10(8):831–838.11489749
Yin SN, Hayes RB, Linet MS, . 1996a. A cohort study of cancer among benzene-exposed workers in China: Overall results. Am J Med 29(3):227–235.
Yin S, Li G, Hu Y, . 1987b. Symptoms and signs of workers exposed to benzene, toluene or the combination. Ind Health 25:113–130.3679888
Yin SN, Hayes RB, Linet MS, . 1996b. An expanded cohort study of cancer among benzene-exposed workers in China. Environ Health Perspect 104(Suppl 6):1339–1341.9118917
Yin SN, Li GL, Tain FD, . 1987a. Leukemia in benzene workers: A retrospective cohort study. Br J Ind Med 44:124–128.3814544
Yin SN, Li GL, Tain FD, . 1989. A retrospective cohort study of leukemia and other cancers in benzene workers. Environ Health Perspect 82:207–213.2792042
Yin SN, Li Q, Liu Y, . 1987c. Occupational exposure to benzene in China. Br J Ind Med 44:192–195.3828244
Yin SN, Linet MS, Hayes RB, . 1994. Cohort study among workers exposed to benzene in China: I. General methods and resources. Am J Ind Med 26(3):383–400.7977412
Young RJ, Rinsky RA, Infante PF, . 1978. Benzene in consumer products. Science 199:248.
Yu R, Weisel CP. 1996. Measurement of benzene in human breath associated with an environmental exposure. J Expo Anal Environ Epidemiol 6(3):261–277.8889948
Zarani F, Papazafiri P, Kappas A. 1999. Induction of micronuclei in human lymphocytes by organic solvents in vitro. J Environ Pathol Toxicol Oncol 18(1):21–28.9951836
Zhang L, Robertson ML, Kolachana P, . 1993. Benzene metabolite, 1,2,4-benzenetriol, induces micronuclei and oxidative DNA damage in human lymphocytes and HL60 cells. Environ Mol Mutagen 21:339–348.8491213
Zhang L, Rothman N, Wang Y, . 1998a. Increased aneusomy and long arm delation of chromosomes 5 and 7 in the lymphocytes of Chinese workers exposed to benzene. Carcinogenesis 19(11):1955–1961.9855009
Zhang L, Rothman N, Wang Y, . 1999. Benzene increases aneuploidy in the lymphocytes of exposed workers: A comparison of data obtained by fluorescence in situ hybridization in interphase and metaphase cells. Environ Mol Mutagen 34(4):260–268.10618174
Zhang L, Wang Y, Shang N, . 1998b. Benzene metabolites induce the loss and long arm deletion of chromosomes 5 and 7 in human lymphocytes. Leuk Res 22(2):105–113.9593466
Zhang Z, Cooper K, Goldstein BD, . 1997. Distribution studies in CD-1 mice administered [^14^C]muconaldehyde. Arch Toxicol 71:703–708.9363844
Zhang Z, Goldstein BD, Witz G. 1995a. Iron-stimulated ring-opening of benzene in a mouse liver microsomal system. Mechanistic studies and formation of a new metabolite. Biochem Pharmacol 50(10):1607–1617.7503763
Zhang Z, Xiang Q, Glatt H, . 1995b. Studies of pathways of ring opening of benzene in a Fenton system. Free Radic Biol Med 18(3):411–419.9101231
Zhu H, Li Y, Trush MA. 1995. Differences in xenobiotic detoxifying activities between bone marrow stromal cells from mice and rats: Implications for benzene-induced hematotoxicity. J Toxicol Environ Health 46(2):183–201.7563217
Ziegler EE, Edwards BB, Jensen RL, . 1978. Absorption and retention of lead by infants. Pediatr Res 12:29–34.643372