# UPDATE STATEMENT

A Toxicological Profile for Benzene, Draft for Public Comment was released in August 2005. This edition supersedes any previously released draft or final profile.

Toxicological profiles are revised and republished as necessary. For information regarding the update status of previously released profiles, contact ATSDR at:

- Agency for Toxic Substances and Disease Registry
  Division of Toxicology and Environmental Medicine/Applied Toxicology Branch
  1600 Clifton Road NE
  Mailstop F-32
  Atlanta, Georgia 30333