# 8 REGULATIONS AND ADVISORIES

The international and national regulations and guidelines regarding benzene in air, water, and other media are summarized in Table 8-1.

ATSDR has derived an acute-duration inhalation MRL of 0.009 ppm for benzene based on a LOAEL of 10.2 ppm for immunological effects in mice exposed for 6 hours/day for 6 consecutive days (Rozen et al. 1984). The LOAEL of 10.2 ppm was adjusted from intermittent to continuous exposure (LOAEL_ADJ_=2.55 ppm) and converted to a human equivalent concentration (LOAEL_HEC_=2.55 ppm) using EPA (1994b) methodology for a category 3 gas; an uncertainty factor of 300 (10 for use of a LOAEL, 3 for extrapolation from animals to humans using dosimetric conversion, and 10 to protect sensitive individuals) was applied.

ATSDR has derived an intermediate-duration inhalation MRL of 0.006 ppm for benzene based on a LOAEL of 10 ppm for significantly delayed splenic lymphocyte reaction to foreign antigens evaluated in in vitro mixed lymphocyte reaction following the exposure of male C57Bl/6 mice to benzene vapors for 6 hours/day, 5 days/week for 20 exposure days (Rosenthal and Snyder 1987). The concentration was adjusted from intermittent to continuous exposure (LOAELADJ=1.8 ppm) and converted to a human equivalent concentration (LOAEL_HEC_=1.8 ppm) using EPA (1994b) methodology for a category 3 gas; an uncertainty factor of 300 (10 for the use of LOAEL, 3 for extrapolation from animals to humans using dosimetric conversion, and 10 for human variability) was applied.

ATSDR has derived a chronic-duration inhalation MRL of 0.003 ppm for benzene based on the results of benchmark dose (BMD) modeling of B cell counts in workers of shoe manufacturing industries in Tianjin, China (Lan et al. 2004a). The resulting BMCL_0.25sd_ of 0.10 ppm was adjusted from intermittent to continuous exposure (BMCL_0.25sdADJ_=0.03 ppm) using EPA (1994b) methodology; an uncertainty factor of 10 (to protect sensitive individuals) was applied.

ATSDR has derived a chronic-duration oral MRL of 0.0005 mg/kg/day for benzene based on estimation of equivalent chronic-duration oral dosing that would result in effects similar to those observed in the occupationally-exposed workers assessed by Lan et al. (2004a, 2004b). The BMCL_0.25sdADJ_ of 0.03 ppm (0.096 mg/m^3^) was converted to an equivalent BMDL_0.25sdADJ_ of 0.014 mg/kg/day for ingested benzene using EPA (1988b) human reference values for inhalation rate (20 m^3^/day) and body weight (70 kg) and a factor of 0.5 to adjust for differences in absorption of benzene following inhalation versus oral exposure; an uncertainty factor of 30 (10 to protect sensitive individuals and 3 for uncertainty in route-to-route extrapolation) was applied.

Table 8-1 Regulations and Guidelines Applicable to Benzene

Agency | | Description | Information | Reference
[underlined: INTERNATIONAL]
Guidelines:
| IARC | Carcinogenicity classification | Group 1^a^ | IARC 1987, 2004, 2007
| WHO | Air quality guidelines | 6×10^−6^ unit risk | WHO 2000
| | Drinking water quality guidelines | 0.01 mg/L^b^ | WHO 2004
[underlined: NATIONAL]
Regulations and Guidelines:
a. | Air
a. | ACGIH | TLV (TWA) | 0.5 ppm^c^ | ACGIH 2006
a. | ACGIH | STEL | 2.5 ppm^c^ | ACGIH 2006
a. | EPA | Hazardous air pollutant | Yes | EPA 2004b; 42 USC 7412
a. | NAS/NRC | AEGL-1^d^ | | EPA 2005a
a. | NAS/NRC | 10 minutes | 130 ppm | EPA 2005a
a. | NAS/NRC | 30 minutes | 73 ppm | EPA 2005a
a. | NAS/NRC | 60 minutes | 52 ppm | EPA 2005a
a. | NAS/NRC | 4 hours | 18 ppm | EPA 2005a
a. | NAS/NRC | 8 hours | 9.0 ppm | EPA 2005a
a. | NAS/NRC | AEGL-2^d^ | | EPA 2005a
a. | NAS/NRC | 10 minutes | 2,000 ppm^e^ | EPA 2005a
a. | NAS/NRC | 30 minutes | 1,100 ppm | EPA 2005a
a. | NAS/NRC | 60 minutes | 800 ppm | EPA 2005a
a. | NAS/NRC | 4 hours | 400 ppm | EPA 2005a
a. | NAS/NRC | 8 hours | 200 ppm | EPA 2005a
a. | NAS/NRC | AEGL-3^d^ | | EPA 2005a
a. | NAS/NRC | 10 minutes | 9,700 ppm^f^ | EPA 2005a
a. | NAS/NRC | 30 minutes | 5,600 ppm^e^ | EPA 2005a
a. | NAS/NRC | 60 minutes | 4,000 ppm^e^ | EPA 2005a
a. | NAS/NRC | 4 hours | 2,000 ppm^e^ | EPA 2005a
a. | NAS/NRC | 8 hours | 990 ppm | EPA 2005a
a. | NIOSH | REL (10-hour TWA) | 0.1 ppm^g^ | NIOSH 2005
a. | NIOSH | STEL | 1.0 ppm^g^ | NIOSH 2005
a. | NIOSH | IDLH | 500 ppm^g^ | NIOSH 2005
a. | OSHA | PEL (8-hour TWA) for general industry | 1 ppm | OSHA 2005b, 2005e; 29 CFR 1910.1000; 29 CFR 1910.1028
a. | OSHA | PEL (8-hour TWA) for construction industry | 1 ppm | OSHA 2005d, 2005f; 29 CFR 1926.55, Appendix A; 29 CFR 1926.1128
a. | OSHA | PEL (8-hour TWA) for shipyard industry | 1 ppm | OSHA 2005a,2005b; 29 CFR 1915.1000; 29 CFR 1915.1028
b. | Water
b. | EPA | Designated as hazardous substances in accordance with Section 311(b)(2)(A) of the Clean Water Act | Yes | EPA 2005b; 40 CFR 116.4
b. | EPA | Drinking water standards and health advisories | | EPA 2004a
b. | EPA | 1-day health advisory for a 10-kg child | 0.2 mg/L | EPA 2004a
b. | EPA | 10-day health advisory for a 10-kg child | 0.2 mg/L | EPA 2004a
b. | EPA | DWEL | 0.1 mg/L | EPA 2004a
b. | EPA | 10^−4^ Cancer risk | 0.1 mg/L | EPA 2004a
b. | EPA | National primary drinking water standards | | EPA 2002a
b. | EPA | MCLG | Zero | EPA 2002a
b. | EPA | MCL | 0.005 mg/L | EPA 2002a
b. | EPA | Reportable quantities of hazardous substances designated pursuant to Section 311 of the Clean Water Act | 10 pounds | EPA 2005c; 40 CFR 117.3
b. | EPA | Water quality criteria for human health consumption of: | | EPA 2002b
b. | EPA | Water + organism | 2.2 µg/L^h^ | EPA 2002b
b. | EPA | Organism only | 51 µg/L^h^ | EPA 2002b
c. | Food
c. | FDA | Bottled drinking water | 0.005 mg/L | FDA 2004; 21 CFR 165.110
d. | Other
d. | ACGIH | Carcinogenicity classification | A1^i^ | ACGIH 2006
d. | ACGIH | Biological exposure indices (end of shift) | | ACGIH 2006
d. | ACGIH | S-phenylmercapturic acid in urine | 25 µg/g creatinine | ACGIH 2006
d. | ACGIH | t,t-Muconic acid in urine | 500 µg/g creatinine | ACGIH 2006
d. | EPA | Carcinogenicity classification | Group A^j^ | IRIS 2007
d. | EPA | Oral slope factor | 1.5×10^−2^–5.5×10^−2^ per (mg/kg)/day | IRIS 2007
d. | EPA | Inhalation unit risk | 2.2×10^−6^–7.8×10^−6^ per µg/m^3^ | IRIS 2007
d. | EPA | RfC | 0.03 mg/m^3^ | IRIS 2007
d. | EPA | RfD | 4×10^−3^ mg/kg/day | IRIS 2007
d. | EPA | Superfund, emergency planning, and community right-to-know
d. | EPA | Designated CERCLA hazardous substance | | EPA 2005d; 40 CFR 302.4
d. | EPA | Reportable quantity | 10 pounds^k^ | EPA 2005d; 40 CFR 302.4
d. | EPA | RCRA hazardous waste number | U019 | EPA 2005d; 40 CFR 302.4
d. | EPA | Effective date of toxic chemical release reporting | 01/01/87 | EPA 2005e; 40 CFR 372.65
d. | NTP | Carcinogenicity classification | Known human carcinogen | NTP 2005

a Group 1: carcinogenic to humans

b For substances that are considered to be carcinogenic, the guideline value is the concentration in drinking water associated with an upper-bound excess lifetime cancer risk of 10^−5^ (one additional cancer per 100,000 of the population ingesting drinking water containing the substance at the guideline value for 70 years). Concentrations associated with upper-bound estimated excess lifetime cancer risks of 10^−4^ and 10^−6^ can be calculated by multiplying and dividing, respectively, the guideline value by 10.

c Skin notation: refers to the potential significant contribution to the overall exposure by the cutaneous route, including mucous membranes and the eyes, either by contact with vapors or, of probable greater significance, by direct skin contact with the substance.

d AEGL-1 is the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience notable discomfort, irritation, or certain asymptomatic nonsensory effects. AEGL-2 is the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience irreversible or other serious, long-lasting adverse health effects or an impaired ability to escape. AEGL-3 is the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience life-threatening health effects or death.

e Values denoted as having safety considerations against the hazard of explosion, whereas the Lower Explosive Limit (LEL) =14,000 ppm and each value should be ≥10% LEL.

f Value denoted as having extreme safety considerations against the hazard of explosion must be taken into account, whereas the LEL =14,000 ppm and each value should be ≥50% LEL.

g NIOSH potential occupational carcinogen

h This criterion is based on carcinogenicity of 10^−6^ risk.

i A1: confirmed human carcinogen

j Group A: known human carcinogen

k Designated CERCLA hazardous substance pursuant to Section 311(b)(2) and 307(a) of the Clean Water Act, Section 112 of the Clean Air Act, and Section 3001 of RCRA.

ACGIH = American Conference of Governmental Industrial Hygienists; AEGL = Acute Emergency Exposure Guideline Levels; CERCLA = Comprehensive Environmetnal Response, Compensation, and Liability Act; CFR = Code of Federal Regulations; DWEL = drinking water equivalent level; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; MCL = maximum contaminant level; MCLG = maximum contaminant level goal; NAS/NRC = National Academy of Sciences/National Research Council; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PEL = permissible exposure limit; RCRA = Resource Conservation and Recovery Act; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; STEL = short-term expsoure limit; TLV = threshold limit values; TWA = time-weighted average; USC = United States Code; WHO = World Health Organization

EPA (IRIS 2007) derived an inhalation reference concentration (RfC) for benzene of 0.03 mg/m^3^ (0.009 ppm) based on the results of BMD modeling of absolute lymphocyte (ALC) data from the occupational epidemiologic study of Rothman et al. (1996a), in which workers were exposed to benzene by inhalation. The resulting BMCL of 7.2 ppm for decreased lymphocyte count was converted to 23.0 mg/m^3^ and adjusted from intermittent to continuous exposure (BMCL_ADJ_=8.2 mg/m^3^); a total uncertainty factor of 300 (3 for effect-level extrapolation, 10 to protect sensitive individuals, 3 for subchronic-to-chronic extrapolation, and 3 for database deficiencies) was applied.

EPA (IRIS 2007) derived an oral reference dose (RfD) for benzene of 0.004 mg/kg/day, based on the results of BMD modeling of ALC data from the occupational epidemiologic study of Rothman et al. (1996a), in which workers were exposed to benzene by inhalation. The resulting BMCL of 7.2 ppm for decreased lymphocyte count was converted to 23.0 mg/m^3^ and adjusted from intermittent to continuous exposure (BMCL_ADJ_=8.2 mg/m^3^). Route-to-route extrapolation methodology was applied to convert from inhalation to equivalent oral exposure, resulting in an equivalent oral dose rate of 1.2 mg/kg/day. This value was divided by a total uncertainty factor of 300 (3 for effect-level extrapolation, 10 to protect sensitive individuals, 3 for subchronic-to-chronic extrapolation, and 3 for database deficiencies).

The International Agency for Research on Cancer (IARC) classifies benzene as a Group 1 carcinogen (carcinogenic to humans) (IARC 2004). EPA classified benzene in Category A (known human carcinogen) based on convincing evidence in humans supported by evidence from animal studies. Under EPA’s most recent guidelines for carcinogen risk assessment, benzene is characterized as a known human carcinogen for all routes of exposure based on convincing human evidence as well as supporting evidence from animal studies (IRIS 2007). The National Toxicology Programs lists benzene as a “substance known to be carcinogenic,” that is, a substance for which the evidence from human studies indicates that there is a causal relationship between exposure to the substance and human cancer (NTP 2005).

The EPA has a current maximum contaminant level (MCL) of 0.005 mg/L for benzene in drinking water (EPA 2002a). The World Health Organization (WHO) has established a guideline value of 0.01 mg/L for benzene in drinking water (WHO 2004).

Benzene is on the list of chemicals in “The Emergency Planning and Community Right-to-Know Act of 1986” (EPA 2005d). Section 313 of Title III of the Superfund Amendments and Reauthorization Act (SARA) requires owners and operators of certain facilities that manufacture, import, process, or otherwise use the chemicals on this list to report annually any release of those chemicals to any environmental media over a specified threshold level (U.S. Congress 1986).

OSHA requires employers of workers who are occupationally exposed to benzene to institute engineering controls and work practices to reduce and maintain employee exposure at or below permissible exposure limits (PEL). If an employer can document that benzene is used in the workplace <30 days/year, the employer can use any combination of engineering controls, work practice controls, or respirators to reduce employee exposure to or below the PEL of 1 ppm (8-hour TWA). Respirators must be provided and used during the time period necessary to install or implement feasible engineering and work practice controls, or where controls are not yet sufficient. Respirators are also required when the employer determines that compliance with the PEL is not feasible with engineering or work practice controls, such as maintenance and repair activities, vessel cleaning, or other operations where exposures are intermittent and limited in duration, and in emergencies (OSHA 2005c).

ACGIH limits exposure to benzene to 0.5 ppm (8-hour TWA) (ACGIH 2006). The National Institute for Occupational Safety and Health (NIOSH 2005) has established a recommended exposure level (REL) of 0.1 ppm (15-minute ceiling limit).