# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Environmental Medicine, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology and Environmental Medicine, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-32, Atlanta, Georgia 30333.

## Benzene Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Benzene
CAS Numbers: | 71-43-2
Date: | August 2007
Profile Status: | Post Public, Final Draft
Route: | [x] Inhalation [ ] Oral
Duration: | [x] Acute [ ] Intermediate [ ] Chronic
Graph Key: | 46
Species: | Mouse

[underlined: Minimal Risk Level]: 0.009 [ ] mg/kg/day [x] ppm

[underlined: Reference]: Rozen MG, Snyder CA, Albert RE. 1984. Depression in B- and T-lymphocyte mitogen-induced blastogenesis in mice exposed to low concentrations of benzene. Toxicol Lett 20:343–349 6608167 .

[underlined: Experimental design]: Male C57BL/6J mice (7–8/group) were exposed to benzene (0, 10.2, 31, 100, or 301 ppm) in whole-body dynamic inhalation chambers for 6 hours/day for 6 consecutive days. Control mice were exposed to filtered, conditioned air only. Erythrocyte counts were depressed in C57BL/6 mice only at 100 and 301 ppm. The 10.2 ppm exposure level resulted in significant depression of femoral lipopolysaccharide-induced B-colony-forming ability in the absence of a significant depression of total numbers of B cells. At 31 ppm, splenic phytohemagglutinin-induced blastogenesis was significantly depressed without a concomitant significant depression in numbers of T-lymphocytes. Peripheral lymphocyte counts were depressed at all exposure levels. These results demonstrate that short-term inhaled benzene even at low exposure concentrations can alter certain immune associated processes.

[underlined: Effect noted in study and corresponding doses]:

- 10.2 ppm = No adverse effect on erythrocytes, depressed peripheral lymphocytes and mitogen-induced blastogenesis of femoral B-lymphocytes (less serious LOAEL).
- 31 ppm = No adverse effect on erythrocytes, depression of mitogen-induced blastogenesis of splenic T-cells.
- 100 ppm = Depressed erythrocyte counts.

[underlined: Dose and end point used for MRL derivation]:

[ ] NOAEL [x] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]: 300

[ ] 1 [ ] 3 [x] 10 (for use of a LOAEL)

[ ] 1 [x] 3 [ ] 10 (for extrapolation from animals to humans using dosimetric conversion)

[ ] 1 [ ] 3 [x] 10 (for human variability)

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Not applicable.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: The concentration was adjusted for intermittent exposure by multiplying the LOAEL (10.2 ppm) by 6/24 to correct for less than a full day of exposure. The resulting LOAEL_ADJ_ is 2.55 ppm.

According to current EPA (1994b) methodology for calculating a human equivalent concentration (HEC) for extrarespiratory effects of a category 3 gas (such as benzene):

LOAEL_HEC_ = LOAEL_ADJ_ × ( [ H_b / g_ ]_A_ / [ H_b / g_ ]_H_ )

where:

- LOAEL_HEC_ = The LOAEL dosimetrically adjusted to a human equivalent concentration
- LOAEL_ADJ_ = The LOAEL adjusted from intermittent to continuous exposure
- [H_b/g_]_A_/[H_b/g_]_H_ = The ratio of the blood:gas partition coefficient of the chemical for the laboratory animal species to the human value

If the animal blood:gas partition coefficient is greater than the human blood:gas partition coefficient, a default value of 1 is used for the ratio. According to Wiester et al. (2002), benzene blood:gas partition coefficients for mice and humans are 17.44 and 8.12, respectively. Therefore the default value of 1 is applied, in which case, the LOAEL_HEC_ is equivalent to the LOAEL_ADJ_ = 2.55 ppm.

[underlined: Was a conversion used from intermittent to continuous exposure]? The concentration was adjusted for intermittent exposure by multiplying the LOAEL (10.2 ppm) by 6/24 to correct for less than a full day of exposure. The resulting LOAEL_ADJ_ is 2.55 ppm.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Increased number of micronucleated polychromatic erythrocytes (MN-PCEs), decreased numbers of granulopoietic stem cells (Toft et al. 1982), lymphopenia (Cronkite et al. 1985), lymphocyte depression, and increased susceptibility to bacterial infection (Rosenthal and Snyder 1985) are among the adverse hematological and immunological effects observed in several other acute-duration inhalation studies. The study by Rozen et al. (1984) shows benzene immunotoxicity (reduced mitogen-induced lymphocyte proliferation) at a slightly lower exposure level than these other studies. C57BI/6J mice were exposed to 0, 10.2, 31, 100, and 301 ppm benzene for 6 days at 6 hours/day. Lymphocyte counts were depressed at all exposure levels while erythrocyte counts were elevated at 10.2 ppm, equal to controls at 31 ppm, and depressed at 100 and 301 ppm. Femoral B-lymphocyte and splenic B-lymphocyte numbers were reduced at 100 ppm. Levels of circulating lymphocytes and mitogen-induced blastogenesis of femoral B-lymphocytes were depressed after exposure to 10.2 ppm benzene for 6 days. Mitogen-induced blastogeneses of splenic T-lymphocytes were depressed after exposure to 31 ppm of benzene for 6 days. In another study, mice exhibited a 50% decrease in the population of erythroid progenitor cells (CFU-E) after exposure to 10 ppm benzene for 5 days, 6 hours/day (Dempster and Snyder 1991). In a study by Wells and Nerland (1991), groups of 4–5 male Swiss-Webster mice were exposed to 0, 3, 25, 55, 105, 199, 303, 527, 1,150, or 2,290 ppm benzene for 6 hours/day for 5 days. The number of leukocytes in peripheral blood and spleen weights were significantly decreased compared with untreated controls at all concentrations ≥25 ppm. Therefore, 3 ppm was the NOAEL and 25 ppm was the LOAEL for these effects. Other end points were not monitored in this study. These data support the choice of Rozen et al. (1984) as a critical study.

[underlined: Agency Contacts (Chemical Managers)]: Sharon Wilbur, M.A., Sam Keith, M.S., C.H.P., Obaid Faroon, Ph.D.

## Benzene Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Benzene
CAS Numbers: | 71-43-2
Date: | August 2007
Profile Status: | Post Public, Final Draft
Route: | [x] Inhalation [ ] Oral
Duration: | [ ] Acute [x] Intermediate [ ] Chronic
Graph Key: | 126
Species: | Mouse

[underlined: Minimal Risk Level]: 0.006 [ ] mg/kg/day [x] ppm

[underlined: Reference]: Rosenthal GJ, Snyder CA. 1987. Inhaled benzene reduces aspects of cell-mediated tumor surveillance in mice. Toxicol Appl Pharmacol 88:35–43 2951897 .

[underlined: Experimental design]: Male C57Bl/6 mice were exposed to 10, 30, or 100 ppm of benzene by inhalation 6 hours/day, 5 days/week for 20 exposure days. The number of lymphocytes and their functional capacities were evaluated in spleens of exposed mice. Following the 20 days of exposure, functional capacity of splenic lymphocytes was evaluated in two in vitro assays: mixed-lymphocyte culture (MLC) and 51Cr-release cytotoxicity assay. Measured mean daily benzene concentrations in the 10, 30, and 100 ppm groups were 11.1 (±1.5) ppm, 29.5 (±4.4) ppm, and 99.7 (±7.0) ppm, respectively. No changes were observed in the relative proportions of splenic leukocytes, in the percentage of T-cell subsets or in the ratio of T-helper and T-suppressor cells, even at the highest exposure level (100 ppm). Therefore, the functional assays could be normalized for particular lymphocyte populations by using equal numbers of splenic cells. MLC is an in vitro measure of alloreactivity (capacity to mount an immune response against foreign antigens). The MLC activity of spleen lymphocytes from 10- and 100-ppm mice was delayed on days 2–4 of culture (relative to air-exposed controls), indicating that benzene exposure causes impaired in vitro alloreactivity (data for the 30-ppm mice were not included in the reported results). This delayed alloreactivity was not due to spleen suppressor cells. The lymphocyte cytotoxic function evaluated in the 51Cr-release assay was also altered; splenic lymphocytes from 100-ppm mice had a significantly reduced lysing capacity. The results indicate that inhalation exposure of mice to benzene has an immunodepressive effect on in vitro alloreactivity and cytotoxicity of splenic lymphocytes.

[underlined: Effect noted in study and corresponding doses]:

- 10 ppm = Significantly delayed splenic lymphocyte reaction to foreign antigens evaluated in in vitro mixed lymphocyte reaction (less serious LOAEL).
- 30 ppm = Results not reported.
- 100 ppm = Significantly delayed splenic lymphocyte reaction to foreign antigens evaluated in in vitro mixed lymphocyte reaction.

[underlined: Dose and end point used for MRL derivation]:

[ ] NOAEL [x] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]: 300

[ ] 1 [ ] 3 [x] 10 (for use of a LOAEL)

[ ] 1 [x] 3 [ ] 10 (for extrapolation from animals to humans using dosimetric conversion)

[ ] 1 [ ] 3 [x] 10 (for human variability)

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Not applicable.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: According to current EPA (1994b) methodology for calculating a human equivalent concentration (HEC) for extrarespiratory effects of a category 3 gas (such as benzene):

LOAEL_HEC_ = LOAEL_ADJ_ × ( [ H_b / g_ ]_A_ / [ H_b / g_ ]_H_ )

where:

- LOAEL_HEC_ = The LOAEL dosimetrically adjusted to a human equivalent concentration
- LOAEL_ADJ_ = The LOAEL adjusted from intermittent to continuous exposure
- [H_b/g_]_A_/[H_b/g_]_H_ = The ratio of the blood:gas partition coefficient of the chemical for the laboratory animal species to the human value

If the animal blood:gas partition coefficient is greater than the human blood:gas partition coefficient, a default value of 1 is used for the ratio. According to Wiester et al. (2002), benzene blood:gas partition coefficients for mice and humans are 17.44 and 8.12, respectively. Therefore, the default value of 1 is applied, in which case, the LOAEL_HEC_ is equivalent to the LOAEL_ADJ_.

[underlined: Was a conversion used from intermittent to continuous exposure]? The concentration was adjusted for intermittent exposure by multiplying the LOAEL (10 ppm) by 6 hours/24 hours to correct for less than a full day of exposure and 5 days/7 days to correct for less than a full week of exposure. The resulting LOAEL_ADJ_ is 1.8 ppm.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Exposure of C57BL mice to 10 ppm benzene for 6 hours/day, 5 days/week caused significant depressions in numbers of lymphocytes (ca. 30% lower than controls) as early as exposure day 32; this effect was also noted at the other scheduled periods of testing (exposure days 66 and 178) (Baarson et al. 1984). Splenic red blood cells were significantly reduced (ca. 15% lower than controls) at exposure days 66 and 178. The failure of the erythrons of benzene-exposed mice to support normal red cell mass was illustrated by the significant reduction in peripheral red cell numbers in these animals at 66 and 178 days of benzene exposure. Green et al. (1981a, 1981b) exposed male CD-1 mice to benzene vapors at concentrations of 0 or 9.6 ppm for 6 hours/day, 5 days/week for 50 days and assessed the effects of exposure on cellularity in the spleen, bone marrow, and peripheral blood. Exposure-related effects included a 90% increase in numbers of multipotential hematopoietic stem cells (CFU-S) (Green et al. 1981a), approximately 25% increase in spleen weight and total splenic nucleated cellularity (Green et al. 1981b), and 80% increase in nucleated RBCs (Green et al. 1981b). The results of Baarson et al. (1984) and Green et al. (1981a, 1981b) are limited for purposes of quantitative risk assessment because a single exposure level was employed. However, they support the choice of Rosenthal and Snyder (1987) as the critical study, which serves as the basis for the intermediate-duration inhalation MRL.

[underlined: Agency Contacts (Chemical Managers)]: Sharon Wilbur, M.A., Sam Keith, M.S., C.H.P., Obaid Faroon, Ph.D.

## Benzene Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Benzene
CAS Numbers: | 71-43-2
Date: | August 2007
Profile Status: | Post Public, Final Draft
Route: | [x] Inhalation [ ] Oral
Duration: | [ ] Acute [ ] Intermediate [x ] Chronic
Graph Key: | 161
Species: | Human

[underlined: Minimal Risk Level]: 0.003 [ ] mg/kg/day [x] ppm [ ] mg/m^3^

[underlined: Reference]: Lan Q, Zhang L, Li G, . 2004a. Hematotoxicity in workers exposed to low levels of benzene. Science 306:1774–1776 15576619 .

[underlined: Experimental design]: A cross-sectional study was performed on 250 workers (approximately two-thirds female) exposed to benzene at two shoe manufacturing facilities in Tianjin, China, and 140 age- and gender-matched workers in clothing manufacturing facilities that did not use benzene. The benzene-exposed workers had been employed for an average of 6.1±2.9 years. Benzene exposure was monitored by individual organic vapor monitors (full shift) 5 or more times during 16 months prior to phlebotomy. Post-shift urine samples were collected from every worker. Urinary benzene concentrations were highly correlated with mean individual air levels. Benzene was not found (detection limit 0.04 ppm) in workplace and home air samples of control workers taken at three different time periods. Study subjects were categorized into four groups (140 controls, 109 at <1 ppm, 110 at 1–<10 ppm, and 31 at ≥10 ppm) according to mean benzene exposure levels measured twice during the month prior to phlebotomy. Of the 250 exposed workers, 109 were exposed to <1 ppm benzene. Each of these individuals worked at the larger of the two facilities included in the study. Exposure concentrations were generally higher at the smaller facility due to a less adequate ventilation system. Complete blood count (CBC) and differential were analyzed mechanically. Coefficients of variation for all cell counts were <10%.

Mean 1-month benzene exposure levels in the four groups (controls, <1 ppm, 1–<10 ppm, and ≥10 ppm) were <0.04, 0.57±0.24, 2.85±2.11, and 28.73±20.74 ppm, respectively (see Table A-1). An evaluation of potential confounding factors showed that age, gender, cigarette smoking, alcohol consumption, recent infection, and body mass index were associated with at least one hematological end point. The values in Table A-1 represent values that were adjusted to account for these variables. All types of white blood cells (WBCs) and platelets were significantly decreased in the lowest exposure group (<1 ppm), ranging in magnitude from approximately 8 to 15% lower than controls. Although similar statistical analyses for the mid- and high-exposure groups were not included in the study report, decreases in all types of WBCs and platelets were noted at these exposure levels as well; the decreases in the highest exposure group ranged in magnitude from 15 to 36%. Lymphocyte subset analysis revealed significantly decreased CD4+-T cells, CD4+/CD8+ ratio, and B cells. Hemoglobin concentrations were significantly decreased only within the highest (≥10 ppm) exposure group. Tests for a linear trend using benzene air level as a continuous variable were significant for platelets and all WBC measures except monocytes and CD8+-T cells. Upon restricting the linear trend analyses to workers exposed to <10 ppm benzene, excluding controls, inverse associations remained for total WBCs, granulocytes, lymphocytes, B cells, and platelets. In order to evaluate the effect of past benzene exposures on the hematological effects observed in this study, the authors compared findings for a group of workers who had been exposed to <1 ppm benzene over the previous year (n=60) and a subset who also had <40 ppm-years lifetime cumulative benzene exposure (n=50). The authors stated that the same cell types were significantly reduced in these groups, but did not provide further information of the magnitude (i.e., percent change) of the hematological effects observed. These data suggest that the 1-month benzene exposure results could be used as an indicator of longer term low-level benzene hematotoxicity. To demonstrate that the observed effects were attributable to benzene, significantly decreased levels of WBCs, granulocytes, lymphocytes, and B cells were noted in a subgroup (n=30; mean 1-month exposure level of 0.29±0.15 ppm) of the <1 ppm group for which exposure to other solvents was negligible.

Table A-1 Significantly Reduced Blood Values in Workers Exposed to Benzene in Tianjin, China (Adapted from Lan et al. 2004a)

End point | Mean exposure level in ppm^a^ (number of subjects)
End point | <0.04 (140) | 0.57±0.24 (109) | 2.85±2.11 (110) | 28.73±20.74 (31)
WBCs^b^ | 6,480±1,710 | 5,540±1,220^d^ | 5,660±1,500 | 4,770±892
Granulocytes^b^ | 4,110±1,410 | 3,360±948^d^ | 3,480±1,170 | 2,790±750
Monocytes^b^ | 241±92 | 217±97^d^ | 224±93 | 179±74
Lymphocytes^b^ | 2,130±577 | 1,960±541^d^ | 1,960±533 | 1,800±392
CD4+-T cells^b^ | 742±262 | 635±187^d^ | 623±177 | 576±188
CD4+/CD8+ ratio | 1.46±0.58 | 1.26±0.41^d^ | 1.22±0.45 | 1.09±0.35
B cells^b^ | 218±94 | 186±95^d^ | 170±75 | 140±101
Platelets^c^ | 230±59.7 | 214±48.8^d^ | 200±53.4 | 172±44.8

a Arithmetic mean of an average of two measurements per subject collected during the month prior to phlebotomy

b Mean cell numbers per microliter blood±standard deviation

c Mean number of platelets (×10^3^)

d Statistically significantly lower than controls (p<0.05) by linear regression on ln of each end point

[underlined: Effect noted in study and corresponding doses]: As shown in Table A-1, exposure-response relationships were noted for several blood factors. Benzene-induced decreased B cell count was selected as the critical effect for benchmark dose (BMD) modeling because it represented the highest magnitude of effect (i.e., B cell count in the highest exposure group was approximately 36% lower than that of controls). A BMD modeling approach was selected to identify the point of departure because the critical study (Lan et al. 2004a) identified a LOAEL in the absence of a NOAEL.

[underlined: Dose and end point used for MRL derivation]: 0.10 ppm (BMCL_0.25sd_) for decreased B cell count.

All continuous variable models in the EPA Benchmark Dose Software (Version 1.3.2) were fit to the B cell count data shown in Table A-1. Visual inspection of the plots of observed versus expected values for B cell counts indicated that the Hill model provided the only adequate fit of the data set (see Figure A-1). A benchmark response (BMR) of 0.25 sd below the control mean B cell count was selected because it resulted in a BMC_0.25sd_ of 0.42 ppm and its lower 95% confidence limit (BMCL_0.25sd_) of 0.10 ppm (Figure A-1), which are below the mean exposure level of the lowest exposure group (0.57 ppm) for which a statistically significant decrease in mean B cell count (186 versus 218 in controls, see Table A-1) was observed. Although Lan et al. (2004a, 2004b) noted significantly decreased levels of WBCs, granulocytes, lymphocytes, and B cells in a subgroup (n=30; mean 1-month exposure level of 0.29±0.15 ppm) of the 0.57 ppm exposure group, this subgroup could not be included in the BMD analysis because the study authors did not include the means and standard deviations for the decreased blood factors, nor did they provide quantitative information regarding the remaining 70 subjects in the 0.57 ppm exposure group (n=109). Assuming that the 0.29 ppm exposure level may represent a minimally adverse exposure level, it seems reasonable to accept the BMCL_0.25sd_ of 0.10 ppm as the point of departure for deriving a chronic-duration inhalation MRL for benzene.

Figure A-1 Observed and Predicted B Cell Counts in Human Subjects Occupationally Exposed to Benzene

BMD=BMC_0.25sd_=0.42 ppm; BMDL=BMCL_0.25sd_=0.10 ppm

The computer output for fitting of the Hill model to B cell counts in human subjects occupationally exposed to benzene (Lan et al. 2004a) follows.

====================================================================
        Hill Model. $Revision: 2.1 $ $Date: 2000/10/11 21:21:23 $
        Input Data File: C:\ATSDR\BENZENE\BMD FILES\BENZENELANBCELLS.(d)
        Gnuplot Plotting File: C:\ATSDR\BENZENE\BMD
FILES\BENZENELANBCELLS.plt
                                          Mon Nov 20 09:27:13 2006
 ====================================================================

 BMDS MODEL RUN
~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~~

  The form of the response function is:

  Y[dose] = intercept + v*dose^n/(k^n + dose^n)

  Dependent variable = MEAN
  Independent variable = ppm
  rho is set to 0
  Power parameter restricted to be greater than 1
  A constant variance model is fit

  Total number of dose groups = 4
  Total number of records with missing values = 0
  Maximum number of iterations = 250
  Relative Function Convergence has been set to: 1e-008
  Parameter Convergence has been set to: 1e-008

                        Default Initial Parameter Values
                              alpha =      8224.64
                                rho =         0   Specified
                          intercept =       218
                                  v=        -78
                                  n=          0.572459
                                  k=          1.5675

            Asymptotic Correlation Matrix of Parameter Estimates

           ( *** The model parameter(s) -n have been estimated at a
boundary point, or have been specified by the user, and do not appear in the
correlation matrix )

                alpha            rho      intercept              v         k

alpha                1            0               0              0         0

rho                  0            1               0              0         0

intercept            0            0               1              0         0

v                    0            0               0              1         0

k                    0            0               0              0         1

                             Parameter Estimates
                                                      
         Variable             Estimate			Std. Err. 
            alpha               8027.09                        1
              rho                     0            	       1	
        intercept               217.113                        1
                v              -69.0144                        1
                n                     1                    NA 
                k              0.878186                        1

NA - Indicates that this parameter has hit a bound
     implied by some inequality constraint and thus
     has no standard error.


      Table of Data and Estimated Values of Interest

Dose       N    Obs Mean    Obs Std Dev   Est Mean    Est Std Dev    Chi^2 Res.
------    ---   --------    -----------   --------    -----------    ----------

 0        140       218         94          217           89.6        0.0099
 0.57     109       186         95          190           89.6       -0.0441
 2.85     110       170         75          164           89.6        0.063
28.73      31       140        101          150           89.6       -0.113


Model Descriptions for likelihoods calculated


Model A1:             Yij = Mu(i) + e(ij)
                 Var{e(ij)} = Sigma^2

Model A2:              Yij = Mu(i) + e(ij)
               Var{e(ij)} = Sigma(i)^2 

Model  R:             Yi = Mu + e(i)
                Var{e(i)} = Sigma^2 


Degrees of freedom for Test A1 vs fitted <= 0

                             Likelihoods of Interest

                Model         Log(likelihood)   DF          AIC
                 A1           -1947.632025       5      3905.264050
                 A2           -1943.411648       8      3902.823297
               fitted         -1948.162584       4      3904.325168
                  R           -1962.157799       2      3928.315597

Test 1:     Does response and/or variances differ among dose levels
            (A2 vs. R)
Test 2:     Are Variances Homogeneous (A1 vs A2)
Test 3:     Does the Model for the Mean Fit (A1 vs. fitted) 

                            Tests of Interest

  Test         -2*log(Likelihood Ratio)     Test df       p-value
  Test 1                      37.4923           6           <.0001 
  Test 2                      8.44075           3          0.03773 
  Test 3                      1.06112           0               NA 

The p-value for Test 1 is less than .05. There appears to be a
difference between response and/or variances among the dose levels.
It seems appropriate to model the data

The p-value for Test 2 is less than .05. Consider running a
non-homogeneous variance model

NA - Degrees of freedom for Test 3 are less than or equal to 0. The Chi-
Square test for fit is not valid

Benchmark Dose Computation
Specified effect =          0.25

Risk Type        =     Estimated standard deviations from the control mean

Confidence level =          0.95

             BMC =       0.42196

            BMCL =      0.104163

Although Test 3 (mean fit) produced an invalid Chi-Square test (degrees of freedom ≤0), visual inspection of the observed vs expected B cell counts from the Hill model output (Figure A-1) resulted in the determination that the predicted B cell counts adequately reflect the observed values and that the associated BMCL_0.25sd_ of 0.104163 provides an appropriate point of departure for deriving a chronic-duration inhalation MRL for benzene.

[ ] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]: 10

- [ ] 1 [ ] 3 [ ] 10 (for use of a LOAEL)
- [ ] 1 [ ] 3 [ ] 10 (for extrapolation from animals to humans)
- [ ] 1 [ ] 3 [x] 10 (for human variability)

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Not applicable.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? The BMCL_0.25sd_ of 0.10 ppm was adjusted from the 8-hour TWA to a continuous exposure concentration (BMCL_0.25sdADJ_) as follows:

BMCL_0.25 sdADJ_ = BMCL_0.25 sd_ × ( 8 hours / 24 hours ) × ( 6 days / 7 days )

Therefore:

BMCL_0.25 sdADJ_ = 0.10 ppm × ( 8 hours / 24 hours ) × ( 6 days / 7 days )

BMCL_0.25 sdADJ_ = 0.03 ppm

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Lan et al. (2004a, 2004b) was selected as the critical study for derivation of a chronic-duration inhalation MRL because it (1) was well designed, (2) provided adequate exposure-response information, (3) employed individual exposure monitoring data collected for up to 16 months prior to blood testing, (4) demonstrated effects that did not appear to be significantly influenced by previous high-level exposures, and (5) included larger numbers of subjects than previous studies (Qu et al. 2002, 2003; Rothman et al. 1996a, 1996b; Ward et al. 1996). In addition, Lan et al. (2004a, 2004b) measured lymphocyte subsets and colony formation from hematopoietic progenitor cells as measures of toxicity.

Previously conducted epidemiology studies provide support to the findings of Lan et al. (2004a). Qu et al. (2002, 2003) compared hematologic values among 105 healthy workers (51 men, 54 women) in industries with a history of benzene usage (Tianjin, China) and 26 age- and gender-matched workers in industries that did not use benzene. Benzene-exposed workers were chosen based on at least 3 years of exposure history. The mean duration of occupational exposure to benzene was 9.7 years (SD=6.2 years). At the time of the study, benzene exposure was monitored by individual organic vapor monitors at 1-week intervals for 4 weeks prior to collection of blood samples for analysis. Measured benzene levels were averaged for each individual to produce a 4-week mean exposure level. Exposure-response relationships were assessed according to ranges of benzene levels (unexposed, >0–5, >5–15, >15–30, and >30 ppm). Benzene hematotoxicity was assessed by mechanical counts of total WBCs, red blood cells (RBCs), and platelets. The WBC differential was hand-counted on a total of 900 cells. Calculations of the numbers of various WBC types were based on total WBCs and differential counts. The mean 4-week benzene level in the control group was 0.004±0.003 ppm. Among all the benzene-exposed workers, the mean 4-week benzene exposure level was 5.2±7.3 ppm. Within the >0–5, >5–15, >15–30, and >30 ppm exposure categories, mean 4-week benzene levels were 2.26±1.35, 8.67±2.44, 19.9±3.1, and 51.8±43.3 ppm, respectively. A significant exposure-related reduction in the numbers of neutrophils (ranging in magnitude from 12% in the 2.26 ppm exposure group to 31% in the 51.8 ppm exposure group) was observed in all four groups of benzene-exposed workers, relative to controls. Significantly reduced numbers of RBCs (approximately 11–16% lower than controls) were also noted in all benzene-exposed groups. Significantly reduced total WBCs were seen in the highest (>30 ppm) exposure group. The study authors identified a subgroup (within the >0–5 ppm exposure group) of 16 women with no measured exposure levels exceeding 0.5 ppm (4-week mean benzene exposure level of 0.14±0.04 ppm) and reported significantly reduced total WBCs, neutrophils, and RBCs in this subgroup as well. However, these results are based on a small number of workers within the larger group and the reduced counts of total WBCs, neutrophils, and RBCs within this subgroup are –much greater in magnitude than those reported for the main (>0–5 ppm) exposure group, rendering the results in this subgroup of questionable value for purposes of risk assessment. Qu et al. (2002, 2003) clearly identified a LOAEL of 2.26 ppm for significantly reduced total WBCs, neutrophils, and RBCs, and provided indication of benzene-induced changes in some hematological values at exposure levels lower than the current industry 8-hour TWA of 1 ppm.

Rothman et al. (1996a, 1996b) performed a cross-sectional study in 1992 on 44 healthy workers (23 males, 21 females) in Chinese (Shanghai) industries with a history of benzene usage and 44 age- and gender-matched workers in industries that did not use benzene. The mean duration of occupational exposure to benzene was 6.3 years (SD=4.4 years). At the time of the study, benzene exposure was monitored by individual organic passive dosimetry badges on 5 separate days during 1 to 2 weeks prior to the collection of blood and urine samples for analysis. Benzene hematotoxicity was assessed by mechanical counts of total WBCs, absolute lymphocytes (ALC), RBCs, and platelets, as well as hemoglobin value and mean corpuscular volume (MCV). The WBC differential was also hand-counted on 100 cells. Abnormal counts were reviewed by hand. Mean (geometric mean of the five exposure samples) 8-hour TWAs for the benzene-exposed workers ranged from 1 to 238 ppm (median 8-hour TWA of 31 ppm). Benzene-exposed workers exhibited statistically significantly reduced numbers of total WBCs, ALC, RBCs, and platelets (approximately 12, 21, 6, and 23% lower, respectively) and significantly increased MCV (approximately 3% higher), relative to unexposed workers. The results were comparable in both men and women. Among the benzene-exposed workers whose mean exposure levels were >31 ppm (median 8-hour TWA of 91.9 ppm; n=22), all measured blood parameters were significantly different from controls; only ALC, RBCs, and platelets were significantly lower in benzene workers with mean exposures of <31 ppm (median 8-hour TWA of 13.6; n=22), compared with controls. In a subgroup of benzene-exposed workers whose measured benzene exposure levels did not exceed 31 ppm on any of the five sampling days (median 8–hour TWA of 7.6 ppm; n=11), significantly reduced ALC (approximately 16% lower than controls) was noted.

In a nested case-control study of a cohort of workers in the Pliofilm production departments of a rubber products manufacturer in Ohio (Ward et al. 1996), incident cases were defined as the first occurrence of a low WBC or RBC count, and matched controls were chosen from those tested within approximately 6 months of the case’s blood test date. Hematologic screening data were available for 657 of 1,037 individuals employed at the plant from 1939 through 1976. A total of 21,710 blood test records were identified; the number of blood tests per individual ranged from 1 to 354, but the majority of subjects had five or fewer blood tests. All blood tests were taken from 1940 through 1975, the majority of which were routine hematological screening tests. Benzene exposures were estimated using a job exposure matrix developed by Rinsky et al. (1987). The effects of benzene exposure in the 30, 90, and 180 days prior to the blood test date, as well as cumulative exposure up until the blood test date, were examined using conditional logistic regression. A total of 78 cases and 5,637 controls were included in the WBC analysis and 105 cases and 8,489 controls in the RBC analysis, all of whom had worked only within the rubber hydrochloride departments during the 180 days prior to the selected blood sample date. The maximum daily benzene exposure estimate was 34 ppm. A strong exposure-response relationship was noted for WBCs, and all of the exposure metrics selected showed a significant relationship with low blood count. A weak positive exposure-response relationship was observed for RBCs, which was significant for the dose metric of cumulative exposure up until the blood test date. The study authors noted that there was no evidence for a threshold for hematologic effects and suggested that exposure to benzene levels <5 ppm may result in hematologic suppression.

[underlined: Agency Contacts (Chemical Managers)]: Sharon Wilbur, M.A., Sam Keith, M.S., C.H.P., Obaid Faroon, Ph.D.

## Benzene Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Benzene
CAS Numbers: | 71-43-2
Date: | August 2007
Profile Status: | Post Public, Final Draft
Route: | [ ] Inhalation [x] Oral
Duration: | [ ] Acute [ ] Intermediate [x] Chronic
Graph Key: | 45
Species: | Human

[underlined: Minimal Risk Level]: 0.0005 [x] mg/kg/day [ ] ppm

[underlined: Reference]: Lan Q, Zhang L, Li G, . 2004a. Hematotoxicity in workers exposed to low levels of benzene. Science 306:1774–1776 15576619 .

[underlined: Experimental design]: The chronic-duration oral MRL for benzene is based on route-to-route extrapolation of the results of benchmark dose analysis of a hematological endpoint (B cell count) assessed in 250 workers (approximately two-thirds female) exposed to benzene at two shoe manufacturing facilities in Tianjin, China, and 140 age- and gender-matched workers in clothing manufacturing facilities that did not use benzene. See the MRL worksheet for the chronic-duration inhalation MRL for details of study design.

[underlined: Effect noted in study and corresponding doses]: As described in the MRL worksheet for the chronic-duration inhalation MRL (see also Table A-1), exposure-response relationships were noted for several blood factors. Benzene-induced decreased B cell count was selected as the critical effect for benchmark dose (BMD) modeling because it represented the highest magnitude of effect (i.e., B cell count in the highest exposure group was approximately 36% lower than that of controls). A BMD modeling approach was selected to identify the point of departure because the critical study (Lan et al. 2004a) identified a LOAEL in the absence of a NOAEL.

[underlined: Dose and end point used for MRL derivation]: BMCL_0.25sdADJ_ of 0.014 mg/kg/day for decreased B cell count, resulting from route-to-route extrapolation of the BMCL_0.25sdADJ_ of 0.03 ppm described in the MRL worksheet for the chronic-duration inhalation MRL.

Results of toxicokinetic studies of inhaled benzene in humans (Nomiyama and Nomiyama 1974a; Pekari et al. 1992; Srbova et al. 1950) and inhaled and orally-administered benzene in rats and mice (Sabourin et al. 1987) indicate that absorption of benzene at relatively low levels of exposure is approximately 50% of an inhaled dose and essentially 100% of an oral dose. Based on these assumptions, inhalation data can be used to estimate equivalent oral doses that would be expected to similarly affect the critical targets of benzene toxicity. Therefore, the point of departure for the chronic-duration inhalation MRL for benzene, namely the BMCL_0.25sdADJ_ of 0.03 ppm for decreased B cell counts in benzene-exposed workers (Lan et al. 2004a, 2004b), serves as the point of departure for deriving the chronic-duration oral MRL as well.

The point of departure (in ppm) was converted to mg/m^3^ using the molecular weight of 78.11 for benzene and assuming 25 °C and 760 mm Hg:

BMCL_0.25 sdADJ_ of 0.03 ppm × 78.11 / 24.45 = 0.096 mg / m^3^

The BMCL_0.25sdADJ_ of 0.096 mg/m^3^ for inhaled benzene was converted to an equivalent BMDL_0.25sdADJ_ for ingested benzene using EPA (1988b) human reference values for inhalation rate (20 m^3^/day) and body weight (70 kg) and a factor of 0.5 to adjust for differences in absorption of benzene following inhalation versus oral exposure (50 versus 100%, respectively) as follows:

BMDL_0.25 sdADJ_ = BMCL_0.25 sdADJ_ of 0.096 mg / m^3^ × 20 m^3^ / day × 0.5 ÷ 70 kg = 0.014 mg / kg / day

[ ] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]: 30

[ ] 1 [ ] 3 [ ] 10 (for use of a LOAEL)

[ ] 1 [ ] 3 [ ] 10 (for extrapolation from animals to humans)

[ ] 1 [ ] 3 [x] 10 (for human variability)

[ ] 1 [x] 3 [ ] 10 (for uncertainty in route-to-route extrapolation)

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Not applicable.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? The BMCL_0.25sd_ of 0.10 ppm was adjusted from the 8-hour TWA to a continuous exposure concentration (BMCL_0.25sdADJ_) as follows:

BMCL_0.25 sdADJ_ = BMCL_0.25 sd_ × ( 8 hours / 24 hours ) × ( 6 days / 7 days )

Therefore:

BMCL_0.25 sdADJ_ = 0.10 ppm × ( 8 hours / 24 hours ) × ( 6 days / 7 days )

BMCL_0.25 sdADJ_ = 0.03 ppm

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Results of toxicokinetic studies of inhaled benzene in humans (Nomiyama and Nomiyama 1974a; Pekari et al. 1992; Srbova et al. 1950) and inhaled and orally-administered benzene in rats and mice (Sabourin et al. 1987) indicate that absorption of benzene at relatively low levels of exposure is approximately 50% of an inhaled dose and essentially 100% of an oral dose. Based on these assumptions, inhalation data can be used to estimate equivalent oral doses that would be expected to similarly affect the critical targets of benzene toxicity. See the chronic-duration inhalation MRL worksheet for additional information that supports the selection of the principal study and critical effect for deriving the chronic-duration inhalation MRL.

[underlined: Agency Contacts (Chemical Managers)]: Sharon Wilbur, M.A., Sam Keith, M.S., C.H.P., Obaid Faroon, Ph.D.