# ADDENDUM TO THE TOXICOLOGICAL PROFILE FOR BENZENE

## ADDENDUM for BENZENE

Supplement to the 2007 Toxicological Profile for Benzene

### Background Statement

This addendum to the Toxicological Profile for Benzene (http://www.atsdr.cdc.gov/toxprofiles/tp3.pdf) supplements the profile that was released in 2007.

Toxicological profiles are developed in response to the Superfund Amendments and Reauthorization Act (SARA) of 1986 which amended the Comprehensive Environmental Response, Compensation, and Liability Act of 1980 (CERCLA or Superfund). CERCLA mandates that the Administrator of ATSDR prepare toxicological profiles on substances on the CERCLA Priority List of Hazardous Substances. CERCLA further states that the Administrator will “establish and maintain inventory of literature, research, and studies on the health effects of toxic substances” [Title 42, Chapter 103, Subchapter I, § 9604 (i)(1)(B)].

The purpose of this addendum is to provide to the public and federal, state, and local agencies a non-peer reviewed supplement of the scientific data that were published in the open peer-reviewed literature since the release of the profile in 2007.

Chapter numbers in this addendum coincide with the Toxicological Profile for Benzene (http://www.atsdr.cdc.gov/toxprofiles/tp3.pdf) (2007). This document should be used in conjunction with the profile. It does not replace it.

## 3 HEALTH EFFECTS

### 3.2 DISCUSSION OF HEALTH EFFECTS BY ROUTE OF EXPOSURE

#### 3.2.1 Inhalation Exposure

##### 3.2.1.2 Systemic Effects

Hepatic Effects. Uzma et al. (2008) evaluated peripheral blood from 154 healthy benzene-exposed male filling station attendants (94 with <10 years of exposure and 60 with >10 years of exposure); a control group of 33 healthy subjects matched for demographics was included. Analysis included evaluation of serum total protein, albumin, total bilirubin, alkaline phosphatase (ALP), alanine transaminase (ALT), and aspartate transaminase (AST) as indicators of liver function. There were no significant differences between controls and filling station attendants regarding serum total protein, albumin, total bilirubin, and AST. Statistically significantly lower mean serum ALP and ALT (18 and 35% lower, respectively, than controls) were noted in the filling station attendants. The study is limited by small numbers of subjects, lack of measured benzene levels, and lack of accounting for exposure to other potential toxicants.

Hematological Effects. Uzma et al. (2008) evaluated peripheral blood from 154 healthy benzene-exposed male filling station attendants (94 with <10 years of exposure and 60 with >10 years of exposure); a control group of 33 healthy subjects matched for demographics was included. Analysis included total white blood cell and differential leukocyte counts. Among the controls, lymphocytes accounted for 37.92% ±1.89 (standard deviation [SD]) of total white blood cells; decreased percentages of lymphocytes were noted for filling station attendants (32.3% ±1.65 for attendants with <10 years of exposure, p=0.056; 29.3±1.76 for attendants with >10 years of exposure, p=0.03). Exposure duration-related significantly decreased absolute numbers of lymphocytes were noted as well. The study is limited by small numbers of subjects, lack of measured benzene levels, and lack of accounting for exposure to other potential toxicants.

Li et al. (2009) evaluated selected hematological parameters in peripheral blood from 68 healthy benzene-exposed workers whose workplace air benzene levels measured 37.8 mg/m^3^ (11.7 ppm) and 27 healthy subjects without documented occupational exposure to benzene (control subjects). There were no statistically significant differences between the groups regarding red blood cell or white blood cell counts or hemoglobin or platelet levels. The study report included findings of significantly decreased white blood cell and red blood cell counts, hemoglobin, and platelets within groups of workers from a variety of workplaces who had been diagnosed with mild (n=23), medium (n=12), or severe (n=35) chronic benzene poisoning (diagnosis based on white blood cell counts). However, benzene exposure levels were not presented for the groups with diagnosed chronic benzene poisoning.

Schnatter et al. (2010) evaluated 12 peripheral blood indices within a group of 928 workers in five factories in the area of Shanghai, China, who were exposed to estimated weekly benzene levels ranging from 0.07 to 872 mg/m^3^ (0.02–270 ppm); the median benzene air concentration was 7.4 mg/m^3^ (2.3 ppm). Estimates of benzene levels were based on individual monitoring. At exposure levels >10 ppm, effects on peripheral blood were noted for red cell indices such as anemia and macrocytosis. Decreases in neutrophils and mean platelet volume were noted at benzene air concentrations in the range of 7.8–8.2 ppm.

Swaen et al. (2010) evaluated hematological parameters in 8,532 blood samples from Dow employees with low benzene exposure (8-hour time-weighted average [TWA] mean benzene concentrations in the range of 0.06–1.24 ppm and 12,173 blood samples from employees with no exposure to benzene. There was no indication of benzene-induced effects on any hematological parameter. Upon stratification of the benzene-exposed population into subgroups according to benzene level (<0.5, 0.5–1, and >1 ppm), there were no significant differences in hematological parameters among the three groups or between benzene-exposed groups and unexposed controls.

##### 3.2.1.3 Immunological and Lymphoreticular Effects

Kirkeleit et al. (2006) investigated the effects of benzene exposure on selected immunological end points among 10 workers exposed to benzene while maintaining cargo tanks containing crude oil residues on a crude oil vessel; a group of 9 catering workers on the same vessel served as referents. Individual benzene exposure was measured daily during a study period that spanned three consecutive 12-hour work shifts. Blood and urine samples were collected at baseline (prior to the first work shift), at the end of the third work shift, and prior to the work shift on the day following the three consecutive work shifts for evaluation of blood and urine benzene levels; blood levels of lymphocytes (total lymphocytes, lymphocytes in subpopulations CD3, CD4, CD8, CD19, CD56, and CD4/CD8 ratio) and complement factors C3 and C4 were determined as well as serum levels of immunoglobulins IgA, IgE, IgG, and IgM. The mean measured benzene air concentration was 0.15 ppm (range 0.01–0.62 ppm) for the tank workers. Mean measured post-shift blood benzene levels were 12.3 nmol/L (range 2–38 nmol/L) for the tank workers and 0.7 nmol/L (0.5–1.0 nmol/L) for the referents. Mean measured post-shift urinary benzene levels were 27.0 nmol/L (range 3.0–333 nmol/L) for the tank workers and 0.7 nmol/L (range 0.5–2.0 nmol/L) for the referents. At baseline, mean serum IgM was significantly lower in the tank workers than in the referents. Baseline to post-shift IgM declined by 4.9% among the tank workers, but increased by 5.1% among the referents. Baseline to post-shift IgA declined by 5.1% among the tank workers, but increased by 0.6% among the referent. The declines in IgM and IgA among the tank workers were statistically significant. The tank workers also exhibited significantly decreased blood CD4 T cell levels from baseline to post-shift. Mean serum IgE among the tank workers was 30% that of controls (36.7 kU/L; 95% confidence interval [CI] 0, 76.2 compared to 123 kU/L; 95% CI 2.75, 243); however, based on wide individual variation in serum IgE, the mean serum IgE values were not statistically significantly different (p=0.15). There were no statistically significant benzene exposure-related effects on IgG; blood levels of total lymphocytes or lymphocyte subpopulations CD3, CD8, CD19, CD56, or CD4/CD8 ratio; or complement factors C3 or C4. The study authors stated that serum levels of IgG and IgE were not significantly correlated with any measure of exposure.

Lan et al. (2005) measured selected hematological parameters in peripheral blood from 49 benzene-exposed workers in shoe-manufacturing factories (measured workplace air level of 15.8±17.9 ppm [mean±SD]) and 45 unexposed controls from clothing-manufacturing factories in the same vicinity. The benzene-exposed workers exhibited significant decreases in white blood cell count and numbers of granulocytes (18–23% lower than control values) and borderline significantly (p=0.054) decreased lymphocyte count (10% lower than controls). Lymphocyte subset analysis revealed significant decreases in numbers of B cells and CD4+-T cells and CD4+/CD8+ ratio. These findings are in concordance with the results of Lan et al. (2004a, 2004b) summarized in the current Toxicological Profile for Benzene.

Brandão et al. (2005) compared lymphocyte subpopulation between 24 subjects with diagnosed chronic benzene poisoning and 24 subjects with other diagnosed occupational diseases in Brazil. The group of chronic benzene poisoning subjects exhibited significantly greater proportion of T-cytotoxic cells (TCD8) controls and significantly lower proportion of T-helper memory cells (CD4CD45RO) than controls. A meaningful association between exposure to benzene and altered lymphocyte subpopulations is precluded by small numbers of subjects, absence of benzene exposure data, and lack of comparative data for healthy controls.

Li et al. (2009) measured levels of T-cell receptor excision DNA circles in peripheral blood mononuclear cells (an indicator of recent thymic output function) from 68 benzene-exposed workers (measured benzene concentration in the workplace air averaged 37.8 mg/m^3^ [11.7 ppm]). A control group consisted of 27 healthy subjects without documented benzene exposure. Levels of T-cell receptor excision DNA circles in the benzene-exposed group were significantly lower than those of controls, indicating that benzene may have impaired thymic output function and T-cell immune function.

##### 3.2.1.4 Neurological Effects

Lee et al. (2007) reported a significant trend (p<0.05) for increased prevalence of acquired dyschromatopsia (partial color blindness) in the left eye (but not the right eye) with increasing benzene exposure (mean exposure levels ranging from 0.27 to 2.43 ppm-years) among 736 workers employed in a petrochemical distillation factory compared with 172 non-exposed office workers. Prevalence of dyschromatopsia was significantly correlated with age and duration of work. The results indicate that chronic low-level exposure to benzene may lead to acquired dyschromatopsia, which may be a relatively sensitive indicator of neurological damage.

##### 3.2.1.5 Reproductive Effects

Katukam et al. (2012) collected semen samples from 160 workers with occupational exposure to benzene and 200 unexposed age- and sex-matched control subjects and evaluated semen volume and sperm quality. The benzene-exposed workers were grouped according to duration of exposure (group 1, 0–5 years of exposure, n=52; group 2, 5–10 years of exposure, n=73; group 3, 10–15 years of exposure, n=35). There were no statistically significant differences between controls and benzene-exposed groups regarding macroscopic semen characteristics (e.g., volume, appearance, pH, viscosity, liquefaction). However, the benzene-exposed workers exhibited exposure duration-related statistically significant effects that included decreases in total sperm count and sperm motility, increased percentages of morphologically abnormal sperm, and increased sperm comet tail length (a measure of DNA integrity). The study report did not include evaluation of reproductive success.

##### 3.2.1.6 Developmental Effects

In a population-based case-control study in Texas, Lupo et al. (2011) evaluated possible associations between maternal exposure to ambient air levels of selected pollutants (including benzene) and risk of neural tube defects (spina bifida, anencephaly). Ambient air levels for each pollutant were obtained from the U.S. Environmental Protection Agency (EPA) 1999 National-Scale Air Toxics Assessment (EPA 2011) that employed the Assessment System for Population Exposure Nationwide (ASPEN) model (EPA 2015). For benzene, estimated air levels ranged from 0.12 to 7.44 µg/m^3^ (0.037–2.28 ppb) and were grouped into ranges described as low (0.12–0.45 µg/m^3^; referent), medium-low (>0.45–0.98 µg/m^3^), medium (>0.98–1.52 µg/m^3^), medium-high (>1.52–2.86 µg/m^3^), and high (>2.86–7.44 µg/m^3^). Compared to the referent group, significantly increased risk of spina bifida was associated with the medium-low (odds ratio [OR] 1.77; 95% CI 1.04, 3.00), medium (OR 1.90; 95% CI 1.11, 3.24), and high (OR 2.30; 95% CI 1.22, 4.33) exposure groups. The medium-high exposure group exhibited an OR of 1.40 (95% CI 0.82, 2.38), indicating the lack of a monotonic exposure-response relationship. There was no significant association between estimated benzene exposure level and risk of anencephaly. Zahran et al. (2012) reported significantly increased risk of low birth weight with increasing benzene level in ambient air in a study of resident births in the United States. Ramakrishnan et al. (2013) found no significant association between estimated ambient air benzene levels and risk of oral cleft among offspring of mothers who delivered in Texas between 1999 and 2008. However, these population-based studies are of limited usefulness for hazard identification because they did not include measurements of individual benzene exposure; ambient air benzene levels were census-tract estimates of annual air levels using models developed for the U.S. EPA National Air Toxic Assessment (EPA 2013a, 2015).

##### 3.2.1.7 Cancer

As summarized in the 2007 ATSDR Toxicological Profile for Benzene (Agency for Toxic Substances and Disease Registry 2007), the International Agency for Research on Cancer (IARC 1982) determined that benzene is carcinogenic to humans based on sufficient evidence including a demonstrated relationship between benzene exposure and development of acute myelogenous leukemia (AML; also known as acute myeloid leukemia, acute myeloblastic leukemia, acute granulocytic leukemia, and acute nonlymphocytic leukemia). At that time, IARC (1982) determined that there was limited evidence that benzene was carcinogenic to laboratory animals. The evidence for benzene-induced carcinogenicity in humans was strengthened by results from subsequent epidemiological studies in which exposure to benzene was associated with leukemia (IARC 1987).

More recently, IARC convened a Working Group to reassess the carcinogenicity of benzene by evaluating numerous cohort and case-control studies of leukemia or its subtypes, non-Hodgkin’s lymphoma (NHL), multiple myeloma, and other tumor types in adults and children, as well as several meta-analyses for selected tumor sites; results were published in the IARC Monograph Volume 100F (IARC 2012). Based on extensive evaluation of available occupational cohort studies and case-control studies, the Working Group reaffirmed its earlier designation that benzene is carcinogenic to humans (Group 1) based on sufficient evidence that benzene causes AML in humans. The Working Group considered the evidence for associations between exposure to benzene and acute lymphocytic leukemia (ALL), chronic lymphocytic leukemia (CLL), multiple myeloma, and NHL sufficient to consider the associations positive, although in most cases, observed associations did not reach the level of statistical significance. Review of available animal studies resulted in the determination that there is sufficient evidence for the carcinogenicity of benzene in experimental animals.

Individual epidemiological studies published subsequent to the time period encompassed by the IARC (2012) publication include a study in which NHL incidence was significantly higher in census tracts that were closer, on average, to benzene release sites (Bulka et al. 2013), a population-based prospective occupational cohort study in which risk of NHL was significantly associated with women ever exposed to benzene (Bassig et al. 2014), a hospital-based case-control study in which no significant association was found between exposure to benzene (as determined from self-reported occupational history) and risk of NHL or lymphoproliferative syndrome (Orsi et al. 2010), a hospital-based case-control study in which no significant association was found between exposure to benzene (as determined from self-reported occupational or nonoccupational exposure) and risk of chronic myelomonocytic leukemia (Gross et al. 2012), and a nested case-control study of petroleum workers in which no convincing association was found between risk of chronic myeloid leukemia or myeloproliferative disease and relatively low level benzene exposure (average 0.17 ppm for myeloproliferative disease cases, 0.3 ppm for chronic myeloid leukemia cases) (Glass et al. 2014).

Reports from several recent meta-analyses were not available to the Working Group. Vlaanderen et al. (2011) evaluated possible associations between occupational exposure to benzene and risk of lymphoma subtypes (Hodgkin’s lymphoma, NHL, multiple myeloma, ALL, and CLL). Results from all peer-reviewed occupational cohort studies (identified from PubMed searching) that reported results for any of the lymphoma subtypes were included in the meta-analysis. The impact of individual study quality variation on risk was evaluated using stratification by strength of the reported association between benzene exposure and acute myelogenic leukemia (commonly been associated with benzene exposure), by year of start of follow-up (prior to 1970 versus during or after 1970), and by quality of benzene exposure assessment. The meta-relative risks (mRRs) for multiple myeloma, ALL, and CLL increased with increasing quality of reported ALL association, more recent start of follow-up, and increasing quality of benzene exposure assessment. The mRRs for NHL increased in a similar, but less pronounced, manner. There was no evidence of an association between occupational exposure to benzene and risk of Hodgkin’s lymphoma. Vlaanderen et al. (2012) similarly designed a meta-analysis of possible associations between occupational exposure to benzene and risk of chronic myeloid leukemia. The overall mRR was nonsignificantly elevated; mRRs increased with increasing study quality for all dimensions with a significant elevation for studies with start of follow-up after 1970. The results of Vlaanderen et al. (2011, 2012) provide support for possible associations between occupational exposure to benzene and risk of selected lymphoma subtypes (multiple myeloma, ALL, and CLL, and NHL) and risk of chronic myeloid leukemia.

Schnatter et al. (2012) updated three nested case-control studies on cohorts of petroleum distribution workers in Canada (Schnatter et al. 1996), the United Kingdom (Rushton and Romaniuk 1997), and Australia (Glass et al. 2003), and pooled the cases and controls in a meta-analysis. The Canadian study included 31 case subjects (gender ratio not specified) with lymphohematopoietic cancers (including 16 cases of leukemia) who died within the time period of 1964–1983, each paired with 4 male age-matched controls; an update was performed for the years 1984–1994 and included 29 additional cases. The United Kingdom study included 90 case subjects (men) with leukemia who died prior to 1993, each paired with 4 male age-matched controls; an update was performed through 2005 and included 103 additional cases. The Australian study included 79 case subjects (men) with lymphohematopoietic cancers identified between 1981 and 1999, each matched to 5 controls; an update was performed through 2006 and included 38 additional cases. The pooled study thus included 370 case subjects and 1,587 controls. There were 168 cases of leukemia (60 cases of acute myeloid leukemia, 28 cases of chronic myeloid leukemia, and 80 cases of CLL), 59 cases of other myeloid disorders (29 cases of myelodysplastic syndrome and 30 cases of myeloproliferative disease), and 143 cases of “other diagnoses” (NHL, multiple myeloma, and diagnoses with too few cases for statistical analysis). After controlling for age, sex, and time period, a significant dose-response association was observed between cumulative benzene exposure and myelodysplastic syndrome (OR 4.33; 95% CI 1.31, 14.3; highest versus lowest tertile, >2.93 versus ≤0.348 ppm-years). In the pooled analysis, no significant association was observed between measures of benzene exposure and risk of acute or chronic myeloid leukemia, CLL, or myeloproliferative disease.

Two other meta-analyses evaluated possible associations between exposure to benzene and risk of NHL (Alexander and Wagner 2010; Kane and Newton 2010). The meta-analysis of Alexander and Wagner (2010) included 8 cohort studies with quantitative benzene exposure estimates, industrial hygiene records, job-exposure matrices, or benzene-specific work history information; and 14 case-control studies for which benzene exposure had been analyzed as an independent variable. No significant associations were observed between benzene exposure and risk of NHL for measures of any measure of benzene exposure (i.e., any benzene exposure, highest level of benzene exposure, and meta-analysis of 5 studies that reported results for ≥60 ppm-years). The meta-analysis of Kane and Newton (2010) included 6 cohort studies, 16 case-control studies, and 2 studies of other designs (all studies were published in peer-reviewed journals and reported relative risks and CIs of NHL associated with benzene exposure or provided sufficient information from which to compute relative risk with CI). Twenty-two of the studies found no association between NHL and ever exposed to benzene compared to never exposed. Random-effects meta-analysis resulted in a pooled risk estimate of 1.11 (95% CI 0.94, 1.30). Among six studies for which benzene exposure was estimated from historical measurements, there were no statistically significant associations between benzene exposure and risk of NHL relative to increasing cumulative, average, peak, or duration of benzene exposure.

#### 3.2.2 Oral Exposure

##### 3.2.2.1 Death

In a study of male Sprague-Dawley rats (6/group) administered benzene (in distilled water vehicle) by gavage once per day for up to 14 days at 0 (controls), 0.5 mL/kg body weight (440 mg/kg), or 1.0 mL/kg (880 mg/kg), all high-dose rats died prior to treatment day 10 (Singh and Bansode 2011).

##### 3.2.2.2 Systemic Effects

Hematological Effects. The National Toxicology Program (NTP 2007) administered benzene to groups of male and female haploinsufficient p16Ink4a/p19Arf mice (15/sex/group) by gavage (in corn oil) once/day, 5 days/week for 27 weeks at 0, 25, 50, 100, or 200 mg benzene/kg/day. All benzene-treated groups of male mice and the 100 and 200 mg/kg/day groups of female mice exhibited significantly decreased numbers of erythrocytes, leukocytes, and lymphocytes, and significantly decreased mean cell volume at weeks 13 and 27 of treatment; the 50 mg/kg/day group of female mice also exhibited significantly decreased numbers of leukocytes and lymphocytes at weeks 13 and 27. Significantly decreased hematocrit and hemoglobin were observed at weeks 13 and 27 at doses ≥50 mg/kg/day in males and in the high-dose females. At week 27 (but not week 13), significantly decreased numbers of segmented neutrophils were observed in male mice dosed at ≥50 mg/kg/day. Male mice exhibited significantly increased incidence of hemosiderin pigmentation in bone marrow at all benzene dose levels, significantly increased incidence of bone marrow atrophy and lymphoid follicle atrophy in the spleen at the two highest dose levels, and significantly increased incidence of hematopoietic cell proliferation in the spleen at the highest dose. There were no indications of treatment-related effects on spleen or bone marrow of female mice.

Body Weight Effects. Treatment-related effects on body weight were reported in a study of male Sprague-Dawley rats (6/group) administered benzene (in distilled water vehicle) by gavage once per day for up to 14 days at 0 (controls), 0.5 mL/kg body weight (440 mg/kg), or 1.0 mL/kg (880 mg/kg) (Singh and Bansode 2011). Mean final body weight of the low-dose group was not significantly different from that of controls; however, the high-dose group lost 5% of its initial mean body weight (final mean body weight 22% less than that of controls) and all high-dose rats had died prior to treatment day 10. Significantly decreased food and water intakes were noted in the high-dose group during treatment days 4–9 and in the mid-dose group at most time points from treatment day 8 onward.

NTP (2007) administered benzene to groups of male and female haploinsufficient p16^Ink4a^/p19^Arf^ mice (15/sex/group) by gavage (in corn oil) once/day, 5 days/week for 27 weeks at 0, 25, 50, 100, or 200 mg benzene/kg/day. Male mice exhibited dose-related lower mean body weight than controls, which was most notable for treatment weeks 14–27, at which time body weights of the 25, 50, 100, and 200 mg/kg dose groups were 9, 12, 22, and 24%, respectively, less than that of controls. Mean body weight of benzene-treated female mice were generally within 2% that of controls throughout the treatment period, with the exception of the high-dose females that exhibited 7% lower mean body weight for the period of 14–27 weeks.

##### 3.2.2.3 Immunological and Lymphoreticular Effects

NTP (2007) administered benzene to groups of male and female haploinsufficient p16^Ink4a^/p19^Arf^ mice (15/sex/group) by gavage (in corn oil) once/day, 5 days/week for 27 weeks at 0, 25, 50, 100, or 200 mg benzene/kg/day. Male mice exhibited dose-related increased incidences of atrophy of thymus and lymph nodes (mandibular, mediastinal, and mesenteric) that reached the level of statistical significance in the two highest dose groups. Female mice exhibited dose-related increased incidences of mesenteric lymph node atrophy that reached the level of statistical significance in the two highest dose groups.

##### 3.2.2.5 Reproductive Effects

Treatment-related effects on selected reproductive end points were reported in a study of male Sprague-Dawley rats (6/group) administered benzene (in distilled water vehicle) by gavage once per day for up to 14 days at 0 (controls), 0.5 mL/kg body weight (440 mg/kg), or 1.0 mL/kg (880 mg/kg) (Singh and Bansode 2011). The high-dose group was necropsied at day 10 due to 100% mortality after 9 treatment days. The low-dose group was necropsied on day 14. Both groups of benzene-treated rats exhibited significantly decreased mean seminal vesicle weight (approximately 40% less than that of controls). Histopathological examination of testes revealed degenerative changes in benzene-treated groups characterized by giant cell formation, cytoplasmic vacuolization, pycnosis, chromatolysis, and desquamation and dissolution of germ cells in tubular lumen. The low-dose group exhibited significantly decreased numbers of non-pachytene and pachytene spermatocytes (48 and 88%, respectively, less than that of controls) and round and elongated spermatids (93 and 98%, respectively, less than that of controls), and significantly decreased diameters of seminiferous tubules and Leydig cell nuclei (23% less than those of controls). Gross and histopathological evaluations of high-dose rats revealed effects on reproductive end points similar to those observed in low-dose rats, but of greater magnitude; the high-dose group also exhibited significantly decreased mean number of type a spermatogonia. There were no statistically significant treatment-related effects on weights of testis, epididymis, or ventral prostate among low- or high-dose groups.

##### 3.2.2.7 Cancer

NTP (2007) administered benzene to groups of male and female haploinsufficient p16^Ink4a^/p19^Arf^ mice (15/sex/group) by gavage (in corn oil) once/day, 5 days/week for 27 weeks at 0, 25, 50, 100, or 200 mg benzene/kg/day. High-dose male mice exhibited significantly increased incidence of malignant lymphoma (5/15 high-dose males compared to 0/15 for each of the other groups, including controls). Multiple organs including the spleen, thymus, lymph node, kidney, lung, and/or brain were infiltrated with neoplastic cells. There were no signs of treatment-related increased incidences of any cancer in the female mice.

#### 3.2.3 Dermal Exposure

##### 3.2.3.2 Systemic Effects

Dermal Effects. Application-site dermal irritation was observed in male hairless rats receiving a single occlusive dermal application of benzene at 230 µL for 1 hour or repeated unocclusive applications at 15µL every 2 hours for 8 hours/day during 4 days (Chatterjee et al. 2005). Evidence of dermal irritation included visual signs of erythema, decreased skin moisture content, increased transepidermal water loss, increased expression of tumor necrosis factor-α at the application site, and increased interleukin-1α in the blood. The repeated unoccluded application scenario was more irritative than the single occluded application.

### 3.3 GENOTOXICITY

Several groups of investigators have reported significant associations between occupational exposure to benzene and increased rates of chromosomal aberrations (e.g., breaks, deletions, translocations, aneuploidy) for a number of chromosomes in peripheral blood lymphocytes (Ji et al. 2012; Zhang et al. 2005, 2007, 2011a, 2012) or sperm (Ji et al. 2012; Kim et al. 2010; Marchetti et al. 2012; Schmid et al. 2006; Xing et al. 2010). For example, using the FISH (fluorescence in situ hybridization) assay, Zhang et al. (2007) observed increased aneuploidy (significant increases in monosomy in chromosomes 2, 4, 6, 11, 12, and 13; trisomy in chromosomes 2, 4, 6, 11, and 18; tetrasomy in chromosomes 2, 4, 6, 11, 12, 13, and 18) and significantly increased frequency of long-arm deletions in chromosome 6 among a group of 22 workers exposed to benzene at levels >31 ppm compared to a group of 44 unexposed controls. Zhang et al. (2007) also observed translocations between chromosomes 14 and 18 among 4/22 of the workers exposed at concentrations >31 ppm and no such translocations among 21 workers exposed at concentrations ≤31 ppm or among 44 unexposed controls. However, DNA from the workers was not of suitable quality to quantify the results. In a subsequent study that included 31 unexposed controls and 37 highly-exposed workers (mean benzene concentration of 22.6 ppm, median 13.8 ppm) and employed real-time quantitative polymerase chain reaction (PCR) to quantify translocations, the benzene-exposed group exhibited a lower frequency of translocations between chromosomes 14 and 18 than that of the unexposed group (McHale et al. 2008). The study authors stated that the apparent discrepancy between the finding of decreased frequency of translocations between chromosomes 14 and 18 in the benzene-exposed workers and the report of increased frequency of this translocation in benzene-exposed workers of a previous study (Zhang et al. 2007) might be explained by different target cell populations and differential sensitivities of the two assays.

Tunsaringkarn et al. (2011) evaluated the frequency of sister chromatid exchange (SCE) in peripheral blood lymphocytes from 33 gasoline station workers and 30 office workers and students (controls). The frequency of SCE was significantly higher among the gasoline station workers (13.47±0.26 SCEs/cell [mean±standard error]) than controls (8.52±0.40 SCEs/cell). Benzene exposure estimates were not included in the study report, although urinary trans,trans-muconic acid (a minor metabolite of benzene) levels were significantly higher in the gasoline station workers than the controls.

Zhang et al. (2014) evaluated the frequency of micronuclei in peripheral blood lymphocytes from 385 benzene-exposed shoe factory workers and 197 unexposed controls. The benzene-exposed workers were evaluated as a total group and also grouped according to duration of exposure (≤5.02, >19.90, >31.81, and >59.00 mg/m^3^-year) and according to exposure level (>3.25, <6.00, and ≥6.00 mg/m^3^). The benzene-exposed workers exhibited both concentration- and duration-related significantly increased frequency of micronuclei compared to controls.

Kim et al. (2010) evaluated the frequency of micronuclei in peripheral blood lymphocytes from 30 workers exposed to benzene in the petroleum refining process (mean exposure level 0.51 ppm; cumulative exposure level <5 ppm-years) and 10 office workers not associated with the petroleum refinery process. The mean frequencies of micronuclei and centromere-negative micronuclei were significantly greater within the group of benzene-exposed workers compared to frequencies within the group of office workers. There was no significant difference between groups regarding frequency of centromere-positive micronuclei.

Katukam et al. (2012) collected semen samples from 160 workers with occupational exposure to benzene and 200 unexposed age- and sex matched control subjects and evaluated sperm quality. The benzene-exposed workers were grouped according to duration of exposure (group 1, 0–5 years of exposure, n=52; group 2, 5–10 years of exposure, n=73; group 3, 10–15 years of exposure, n=35). Exposure duration-related significantly increased sperm comet tail length (a measure of DNA damage) was observed in the benzene-exposed workers compared to controls. Mean sperm tail length (±SD) were 1.89±0.28, 4.98±2.44, 5.86±0.2.46, and 6.13±0.2.11 µm, for controls, group 1, group 2, and group 3, respectively).

Bassig et al. (2014) evaluated telomere length in leukocytes from peripheral blood samples collected from 43 benzene-exposed workers and 43 matched unexposed controls. Mean telomere length was 9% longer (p=0.03) among 22 workers with benzene exposure levels >31 ppm (n=22) than the unexposed controls. Significantly increased frequency of micronuclei was observed in polychromatic erythrocytes from bone marrow of male CD-1 mice exposed to benzene vapor for 6 hours/day for 8 of 15 days at 50 ppm, a 2.4-fold increase over the frequency of micronuclei in air-only control mice (Wetmore et al. 2008). Similar exposure during 8 consecutive days resulted in a nearly 5-fold increased frequency of micronuclei (Bird et al. 2010). Lau et al. (2009) reported significantly increased percentages of micronuclei in bone marrow cells of adult mice following single intraperitoneal injection of benzene at 400 mg/kg. Following intraperitoneal injections of benzene to timed-pregnant female mice at 400 mg/kg/day during gestation days 7–15 significantly increased percentages of micronuclei were noted in fetal liver and postnatal day 9 bone marrow cells.

Billet et al. (2010) evaluated the mutational pattern induced by benzene on the TP53 gene in human type II-like alveolar epithelial A549 cells in vitro. A total of 17 mutations were linked to benzene exposure: 3 one- or two-base deletions and 14 single nucleotide substitutions. Benzene induced micronuclei, chromosomal aberrations, and DNA damage in Chinese hamster ovary cells (Pandey et al. 2009a, 2009b).

### 3.4 TOXICOKINETICS

#### 3.4.1 Absorption

##### 3.4.1.1 Inhalation Exposure

The observation that levels of the benzene urinary metabolite trans,trans-muconic acid in a group of ceramic factory workers exposed to benzene were higher than those of nonexposed control workers (Ibrahim et al. 2014) indicates that benzene was absorbed via inhalation and/or dermal routes.

##### 3.4.1.3 Dermal Exposure

Modjtahedi and Maibach (2008) reported absorption of benzene through forearm skin and palm of volunteers. Absorption through the forearm skin and palm averaged 0.7 and 0.13%, respectively, of the applied dose, based on recovery in the urine. Fent et al. (2014) reported increased benzene levels in the breath of firefighters exposed to benzene and other substances during controlled structure burns, indication that some degree of dermal absorption of benzene had occurred because the subjects wore their protective breathing systems during the burns.

##### 3.4.1.4 Other Routes of Exposure

Adami et al. (2006) applied benzene to human skin in vitro and recovered 0.43% of the applied dose in the receptor fluid; a permeability coefficient of 0.000438 cm/hour was determined. Hui et al. (2009a, 2009b) observed dose-related increased absorption of benzene through human skin in vitro and reported that occlusion increased the extent of absorption.

#### 3.4.5 Physiologically Based Pharmacokinetic (PBPK)/Pharmacodynamic (PD) Models

##### 3.4.5.1 Summary of PBPK Models

Three studies have expanded or enhanced the Cole et al. (2001) mouse PBPK model (Knutsen et al. 2013a, 2013b; Manning et al. 2010; Yokely et al. 2006). Yokely et al. (2006) estimated parameter values for humans, including human population distributions for several metabolism parameters. Knutsen et al. (2013a, 2013b) expanded the Yokely et al. (2006) human model to include two additional compartments representing bone marrow and urinary bladder. This enabled dosimetry predictions for benzene and metabolites in bone marrow and provided a compartment for simulating background levels (e.g., pre-exposure) of benzene metabolite conjugates in urine. Manning et al. (2010) extended the Cole et al. (2001) mouse model to include a kidney compartment and subdivided the liver compartment into three zones to represent heterogeneous distribution of enzymes that participate in the production of benzene metabolites.

Yokely et al. (2006). Yokely et al. (2006) estimated human population distributions of metabolism parameters for the Cole et al. (2001) model (described in Agency for Toxic Substances and Disease Registry 2007). Parameters evaluated included the specific activity of CYP2E1 in liver (V2E1), maximum rates of conjugation of phenol (VPH1, VPH2) and hydroquinone (VHQ), and first-order clearances for formation of phenylmercapturic acid (k3) and muconic acid (k4) from benzene oxide. Data from in vitro studies of human liver tissue were used to establish prior log-normal distributions for V2E1, VPH1, VPH2, and VHQ. Parameters k3 and k4 were assigned log-normal prior distributions with means equal to the mouse model values and SDs of 0.1 and 2, respectively. Posterior distributions were computed from Markov Chain Monte Carlo (MCMC) simulations with calibration data from human subjects. These data included a clinical study in which 3 subjects were exposed to 1.7 or 10 ppm benzene for 4 hours and benzene in blood and exhaled air were measured (Pekari et al. 1992), and an occupational study in which benzene metabolites in urine were monitored in 35 workers who were exposed to 25 ppm benzene during their work shifts (Rothman et al. 1998; Waidyanatha et al. 2004). The population model predicted the observed variability in blood benzene and exhaled benzene and urinary levels of muconic acid, phenylmercapturic acid, phenol, and hydroquinone; however, it under-predicted urinary catechol and benzenetriol levels.

Manning et al. (2010). Manning et al. (2010) developed a PBPK model of benzene and its major metabolites benzene oxide, phenol, and hydroquinone. The model is an extension of the Cole et al. (2001) model (described in Agency for Toxic Substances and Disease Registry 2007), with the addition of a kidney compartment, and expansion of the liver compartment to include three subcompartments. The three liver compartments were included in the model to simulate the heterogeneous distribution of CYP2E1 and sulfotransferases. CYP2E1 is more strongly expressed in the pericentral region of the liver and sulfotransferases are more strongly expressed in the periportal region of the liver (Ingelman-Sundberg et al.1988; Tsutsumi et al. 1989). This heterogeneous, or zonal, distribution of enzymes is thought to give rise to different metabolic patterns following an external dose of benzene or phenol (Hoffman et al. 1999; Koop e al. 1989). Following an external dose of phenol, sulfotransferases in the periportal region of the liver convert a large fraction of the absorbed dose to sulfate esters before it can be delivered to the pericentral region of the liver where it can be metabolized to benzene oxide through the CYP2E1 pathway and to downstream metabolites, including hydroquinone. Following an external dose of benzene, phenol is formed in the pericentral region of the liver and, as a result, a larger fraction of the benzene dose is converted hydroquinone.

The three-compartment liver model has flow-limited transfer of chemical from blood to liver compartment 1, representing the periportal region, through an intermediate compartment 2, to compartment 3, representing the pericentral region. Each compartment is assumed to comprise one-third of the total volume of the liver. Hepatic sulfotransferase and glucuronlytransferase activity are assigned to compartment 1, whereas CYP2E1, epoxide hydrolase, and GST activities are assigned to compartment 3. Non-enzymatic conversion of benzene oxide to phenol is assumed to occur in all three compartments. Sulfate and glucuronic acid conjugates of phenol and hydroquinone are formed in liver compartment 1. Metabolites formed in compartment 3 include the CYP2E1 metabolites benzene oxide (from phenol), hydroquinone and catechol (from phenol), and benzenetriol (from hydroquinone), the epoxide hydrolase metabolite of benzene oxide (muconic acid), and the GST metabolite of benzene oxide (phenyl-mercapturic acid). The kidney compartment is assigned 10% of the CYP2E1 activity relative to the liver. Formation of phenylmercapturic acid is assumed to occur in blood, kidney, fat, slowly perfused tissue, and rapidly perfused tissues.

Tissue/blood partition coefficients for benzene metabolites, phenol and hydroquinone, were estimated from physical-chemical properties (Poulin and Krishnan, 1995). Phenol and hydroquinone were assumed to bind in all tissues. Binding was represented in the model with first order clearance terms which were optimized. Information regarding tissue/blood partition coefficients for benzene was taken from the literature (Medinsky et al. 1989). The partition coefficients for benzene were used for benzene oxide. Parameters governing CYP2E1 and conjugation rates (Km, Vmax) were scaled to the whole liver from estimates made in in vitro studies (Lovern et al. 1999; Seaton et al. 1995). First-order clearances for GST-mediated formation of phenylmercapturic acid and epoxide hydrolase-mediated formation of muconic acid were optimized.

Data used in optimizing the model were derived from benzene oral dosing studies (Henderson et al. 1989; Kenyon et al. 1995; Mathews et al. 1998; Sabourin et al. 1987) and inhalation studies (Sabourin et al. 1988) conducted in mice. The introduction of three liver compartments to account for zonal distribution of metabolism improved some aspects of performance of the model at predicting dose-dependent metabolism of benzene. For example, it improved agreement between observed and predicted benzene concentrations in liver and phenol concentrations in blood following inhalation of benzene, and predictions of formation of phenol and hydroquinone conjugates following oral dosing with benzene.

Knutsen et al. (2013a, 2013b). Knutsen et al. (2013a, 2013b) expanded the Yokely et al. (2006) human model to include two additional compartments representing bone marrow and urinary bladder. Saturable metabolism was assumed for the formation of benzene oxide from benzene, hydroquinone and catechol from phenol, benzenetriol from catechol and hydroquinone, and conjugates. Bone marrow is assumed to oxidize to benzene oxide at approximately 4% of the hepatic maximal rate. Maximal rates for all other saturable conversions in liver and bone marrow (per mg tissue protein) were assumed to be proportional to tissue masses. First-order metabolic clearance was assumed for formation of muconic acid and phenylmercapturic acid from benzene oxide and phenol from benzene oxide, with first-order clearance rates identical in liver and bone marrow. The bladder compartment receives conjugated metabolites resulting from exposure to benzene and was assigned values for background levels of metabolites expected in the absence of exposure to benzene. Background levels of urinary metabolites were assigned values based on measurements made in humans who were not exposed to benzene (Waidyanatha et al. 2004).

Metabolism parameters for CYP2E1 were assigned initial values from quantitative studies of human liver CYP2E1 (Lipscomb et al. 2003a, 2003b) and all metabolism parameters were calibrated to achieve agreement with measurements of urinary benzene metabolites in workers exposed to benzene during the work shift (Waidyanatha et al. 2004). The calibrated model was validated by comparing observed levels of benzene in blood and exhaled air in three subjects who inhaled benzene (1.9 and 9.4 ppm) for 4 hours (Pekari et al. 1992) and observed and predicted urinary metabolite levels measured in workers exposed to benzene (Kim et al. 2006).

In comparison to the Yokely et al. (2006) human model, calibration of the Knutsen et al. (2013a, 2013b) model resulted in lower values for the maximal rate of metabolism of phenol and first-order clearance of benzene to benzene oxide and higher values for first-order clearance of phenol to catechol and hydroquinone to benzenetriol. Good agreement was achieved between observed and predicted levels of benzene in blood and exhaled air, and benzene metabolites in urine (Kim et al. 2006; Pekari et al. 1992). The model was used to compare predicted blood and bone marrow metabolite exposures resulting from an 8-hour exposure to air concentrations of benzene ranging from 5 to 100 ppm. The total metabolites formed (24-hour area under the curve [AUC]) were higher in blood compared to bone marrow. Both compartments exhibited saturation kinetics, with saturation in bone marrow predicted at lower exposures.

### 3.5 MECHANISMS OF ACTION

#### 3.5.2 Mechanisms of Toxicity

As discussed in the ATSDR Toxicological Profile for Benzene (Agency for Toxic Substances and Disease Registry 2007), benzene hematotoxic and carcinogenic effects are dependent upon benzene metabolism; reactive metabolites produced in liver and bone marrow can lead to production of reactive oxygen species and damage to tubulin, histone proteins, topoisomerase II, other DNA associated proteins, and DNA itself (clastogenic effects such as strand breakage, mitotic recombination, chromosome translocations, and aneuploidy). A number of recent findings add to the present understanding of mechanisms of benzene hematotoxicity and carcinogenicity.

Hirabayashi and coworkers (Hirabayashi and Inoue 2010; Hirabayashi et al. 2008; Yoon et al. 2002; 2003) demonstrated a role for a hematopoietic stem cell-specific, aryl hydrocarbon receptor (AhR) in benzene-induced bone marrow toxicity using wild-type and AhR-knockout mice exposed to benzene at levels resulting in marked decreases in numbers of peripheral white blood cells and red blood cells in the wild-type mice. No such effects were seen in benzene-exposed AhR-knockout mice or in wild-type mice that had been whole-body irradiated and repopulated using bone marrow from AhR-knockout mice prior to benzene exposure. AhR expression may be involved in the regulation of hematopoietic stem cells (Singh et al. 2009). It has been suggested that the absence of AhR makes hematopoietic stem cells susceptible to benzene-induced DNA damage and subsequent apoptosis (IARC 2012). Based on evaluation of available mechanistic data, IARC (2012) determined that there is strong evidence that benzene metabolites produce multiple genotoxic effects on pluripotent hematopoietic stem cells resulting in chromosomal changes consistent with those observed in hematopoietic cancer.

### 3.8 BIOMARKERS OF EXPOSURE AND EFFECT

#### 3.8.1 Biomarkers Used to Identify or Quantify Exposure to Benzene

Several recent reports (Fracasso et al. 2010; Garte et al. 2005; Hoet et al. 2009; Lovreglio et al. 2010, 2011; Lv et al. 2014; Zhang et al. 2011b) provide support to the usefulness of selected benzene metabolites (particularly urinary trans,trans-muconic acid and S-phenylmercapturic acid and urinary benzene itself) as biomarkers of exposure to benzene, as discussed in the 2007 Toxicological Profile for Benzene (Agency for Toxic Substances and Disease Registry 2007).. In addition, results of Lovreglio et al. (2011) indicate that urinary benzene may serve as a more reliable biomarker of exposure than urinary trans,trans-muconic acid or S-phenylmercapturic acid at environmentally-relevant benzene exposure levels. Lin et al. (2007) evaluated possible usefulness of albumin adducts of electrophilic benzene metabolism in workers with relatively low-level exposure to benzene (0.026–54.5 ppm). The results indicate that albumin adducts of benzene oxide and benzoquinones reflect exposures to benzene at levels ≥1 ppm, but would not be useful biomarkers of exposure at levels <1 ppm.

#### 3.8.2 Biomarkers Used to Characterize Effects Caused by Benzene

Benzene-induced effects such as alterations in selected gene expression (Bai et al. 2014a, 2014b; Park et al. 2008; Yang et al. 2014), DNA damage and altered DNA repair capacity (Chanvaivit et al. 2007; Fracasso et al. 2010), and increases in chromosomal aberrations (Kim et al. 2010; Tunsaringkarn et al. 2011) have been suggested as potential biomarkers of effects, particularly at relatively low levels of benzene exposure. However, these biomarkers are not specific to benzene exposure.

### 3.9 INTERACTIONS WITH OTHER CHEMICALS

Coexposure of mice to benzene and toluene resulted in higher frequency of micronuclei in polychromatic erythrocytes compared to exposure to benzene or toluene alone (Bird et al. 2010; Wetmore et al. 2008). Li et al. (2009) subjected groups of mice to intratracheal instillation of either benzene or carbon nanotubes or combined instillation of benzene and carbon nanotubes. Combined instillation resulted in considerably more severe histopathological pulmonary toxicity than that observed in mice exposed to benzene or carbon nanotubes alone.

### 3.10 POPULATIONS THAT ARE UNUSUALLY SUSCEPTIBLE

Reports from several studies indicate that susceptibility to benzene-induced hematotoxicity among workers may be associated with polymorphisms in multiple genes involved in benzene metabolism (Garte et al. 2008; Gu et al. 2007; Kim et al. 2007; Shen et al. 2011; Sun et al. 2007, 2008, 2009a, 2009b; Wu et al. 2008; Zhang et al. 2011a). In addition, results from Hosgood et al. (2009) indicate that genetic variation in vascular endothelial growth factor (VEGF), which plays a role in blood vessel growth, and excision repair cross-complementing 3 (ERCC3), which is part of the DNA repair pathway, may contribute to individual susceptibility to low-level benzene-induced hematotoxicity.

### 3.11 METHODS FOR REDUCING TOXIC EFFECTS

#### 3.11.3 Interfering with the Mechanism of Action for Toxic Effects

Several groups of investigators have evaluated possible roles of selected antioxidants in decreasing the hematotoxicity of benzene. Melatonin inhibited benzene-induced lipid peroxidation in the rat liver (Sharma and Rana 2010). Progesterone inhibited formation of reactive oxygen species in benzene-treated rats (Verma and Rana 2008). Green tea was observed to attenuate benzene-induced oxidative stress in filling station workers (Emara and El-Bahrawy 2008). Saha et al. (2012) reported that methanolic leaf extract of Ocimum basilicum L. reduced benzene-induced hematotoxicity in mice. Polyphenolic acetates demonstrated time-dependent inhibition of CYP450-linked mixed function oxidases in rat bone marrow and lung cells in vitro (Kumar et al. 2011). Acetylsalycilic acid decreased selected hematotoxic effects of inhaled benzene in rats (Kowalówka-Zawieja et al. (2013).

Yu et al. (2007) found that amifostine (a well-known cytoprotective agent used to protect normal tissues from toxic effects of chemotherapy and radiotherapy) reduced benzene-induced hematotoxic effects in bone marrow of treated mice. Polyphenolic acetates inhibited the formation of micronuclei in rat bone marrow and lung cells in vitro (Kumar et al. 2011).

### 3.12 ADEQUACY OF THE DATABASE

#### 3.12.3 Ongoing Studies

The following ongoing studies pertaining to benzene were identified in National Institutes of Health (NIH) Research Portfolio Online Reporting Tools (RePORTER 2014):

Dr. Anneclaire De Roos, Public Health and Preventive Medicine, Schools of Public Health, Drexel University, Philadelphia, Pennsylvania, College of Public Health, University of Iowa, is conducting a meta-analysis of 13 case-control studies of multiple myeloma to evaluate risks associated with occupational solvent exposures, including benzene.

Dr. Edward Paul Hasty, University of Texas Health Science Center, San Antonio, Texas is investigating the dynamics of repairing benzene-induced DNA lesions and the development of myelodysplastic syndrome and acute myeloid leukemia.

## 4 CHEMICAL AND PHYSICAL INFORMATION

No updated data.

## 5 PRODUCTION, IMPORT/EXPORT, USE, AND DISPOSAL

### 5.1 PRODUCTION

Table 5-1 lists the facilities in each state that manufacture or process benzene, the intended use, and the range of maximum amounts of benzene that are stored on-site. There are 981 facilities that produce, process, or use benzene in the United States (TRI13 2014). The data from the Toxics Release Inventory (TRI) listed in Table 5-1 should be used with caution, however, since only certain types of facilities were required to report (EPA 2005). This is not an exhaustive list.

### 5.2 IMPORT/EXPORT

Imports of benzene (from mineral fuels and pure benzene) into the United States were approximately 4,757 million L (9,131 million pounds) in 2013 and 4,751 million L (9,143 million pounds) in 2012. The largest exporters of benzene to the United States during 2013–2014 were Saudi Arabia, Iraq, Korea, and Venezuela (USITC 2014).

Table 5-1 Facilities that Produce, Process, or Use Benzene

State^a^ | Number of facilities | Minimum amount on site in pounds^b^ | Maximum amount on site in pounds^b^ | Activities and uses^c^
AK | 9 | 1,000 | 49,999,999 | 1, 3, 4, 5, 6, 7, 9, 13
AL | 12 | 100 | 49,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 11, 12, 13, 14
AR | 8 | 100 | 49,999,999 | 1, 2, 3, 5, 6, 7, 9, 12
AZ | 16 | 100 | 9,999,999 | 1, 5, 9, 11, 12, 13
CA | 67 | 0 | 49,999,999 | 1, 2, 3, 4, 5, 6, 7, 9, 12, 13, 14
CO | 10 | 0 | 499,999,999 | 1, 3, 5, 7, 8, 9, 12, 13
CT | 7 | 100 | 9,999,999 | 9
DE | 1 | 100,000 | 999,999 | 1, 2, 3, 4, 5, 6, 7, 9
FL | 26 | 100 | 9,999,999 | 1, 2, 4, 5, 7, 9
GA | 15 | 1,000 | 9,999,999 | 1, 5, 7, 9, 10
GU | 2 | 100 | 999,999 | 7, 9
HI | 8 | 100 | 9,999,999 | 1, 2, 3, 4, 5, 6, 9, 12, 13, 14
IA | 36 | 100 | 9,999,999 | 1, 4, 5, 7, 8, 9, 12
ID | 3 | 1,000 | 999,999 | 2, 4, 7, 9
IL | 42 | 100 | 99,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 11, 12, 13, 14
IN | 39 | 0 | 499,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 10, 12, 14
KS | 18 | 0 | 499,999,999 | 1, 3, 4, 5, 6, 7, 8, 9, 12
KY | 20 | 0 | 49,999,999 | 1, 3, 5, 6, 7, 8, 9, 10, 12, 13, 14
LA | 61 | 0 | 499,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 10, 11, 12, 13, 14
MA | 12 | 10,000 | 49,999,999 | 1, 2, 4, 5, 7, 8, 9, 12
MD | 10 | 1,000 | 9,999,999 | 2, 4, 9, 12
ME | 5 | 0 | 9,999,999 | 2, 3, 4, 7, 9, 12
MI | 38 | 0 | 9,999,999 | 1, 4, 5, 6, 7, 8, 9, 10, 12, 13, 14
MN | 18 | 10,000 | 49,999,999 | 1, 2, 3, 4, 5, 6, 7, 9, 10, 11, 12, 13
MO | 16 | 0 | 9,999,999 | 1, 5, 7, 8, 9, 12, 14
MP | 2 | 100 | 99,999 | 7, 9
MS | 15 | 1,000 | 49,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 13, 14
MT | 5 | 1,000 | 9,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 12, 13, 14
NC | 19 | 0 | 9,999,999 | 1, 2, 4, 5, 7, 9, 12
ND | 14 | 0 | 49,999,999 | 1, 2, 3, 4, 5, 6, 9, 12, 13, 14
NE | 20 | 1,000 | 99,999 | 1, 5, 7, 12
NH | 1 | 10,000 | 99,999 | 1, 5, 12
NJ | 13 | 1,000 | 49,999,999 | 1, 2, 3, 4, 5, 6, 7, 9
NM | 6 | 100,000 | 9,999,999 | 1, 3, 4, 6, 7, 9
NV | 3 | 1,000,000 | 9,999,999 | 9
NY | 38 | 0 | 99,999,999 | 1, 2, 4, 5, 7, 8, 9, 12
OH | 42 | 0 | 99,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 11, 12, 13, 14
OK | 13 | 0 | 9,999,999 | 1, 2, 3, 4, 5, 6, 7, 9, 12, 13, 14
OR | 8 | 10,000 | 9,999,999 | 1, 5, 7, 9, 12
PA | 23 | 0 | 49,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 12, 13, 14
PR | 7 | 0 | 499,999,999 | 2, 4, 5, 7, 8, 9, 13
RI | 2 | 1,000,000 | 9,999,999 | 7, 9
SC | 6 | 100 | 9,999,999 | 1, 2, 4, 5, 8, 9, 12, 14
SD | 11 | 10,000 | 99,999 | 7, 9
TN | 12 | 0 | 9,999,999 | 1, 2, 3, 5, 7, 8, 9, 11, 12, 13, 14
TX | 146 | 0 | 499,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 10, 11, 12, 13, 14
UT | 9 | 10,000 | 99,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 12
VA | 11 | 0 | 999,999 | 1, 2, 4, 5, 7, 9, 12
VI | 2 | 10,000 | 999,999 | 1, 2, 4, 5, 7, 9, 12
WA | 17 | 0 | 49,999,999 | 1, 2, 3, 4, 5, 7, 9, 11, 12, 13, 14
WI | 22 | 0 | 9,999,999 | 1, 2, 5, 7, 9, 11, 12, 13, 14
WV | 7 | 1,000 | 9,999,999 | 1, 3, 4, 5, 6, 7, 8, 9, 12, 13
WY | 8 | 0 | 9,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 12, 13, 14

a Post office state abbreviations used.

b Amounts on site reported by facilities in each state.

c Activities/Uses:

1. Produce
2. Import
3. Onsite use/processing
4. Sale/Distribution
5. Byproduct
6. Reactant
7. Formulation Component
8. Article Component
9. Repackaging
10. Chemical Processing Aid
11. Manufacturing Aid
12. Ancillary/Other Uses
13. Manufacturing Impurity
14. Process Impurity

Source: TRI13 2014 (Data are from 2013)

Exports of benzene (both pure benzene and benzene derived from mineral fuels) to other countries were approximately 372 million L (716 million pounds) in 2013 and 178 million L (341 million pounds) in 2012. The largest importers of benzene from the United States are Canada, the Netherlands, and Belgium (USITC 2014).

## 6 POTENTIAL FOR HUMAN EXPOSURE

### 6.2 RELEASES TO THE ENVIRONMENT

Data from EPA’s Toxics Release Inventory (TRI) on facilities that release benzene in 2012 are shown in Tables 6-1 (TRI13 2014).

Table 6-1 Releases to the Environment from Facilities that Produce, Process, or Use Benzene^a^

State^c^ | RF^d^ | Reported amounts released in pounds per year^b^
State^c^ | RF^d^ | Air^e^ | Water^f^ | UI^g^ | Land^h^ | Other^i^ | Total release
State^c^ | RF^d^ | Air^e^ | Water^f^ | UI^g^ | Land^h^ | Other^i^ | On-site^j^ | Off-site^k^ | On- and off-site
AK | 9 | 11,201 | 9 | 0 | 19 | 1 | 11,229 | 1 | 11,230
AL | 11 | 57,712 | 2 | 0 | 305 | 29 | 57,731 | 317 | 58,048
AR | 8 | 25,447 | 8 | 10 | 0 | 429 | 25,465 | 429 | 25,894
AZ | 15 | 18,444 | 0 | 0 | 0 | 0 | 18,444 | 0 | 18,444
CA | 58 | 48,810 | 2,936 | 42 | 167,324 | 365 | 218,489 | 988 | 219,477
CO | 11 | 15,165 | 2 | 0 | 3 | 2 | 15,167 | 4 | 15,171
CT | 8 | 2,121 | 1 | 0 | 0 | 0 | 2,122 | 0 | 2,122
DE | 1 | 11,893 | 5 | 0 | 0 | 0 | 11,898 | 0 | 11,898
FL | 27 | 103,351 | 11 | 0 | 12 | 215 | 103,362 | 227 | 103,590
GA | 14 | 14,363 | 36 | 0 | 17 | 0 | 14,399 | 17 | 14,416
GU | 2 | 1,345 | 0 | 0 | 1 | 0 | 1,345 | 1 | 1,347
HI | 9 | 13,745 | 16 | 0 | 6 | 1 | 13,763 | 5 | 13,768
IA | 36 | 62,355 | 5 | 0 | 1 | 0 | 62,360 | 1 | 62,361
ID | 3 | 1,080 | 0 | 0 | 0 | 0 | 1,080 | 0 | 1,080
IL | 42 | 120,415 | 304 | 4 | 1,076 | 63 | 120,847 | 1,016 | 121,862
IN | 39 | 178,044 | 156 | 10,620 | 1,382 | 1,660 | 188,825 | 3,037 | 191,862
KS | 17 | 58,579 | 34 | 184 | 585 | 3 | 58,818 | 568 | 59,385
KY | 19 | 58,539 | 5 | 0 | 31 | 0 | 58,554 | 21 | 58,575
LA | 58 | 468,108 | 489 | 3,409 | 1,511 | 1,973 | 472,040 | 3,450 | 475,490
MA | 13 | 3,733 | 4 | 0 | 14 | 278 | 3,736 | 292 | 4,029
MD | 8 | 2,053 | 7 | 0 | 3 | 0 | 2,060 | 3 | 2,063
ME | 6 | 2,414 | 37 | 0 | 0 | 14 | 2,451 | 14 | 2,465
MI | 35 | 156,500 | 33 | 0 | 109 | 428 | 156,537 | 533 | 157,070
MN | 19 | 14,836 | 30 | 0 | 8 | 0 | 14,866 | 8 | 14,874
MO | 15 | 32,532 | 0 | 0 | 0 | 0 | 32,532 | 0 | 32,532
MP | 2 | 188 | 0 | 0 | 0 | 0 | 188 | 0 | 188
MS | 15 | 44,354 | 6 | 0 | 16 | 0 | 44,361 | 15 | 44,376
MT | 6 | 28,396 | 17 | 0 | 49 | 0 | 28,431 | 30 | 28,462
NC | 16 | 11,137 | 0 | 0 | 0 | 0 | 11,137 | 0 | 11,137
ND | 9 | 23,778 | 0 | 0 | 8 | 0 | 23,782 | 4 | 23,786
NE | 21 | 1,428 | 0 | 0 | 58 | 0 | 1,428 | 58 | 1,486
NH | 1 | 43 | 0 | 0 | 0 | 1 | 43 | 1 | 44
NJ | 15 | 22,796 | 389 | 0 | 164 | 10 | 23,188 | 171 | 23,359
NM | 6 | 28,937 | 0 | 230 | 6,026 | 0 | 29,516 | 5,677 | 35,193
NV | 3 | 976 | 0 | 0 | 0 | 0 | 976 | 0 | 976
NY | 39 | 43,314 | 3 | 0 | 7 | 234 | 43,321 | 237 | 43,558
OH | 41 | 138,303 | 9 | 185 | 180 | 45 | 138,511 | 211 | 138,722
OK | 12 | 107,565 | 261 | 0 | 275 | 5 | 107,826 | 280 | 108,106
OR | 8 | 2,443 | 1 | 0 | 17,103 | 0 | 19,491 | 57 | 19,548
PA | 24 | 174,915 | 116 | 0 | 121 | 13 | 175,032 | 134 | 175,166
PR | 6 | 7,637 | 0 | 0 | 1 | 2 | 7,638 | 2 | 7,641
RI | 2 | 801 | 9 | 0 | 0 | 413 | 810 | 413 | 1,223
SC | 7 | 42,796 | 0 | 0 | 0 | 5 | 42,796 | 5 | 42,801
SD | 12 | 274 | 0 | 0 | 1 | 0 | 275 | 0 | 275
TN | 12 | 29,981 | 3 | 0 | 254 | 410 | 29,984 | 664 | 30,648
TX | 149 | 1,130,400 | 991 | 225,855 | 7,336 | 9,857 | 1,353,861 | 20,578 | 1,374,439
UT | 9 | 25,743 | 5 | 0 | 131 | 9,019 | 25,750 | 9,148 | 34,898
VA | 14 | 12,783 | 102 | 0 | 2 | 14 | 12,885 | 16 | 12,901
VI | 2 | 12,386 | 0 | 0 | 30 | 1 | 12,386 | 31 | 12,418
WA | 17 | 31,476 | 421 | 0 | 146 | 2 | 31,965 | 80 | 32,045
WI | 22 | 144,132 | 1 | 0 | 751 | 8 | 144,133 | 759 | 144,893
WV | 6 | 56,554 | 5 | 0 | 142 | 21 | 56,559 | 163 | 56,722
WY | 8 | 19,951 | 5 | 0 | 578 | 0 | 19,956 | 578 | 20,534
Total | 967 | 3,626,277 | 6,474 | 240,539 | 205,787 | 25,521 | 4,054,354 | 50,245 | 4,104,598

a The TRI data should be used with caution since only certain types of facilities are required to report. This is not an exhaustive list. Data are rounded to nearest whole number.

b Data in TRI are maximum amounts released by each facility.

c Post office state abbreviations are used.

d Number of reporting facilities.

e The sum of fugitive and point source releases are included in releases to air by a given facility.

f Surface water discharges, waste water treatment-(metals only), and publicly owned treatment works (POTWs) (metal and metal compounds).

g Class I wells, Class II-V wells, and underground injection.

h Resource Conservation and Recovery Act (RCRA) subtitle C landfills; other onsite landfills, land treatment, surface impoundments, other land disposal, other landfills.

i Storage only, solidification/stabilization (metals only), other off-site management, transfers to waste broker for disposal, unknown

j The sum of all releases of the chemical to air, land, water, and underground injection wells.

k Total amount of chemical transferred off-site, including to POTWs.

RF = reporting facilities; UI = underground injection

Source: TRI13 2014 (Data are from 2013)

#### 6.2.1 Air

Estimated releases of 3,626,277 pounds (~1,645 metric tons) of benzene to the atmosphere from 967 domestic manufacturing and processing facilities in 2012 accounted for about 88% of the estimated total environmental releases from facilities required to report to the TRI (TRI13 2014). These releases are summarized in Table 6-1.

U.S. EPA’s National Emission Inventory (NEI) database contains a detailed estimate of air emissions of criteria air pollutants and their precursors from all air emission sources, including point, nonpoint, onroad, offroad, and events (wildfires, prescribed burns, etc.), provided by state, local, and tribal air agencies, and supplemented by data developed by the U.S. EPA. According to data obtained from the NEI, 542 million pounds (~246,000 metric tons) of benzene were released to air from 54 different emission source categories in 2011, with the highest percentage coming from wildfires (EPA 2013b).

#### 6.2.2 Water

Estimated releases of 6,474 pounds (~2.94 metric tons) of benzene to surface water from 967 domestic manufacturing and processing facilities in 2012 accounted for about 0.2% of the estimated total environmental releases from facilities required to report to the TRI (TRI13 2014). This estimate includes releases to waste water treatment and publicly owned treatment works (POTWs) (TRI13 2014). These releases are summarized in Table 6-1.

#### 6.2.3 Soil

Estimated releases of 205,787 pounds (~93 metric tons) of benzene to soils from 967 domestic manufacturing and processing facilities in 2012 accounted for about 5% of the estimated total environmental releases from facilities required to report to the TRI (TRI13 2014). An additional 240,539 pounds (~109 metric tons), constituting about 6% of the total environmental emissions, were released via underground injection (TRI13 2014). These releases are summarized in Table 6-1.

### 6.3 ENVIRONMENTAL FATE

#### 6.3.2 Transformation and Degradation

Bacterium strain, Mycobacterium cosmeticum byf-4, has been reported to aerobically biodegrade benzene, toluene, ethylbenzene, and o-xylene, simultaneously or individually, via mineralization and incorporation into cell materials (Zhang et al. 2013). Benzene alone or in a mixture of benzene, toluene, ethylbenzene, and o-xylene, at an initial concentration of 100 mg/L, was completely degraded within 36–42 hours.

### 6.4 LEVELS MONITORED OR ESTIMATED IN THE ENVIRONMENT

#### 6.4.1 Air

The U.S. EPA’s Air Quality System (AQS) takes direct measurements of pollutant concentrations in ambient air at monitoring stations around the country (EPA 2014a). The data for benzene concentrations measured by the AQS in 2013 are presented in Table 6-2.

Table 6-2 Benzene Ambient Air Concentrations by City in 2013

State | City | Mean concentration (ppbC)^a^
Alaska | Anchorage | 2.91
Arizona | Phoenix | 2
Arizona | Phoenix | 1.97
Arizona | Phoenix | 2.03
Arizona | Phoenix | 0.995
Arizona | Queen Valley | 0
Arizona | Queen Valley | 0
California | Livermore | 1.61
California | Livermore | 0.954
California | Oakland | 2.14
California | Oakland | 1.77
California | Livermore | 0.401
California | Chico | 1.64
California | Concord | 1.06
California | Richmond | 1.43
California | Crockett | 0.88
California | Bethel Island | 1.27
California | San Pablo | 1.29
California | Martinez | 1.09
California | San Ramon | 0.664
California | Fresno | 1.84
California | Parlier | 0.59
California | Clovis | 0.64
California | Calexico | 2.61
California | Bakersfield | 1.54
California | Bakersfield | 1.45
California | Bakersfield | 0.842
California | Shafter | 1.11
California | Azusa | 1.68
California | Burbank | 2.63
California | Los Angeles | 2.29
California | Pico Rivera | 1.69
California | Long Beach | 1.79
California | Madera | 0.554
California | San Rafael | 1.23
California | Mill Valley | 0.496
California | Napa | 1.84
California | Roseville | 1.25
California | Rubidoux | 1.85
California | Arden-Arcade | 0.622
California | Elk Grove | 0.38
California | Folsom | 0.564
California | Chula Vista | 1.16
California | El Cajon | 1.29
California | El Cajon | 2.22
California | El Cajon | 1.58
California | Alpine | 0.657
California | Alpine | 0.874
California | Camp Pendleton South | 0.541
California | Camp Pendleton South | 1.08
California | San Francisco | 1.34
California | San Francisco | 0.88
California | San Francisco | 1.26
California | Stockton | 1.67
California | Redwood City | 1.73
California | San Jose | 2.17
California | San Jose | 2.03
California | Cupertino | 0.92
California | Vallejo | 1.77
California | Santa Rosa | 1.23
California | Simi Valley | 0.719
California | Simi Valley | 1.15
California | Oxnard | 0.274
Colorado | Denver | 3.03
Colorado | Parachute | 3.6
Colorado | Rifle | 2.85
Colorado | Silt | 2.15
Colorado | Carbondale | 1.07
Colorado | Grand Junction | 1.86
Colorado | Platteville | 6.81
Connecticut | Westport | 0.326
Connecticut | East Hartford | 0.463
Connecticut | New Haven | 1.22
Delaware | Delaware City | 0.989
Delaware | Wilmington | 1.81
District Of Columbia | Washington | 0.691
District Of Columbia | Washington | 1.03
District Of Columbia | Washington | 0.888
District Of Columbia | Washington | 1.42
Florida | Fort Lauderdale | 1.53
Florida | Davie | 1.54
Florida | Dania | 2.84
Florida | Valrico | 0.723
Florida | Winter Park | 0.663
Florida | Saint Petersburg | 0.714
Florida | Pinellas Park | 0.876
Georgia | Macon | 6.93
Georgia | Savannah | 0.74
Georgia | Nicholls | 0.638
Georgia | Dawsonville | 1.54
Georgia | Decatur | 1.03
Georgia | Decatur | 0.926
Georgia | Decatur | 1.68
Georgia | Rockmart | 0.059
Georgia | Rockmart | 0.605
Georgia | Rockmart | 0.567
Georgia | Conyers | 0.508
Georgia | Conyers | 0.765
Illinois | Schiller Park | 1.39
Illinois | Northbrook | 0.884
Illinois | Northbrook | 1.05
Illinois | Roxana | 1.82
Indiana | Clarksville | 1
Indiana | Gary | 2.43
Indiana | Gary | 2.2
Indiana | Gary | 2.68
Indiana | Indianapolis (Remainder) | 0.869
Iowa | Cedar Rapids | 1.17
Iowa | Cedar Rapids | 0.68
Iowa | Des Moines | 1.12
Iowa | Des Moines | 0.647
Iowa | Davenport | 1.1
Iowa | Davenport | 0.63
Kentucky | Ashland | 2.85
Kentucky | Grayson | 0.912
Kentucky | Lexington-Fayette (corporate name for Lexington) | 1.25
Kentucky | Smithland | 1.26
Kentucky | Calvert City (RR name Calvert) | 1.94
Kentucky | Calvert City (RR name Calvert) | 2.01
Kentucky | Calvert City (RR name Calvert) | 1
Kentucky | Calvert City (RR name Calvert) | 0.928
Kentucky | Calvert City | 1.17
Louisiana | Geismar | 1.45
Louisiana | Geismar | 1.37
Louisiana | Baton Rouge | 1.57
Louisiana | Baton Rouge | 1.73
Louisiana | Zachary | 0.861
Louisiana | Zachary | 0.842
Louisiana | Plaquemine | 1.26
Louisiana | Plaquemine | 1.24
Maine | Lewiston | 1.25
Maine | Presque Isle | 1.16
Maine | Portland | 1.18
Maine | Portland | 1.16
Maine | Cape Elizabeth | 0.523
Maine | Acadia National Park | 0.287
Maine | Rumford (census name for Rumford Compact) | 1.3
Maine | Bangor | 1.08
Maryland | Essex | 0.869
Maryland | Essex | 1.6
Maryland | Essex | 1.36
Maryland | Beltsville | 0.605
Maryland | Beltsville | 0.79
Maryland | Beltsville | 0.898
Maryland | Baltimore | 1.46
Massachusetts | Lynn | 0.394
Massachusetts | Lynn | 0.74
Massachusetts | Lynn | 0.733
Massachusetts | Chicopee | 0.368
Massachusetts | Boston | 1.08
Massachusetts | Boston | 1.15
Michigan | Midland | 0.602
Michigan | Midland | 0.872
Michigan | Midland | 0.498
Michigan | Midland | 0.516
Michigan | Detroit | 1.18
Michigan | Dearborn | 1.2
Michigan | Detroit | 2.48
Michigan | Detroit | 2.31
Michigan | Detroit | 2.39
Michigan | Detroit | 3.74
Michigan | Detroit | 2.54
Minnesota | Blaine | 0.861
Minnesota | Rosemount | 0.953
Minnesota | Inver Grove Heights (RR name Inver Grove) | 0.635
Minnesota | Rosemount | 0.677
Minnesota | Rosemount | 0.629
Minnesota | Apple Valley | 0.768
Minnesota | Richfield | 0.888
Minnesota | Minneapolis | 1.45
Minnesota | Minneapolis | 1.14
Minnesota | Minneapolis | 1.05
Minnesota | Minneapolis | 1.05
Minnesota | Minneapolis | 1.07
Minnesota | Minneapolis | 1.25
Minnesota | St. Louis Park | 0.96
Minnesota | St. Paul | 1.2
Minnesota | St. Paul | 0.984
Minnesota | Duluth | 1.03
Minnesota | St. Paul Park | 1.21
Minnesota | St. Paul Park | 1.2
Minnesota | Newport | 1.32
Minnesota | Bayport | 0.696
Mississippi | Columbus | 1
Mississippi | Columbus | 1.14
Missouri | St. Louis | 1.14
New Hampshire | Nashua | 0.237
New Hampshire | Nashua | 1.37
New Hampshire | Peterborough (Peterboro) | 0.385
New Hampshire | Peterborough (Peterboro) | 0.553
New Jersey | Camden | 1.6
New Jersey | North Brunswick Township | 1.22
New Jersey | East Brunswick | 0.345
New Jersey | Chester | 0.921
New Jersey | Elizabeth | 1.51
New York | New York | 1.37
New York | New York | 1.27
New York | New York | 1.3
New York | New York | 1.71
New York | New York | 1.18
New York | New York | 1.29
New York | Buffalo | 0.911
New York | Tonawanda | 1.62
New York | Tonawanda | 1.53
New York | Tonawanda | 1.67
New York | Tonawanda | 1.01
New York | Wilmington | 0.493
New York | New York | 1.32
New York | Rochester | 0.807
New York | New York | 1.04
New York | New York | 1.14
New York | New York | 1.4
New York | Addison | 0.613
North Carolina | Asheville | 0.889
North Carolina | Asheville | 0.68
North Carolina | Winston-Salem | 1.19
North Carolina | Winston-Salem | 1.08
North Carolina | Sanford | 0.63
North Carolina | Charlotte | 1.23
North Carolina | Candor | 0.69
North Carolina | Candor | 0.433
North Carolina | Wilmington | 0.633
North Carolina | Wilmington | 1.31
North Carolina | Raleigh | 1.03
North Carolina | Raleigh | 1.04
Ohio | Middletown | 1.27
Ohio | Middletown | 1.21
Ohio | Middletown | 1.14
Ohio | Cleveland | 1.92
Ohio | Brook Park | 1.58
Ohio | Columbus | 1.28
Ohio | Cincinnati | 1.21
Ohio | Cincinnati | 1.21
Ohio | Steubenville | 8.27
Ohio | Portsmouth | 0.804
Ohio | Franklin Furnace | 0.895
Ohio | Franklin Furnace | 0.947
Oklahoma | Yukon | 0.931
Oklahoma | Oklahoma City | 0.989
Oklahoma | Oklahoma City | 1.45
Oklahoma | Tulsa | 1.89
Oklahoma | Tulsa | 2.26
Oklahoma | Tulsa | 1.81
Oregon | Medford | 4.36
Oregon | Portland | 1.19
Oregon | Portland | 1.2
Oregon | La Grande | 0.966
Oregon | Hillsboro | 1.15
Pennsylvania | Pittsburgh | 1.61
Pennsylvania | Liberty | 1.36
Pennsylvania | Philadelphia | 0.84
Pennsylvania | Philadelphia | 1.21
Pennsylvania | Philadelphia | 1.22
Pennsylvania | Philadelphia | 1.64
Pennsylvania | Philadelphia | 1.74
Pennsylvania | Philadelphia | 0.78
Pennsylvania | Philadelphia | 1.96
Pennsylvania | Philadelphia | 1.89
Pennsylvania | Philadelphia | 1.02
Rhode Island | West Greenwich | 0.605
Rhode Island | Providence | 1.08
Rhode Island | Pawtucket | 1.5
Rhode Island | East Providence | 0.511
Rhode Island | East Providence | 0.87
Rhode Island | East Providence | 0.827
Texas | San Antonio | 1.33
Texas | Clute (corporate name for Clute City) | 0.952
Texas | Brownsville | 1.21
Texas | Dallas | 0.871
Texas | Dallas | 1.21
Texas | Denton | 1.42
Texas | Odessa | 1.95
Texas | Midlothian | 0.844
Texas | Italy | 0.905
Texas | El Paso | 1.47
Texas | El Paso | 1.79
Texas | El Paso | 1.99
Texas | Socorro | 1.6
Texas | El Paso | 1.01
Texas | Texas City | 2.08
Texas | Galveston | 1.01
Texas | Longview | 2.63
Texas | Houston | 2.02
Texas | Channelview | 2.6
Texas | Cypress | 1.8
Texas | Channelview | 5.49
Texas | Houston | 1.58
Texas | Galena Park | 5.89
Texas | Baytown | 2.21
Texas | La Porte | 4.72
Texas | Houston | 1.73
Texas | Houston | 2.98
Texas | Houston | 2.83
Texas | Houston | 6.5
Texas | Houston | 2.05
Texas | Deer Park | 1.9
Texas | Deer Park | 2.46
Texas | Deer Park | 2.76
Texas | Pasadena | 4.49
Texas | Houston | 2.16
Texas | Marshall | 1.61
Texas | Mission | 1.3
Texas | Greenville | 0.958
Texas | Beaumont | 2.28
Texas | Beaumont | 1.77
Texas | Port Arthur | 2.11
Texas | Port Arthur | 4.34
Texas | Port Neches | 1.54
Texas | Port Arthur | 1.58
Texas | Port Arthur | 2.74
Texas | Nederland | 1.43
Texas | Beaumont | 2.01
Texas | Alvarado | 0.926
Texas | Kaufman | 1.31
Texas | Conroe | 1.41
Texas | Corpus Christi | 2.41
Texas | Corpus Christi | 5.38
Texas | Corpus Christi | 1.96
Texas | Corpus Christi | 1.65
Texas | Fort Worth | 0.988
Texas | Fort Worth | 1.25
Texas | Grapevine | 1.01
Texas | Austin | 1.49
Texas | Laredo | 3.67
Utah | Bountiful | 1.78
Utah | Bountiful | 2.15
Vermont | Underhill (Town of) | 0.588
Vermont | Burlington | 1.24
Vermont | Burlington | 1.2
Vermont | Rutland | 1.56
Virginia | Corbin | 0.775
Virginia | Groveton | 0.89
Virginia | East Highland Park | 0.788
Virginia | East Highland Park | 1.02
Virginia | East Highland Park | 1.07
Virginia | Hopewell | 1.02
Virginia | Hopewell | 1.13
Virginia | Virginia Beach | 1.18
Washington | Seattle | 1.05
West Virginia | Wheeling | 1.68
Wisconsin | Horicon | 1.11
Wisconsin | Horicon | 0.7
Wisconsin | Milwaukee | 2.34

a Units are parts per billion carbon, which is equivalent to ppb times the number of carbon atoms.

Source: EPA 2014a

During the Detroit Exposure and Aerosol Research Study, which measured daily average ambient air concentrations of benzene from 2004 to 2007 in Detroit, Michigan, the mean average daily ambient air concentration ranged from 1.3 to 4.1 µg/m^3^ (0.4–1.3 ppb) for 1,483 samples and the mean average daily indoor air concentration ranged from 2.3 to 6.0 µg/m^3^ (0.7–1.8 ppb) for 934 samples (George et al. 2011).

#### 6.4.2 Water

The U.S. Geological Survey (USGS) conducted a national assessment of 55 volatile organic compounds in well water samples collected from 2,401 domestic wells around the country during 1985–2002. Benzene was detected in 37 of 1,208 well samples, or 3.1% of the samples, at concentrations mostly <1 µg/L (Rowe et al. 2007). The USGS also evaluated benzene concentrations from 1,973 wells in California State Water Board’s Groundwater Ambient Monitoring and Assessment Program and 12,417 wells from California Department of Public Health. The median concentration of benzene detected was 0.024 µg/L and the frequency of detection was 1.7%.

#### 6.4.4 Other Environmental Media

In a study analyzing the benzene concentration in 455 food samples from the Belgian market, benzene was detected in 58% of samples collected (Medeiros Vinci et al. 2012). The highest concentrations of benzene were found in processed foodstuffs, including fish (smoked or canned) with a reported maximum concentration of 76.21 µg/kg. Raw meat, fish, eggs, and other unprocessed foods had no or lower concentrations of benzene, with values ranging from 0 to 9.44 µg/kg. Using this study, an estimated mean benzene intake for all foods in the Belgian market was reported as 0.020 µg/kg body weight/day (0.00002 mg/kg/day).

### 6.5 GENERAL POPULATION AND OCCUPATIONAL EXPOSURE

During the Detroit Exposure and Aerosol Research Study, which measured daily average ambient breathing zone concentrations of benzene for the general population from 2004 to 2007 in Detroit, Michigan, the mean average daily personal air concentrations ranged from 2.7 to 7.7 µg/m^3^ (858 samples) (George et al. 2011).

Bogen and Sheehan (2014) estimated that workers’ dermal exposure to benzene in mineral spirits solvents (MSS), used in parts washing and degreasing operations, averaged 33% of their total (dermal and inhalation) benzene uptake. The estimated average benzene doses from parts washing by dermal exposure and total exposure were reported as 0.0093 and 0.054 mg/day, respectively, using current ‘low-aromatic’ MSS formulations from 1995 to 1999. In a study assessing the dermal exposure and absorption of combustion contaminants in firefighters during six different controlled structure burns, the median increase in breath concentrations of benzene post versus pre-burn were 48.1, 2.81, 39.2, −0.33, 7.39, and 18.8 µg/m^3^ (Fent et al. 2014). The benzene metabolite, S-phenylmercapturic acid, could not be detected in urine samples collected from the firefighters (minimum detectable concentration 8.5 µg/g).

In a study comparing the urinary benzene metabolite trans,trans-muconic acid between 81 ceramic factory workers exposed to low levels of benzene and 83 nonexposed controls, the workers and the control group had mean trans,trans-muconic acid concentrations of 0.22 and 0.043 mg/g creatinine, respectively (Ibrahim et al. 2014).

One study assessed the exposure of 133 male petrochemical industry operators to benzene by both environmental (personal air) and biological monitoring (metabolites trans,trans-muconic acid and S-phenylmercapturic acid in end-shift urine). The mean reported values of benzene exposure were 0.014 ppm, 101 µg/g creatinine, and 2.8 µg/g creatinine for benzene, trans,trans-muconic acid, and S-phenylmercapturic acid, respectively (Carrieri et al. 2010). Another study assessed the occupational exposure of urban and rural female workers to benzene, toluene, and xylenes by monitoring urban air for traffic policewomen (street) versus police drivers (vehicle); monitoring urban air versus rural air; and biological monitoring of workers in urban areas versus rural areas (Ciarrocca et al. 2012). Mean personal air exposures to benzene over an 8-hour sampling period were similar for urban street (16.7 µg/m^3^) and vehicle workers (18.7 µg/m^3^), but were reported to be higher when compared to rural workers (less than the limit of detection [LOD] of 1.6 µg/m^3^). Mean blood and urine levels of benzene, and trans,transmuconic acid and S-phenylmercapturic acid, respectively, were similar among the street (244.4 ng/L, 62.0 µg/g creatinine, 3.5 µg/g creatinine) and vehicle workers (241.1 ng/L, 61.8 µg/g creatinine, 3.4 µg/g creatinine), but blood levels of benzene were higher in urban workers compared to rural workers (113.1 ng/L, 40.8 µg/g creatinine, 2.8 µg/g creatinine) (Ciarrocca et al. 2012). In a study measuring the mean benzene exposure in 33 petrochemical plant workers, 30 small town residents 2 km from the plant, 26 small town residents 2–4 km from the plant, and 54 urban residents 25 km from the plant, measured median personal air benzene concentrations were 25, 9, 7, and 6 µg/m^3^, respectively, while median urinary metabolite concentrations were 236, 48, 63, and 120 ng/L and 692, 470, 421, and 1,090 ng/L, for nonsmokers and smokers, respectively (Fustinoni et al. 2012).

A study determined benzene exposure in 33 petrochemical industry operators (PIOs), 28 service station attendants (SSAs), 21 gasoline pump maintenance workers (GPMWs), and 51 nonexposed controls by measuring personal air concentrations and benzene metabolites, trans,trans-muconic acid and S-phenylmercapturic acid, in end-of-shift urine samples (Fracasso et al. 2010). The levels of benzene (in µg/m^3^) in personal air for PIOs, SSAs, GPMWs, and controls were 1.7–593.50 (median 27.8), 8.00–260.00 (median 40.00), 4.60–514.90 (median 24.20), and 1.97–16.3 (median 5.40), respectively. Urinary levels of metabolites (in µg/g creatinine), trans,trans-muconic acid and S-phenylmercapturic acid, in PIOs, SSAs, GPMWs, and controls were 49.00–422.00 (median 128.00) and 0.40–35.60 (median 8.60), 30.00–418.00 (median 117.00) and 1.55–15.00 (median 5.55), 13.40–242.50 (median 92.00) and 0.21–10.53 (median 1.77), and 3.00–460.50 (median 84.00) and 0.30–10.08 (median 1.90), respectively. The results show that in all groups of workers, the level of personal air exposure to benzene was higher than the control groups, while the level of urinary metabolites was higher in the SSA and PIO groups compared to the control. No increase in urinary metabolites was measured in GPMWs, but it was noted that for these workers, benzene exposure was not continuous and only occurred on specific days.

### 6.6 EXPOSURES OF CHILDREN

Lagorio et al. (2013) conducted a study in Italy assessing the exposure of benzene to children by repeated weekly measurements in breathing zone and ambient outdoor air samples along with determination of cotinine, trans,trans-muconic acid, and S-phenylmercapturic acid in urine. In 108 children, all between the ages of 2 and 12 years, the average benzene concentrations in personal and outdoor air samples were reported as 3 and 2.7 µg/m^3^ (0.92 and 0.81 ppb), respectively. The average urinary cotinine, trans,trans-muconic acid, and S-phenylmercapturic acid concentrations were 3.73, 116.65, and 1.28 µg/g creatinine, respectively.

### 6.7 POPULATIONS WITH POTENTIALLY HIGH EXPOSURES

In a study measuring the mean benzene exposure by monitoring urinary benzene excretion in 33 petrochemical plant workers, 30 small town residents 2 km from the plant, 26 small town residents 2–4 km from the plant, and 54 urban residents 25 km from the plant, nonsmokers had median urinary benzene concentrations of 236, 48, 63, and 120 ng/L, respectively, while smokers had median concentrations of 692, 470, 421, and 1,090 ng/L, respectively (Fustinoni et al. 2012).

A study compared the urinary benzene metabolite, trans,trans-muconic acid, between smokers and nonsmokers among 81 ceramic factory workers exposed to low levels of benzene and 83 general population controls (Ibrahim et al. 2014). Among the factory workers, 26 smokers had an average urinary trans,trans-muconic acid concentration of 0.252 mg/g creatinine, while 55 nonsmokers had an average of 0.183 mg/g creatinine. In the nonexposed control group, 25 smokers had an average urinary trans,trans-muconic acid concentration of 0.043 mg/g creatinine, while 58 nonsmokers had an average of 0.035 mg/g creatinine.

## 7 ANALYTICAL METHODS

### 7.1 BIOLOGICAL SAMPLES

A method for detecting benzene, toluene, ethylbenzene, and xylenes in environmental waste water and human hair samples using hollow fiber solid-phase microextraction (SPME) containing carbon nanotube reinforced sol-gel followed by gas chromatography (GC)/flame ionization analysis was described (Es’haghi et al. 2011). The LOD for benzene using this method was reported as 0.7 ng/L (5.2% relative standard deviation [RSD] and 87% recovery for five samples) for human hair.

Gagne (2013) described a method for detecting benzene metabolite, trans,trans-muconic acid, in the urine of workers exposed to benzene using ultra-performance liquid chromatography (UPLC) coupled with tandem mass spectrometry (MS/MS). In this method, urine samples can be diluted and injected directly into the system instead of using a solid-phase extraction (SPE) procedure to prepare the sample. The LOD was reported as 69.6 µg/L (precision of 98%).

### 7.2 ENVIRONMENTAL SAMPLES

Bianchin et al. (2012) described a method using SPME followed by GC-MS separation and detection for determining polycyclic aromatic hydrocarbons and benzene, toluene, ethylbenzene, and xylene isomers in water simultaneously. This SPME technique uses an optimized fiber coating (PDMS/DVB 65 µm) and careful combination of extraction time, temperature, and extraction mode in order to maximize the extraction of both semivolatile and volatile compounds. The final method proceeds using direct immersion extraction for 48 minutes at 80°C, followed by headspace extraction for 32 minutes at 10°C. The LOD for benzene is 0.15 µg/L (1.7% RSD for five samples of 1 µg/L).

A method for detecting benzene, toluene, ethylbenzene, and xylenes in environmental waste water and human hair samples using hollow fiber solid phase microextraction containing carbon nanotube reinforced sol-gel followed by GC/flame ionization analysis was described (Es’haghi et al. 2011). The LOD for benzene using this method was reported as 0.61 ng/L (4.1% RSD for five samples) for waste water.

A method for extracting benzene from various foodstuffs using distillation and isotope dilution headspace-GC with MS has been described (Vinci et al. 2010). The sample preparation involves distillation with the addition of a borate buffer solution (pH 11). The LOD for this method was ≤0.5 µg/L.

## 8 REGULATIONS AND ADVISORIES

Table 8-1 Regulations and Guidelines Applicable to Benzene

Agency | | Description | Information | Reference
[underlined: INTERNATIONAL]
Guidelines:
| IARC | Carcinogenicity classification | Group 1^a^ | IARC 2015
| WHO | Air quality guidelines | 6×10^−6^ unit risk | WHO 2010
| WHO | Drinking water quality guidelines | 0.01 mg/L^b^ | WHO 2011
[underlined: NATIONAL]
Regulations and guidelines:
a. | Air
a. | ACGIH | TLV (TWA) | 0.5 ppm^c^ | ACGIH 2014
a. | ACGIH | STEL | 2.5 ppm^c^ | ACGIH 2014
a. | AIHA | ERPGs | | AIHA 2014
a. | AIHA | ERPG-1 | 50 ppm | AIHA 2014
a. | AIHA | ERPG-2 | 150 ppm | AIHA 2014
a. | AIHA | ERPG-3 | 1000 ppm | AIHA 2014
a. | DOE | PACs | | DOE 2012
a. | DOE | PAC-1 | 52 ppm | DOE 2012
a. | DOE | PAC-2 | 800 ppm | DOE 2012
a. | DOE | PAC-3 | 4,000 ppm | DOE 2012
a. | EPA | Hazardous air pollutant | Yes | EPA 2013c
a. | EPA | AEGL-1^d^ | | EPA 2014b
a. | EPA | 10 minutes | 130 ppm | EPA 2014b
a. | EPA | 30 minutes | 73 ppm | EPA 2014b
a. | EPA | 60 minutes | 52 ppm | EPA 2014b
a. | EPA | 4 hours | 18 ppm | EPA 2014b
a. | EPA | 8 hours | 9.0 ppm | EPA 2014b
a. | EPA | AEGL-2^d^ | | EPA 2014b
a. | EPA | 10 minutes | 2,000 ppm^e^ | EPA 2014b
a. | EPA | 30 minutes | 1,100 ppm | EPA 2014b
a. | EPA | 60 minutes | 800 ppm | EPA 2014b
a. | EPA | 4 hours | 400 ppm | EPA 2014b
a. | EPA | 8 hours | 200 ppm | EPA 2014b
a. | EPA | AEGL-3^d^ | | EPA 2014b
a. | EPA | 3 – 10 minutes | 9,700 ppm^f^ | EPA 2014b
a. | EPA | 30 minutes | 5,600 ppm^e^ | EPA 2014b
a. | EPA | 60 minutes | 4,000 ppm^e^ | EPA 2014b
a. | EPA | 4 hours | 2,000 ppm^e^ | EPA 2014b
a. | EPA | 8 hours | 990 ppm | EPA 2014b
a. | NIOSH | REL (10-hour TWA) | 0.1 ppm^g^ | NIOSH 2015
a. | NIOSH | STEL (15-minute TWA) | 1.0 ppm^g^ | NIOSH 2015
a. | NIOSH | IDLH | 500 ppm^g^ | NIOSH 2015
a. | OSHA | PEL (8-hour TWA) for general industry | 1 ppm | OSHA 2013a, 2013b; 29 CFR 1910.1000; 29 CFR 1910.1028
a. | OSHA | STEL (15-minute TWA) for general industry | 5 ppm | OSHA 2013a, 2013b; 29 CFR 1910.1000; 29 CFR 1910.1028
a. | OSHA | PEL (8-hour TWA) | 10 ppm^h^ | OSHA 2013a, 2013b; 29 CFR 1910.1000; 29 CFR 1910.1028
a. | OSHA | Acceptable ceiling concentration | 25 ppm^h^ | OSHA 2013a, 2013b; 29 CFR 1910.1000; 29 CFR 1910.1028
a. | OSHA | Acceptable maximum peak above the acceptable ceiling concentration for an 8-hour shift (maximum duration is 10 minutes) | 50 ppm^h^ | OSHA 2013a, 2013b; 29 CFR 1910.1000; 29 CFR 1910.1028
a. | OSHA | PEL (8-hour TWA) for construction industry | 1 ppm | OSHA 2014a, 2014b; 29 CFR 1926.55, Appendix A; 29 CFR 1926.1128
a. | OSHA | STEL(15-minute TWA) for construction industry | 5 ppm | OSHA 2014a, 2014b; 29 CFR 1926.55, Appendix A; 29 CFR 1926.1128
a. | OSHA | PEL (8-hour TWA) for shipyard industry | 1 ppm | OSHA 2014c,2014d; 29 CFR 1915.1000; 29 CFR 1915.1028
a. | OSHA | STEL(15-minute TWA) for shipyard industry | 5 ppm | OSHA 2014c,2014d; 29 CFR 1915.1000; 29 CFR 1915.1028
b. | Water
b. | EPA | Designated as hazardous substances in accordance with Section 311(b)(2)(A) of the Clean Water Act | Yes | EPA 2013d; 40 CFR 116.4
b. | EPA | Drinking water health advisories | | EPA 2012
b. | EPA | 1-day health advisory for a 10-kg child | 0.2 mg/L | EPA 2012
b. | EPA | 10-day health advisory for a 10-kg child | 0.2 mg/L | EPA 2012
b. | EPA | RfD | 0.004 mg/kg/day | EPA 2012
b. | EPA | DW EL | 0.1 mg/L | EPA 2012
b. | EPA | Life-time health advisory | 0.003 mg/L | EPA 2012
b. | EPA | 10^−4^ Cancer risk | 1 – 10 mg/L | EPA 2012
b. | EPA | Cancer descriptor | H^i^ | EPA 2012
b. | EPA | National primary drinking water standards | | EPA 2009
b. | EPA | MCLG | Zero | EPA 2009
b. | EPA | MCL | 0.005 mg/L | EPA 2009
b. | EPA | Reportable quantities of hazardous substances designated pursuant to Section 311 of the Clean Water Act | 10 pounds | EPA 2013e; 40 CFR 117.3
b. | EPA | Water quality criteria for human health consumption of: | | EPA 2013f
b. | EPA | Water + organism | 2.2 µg/L^j^ | EPA 2013f
b. | EPA | Organism only | 51 µg/L^j^ | EPA 2013f
b. | EPA | Water + organism | 0.45–1.6 µg/L^k^ | EPA 2014c
b. | EPA | Organism only | 6.2–23 µg/L^k^ | EPA 2014c
c. | Food
c. | FDA | Bottled drinking water | 0.005 mg/L | FDA 2004; 21 CFR 165.110
d. | Other
d. | ACGIH | Carcinogenicity classification | A1^l^ | ACGIH 2014
d. | ACGIH | Biological exposure indices (end of shift) | | ACGIH 2014
d. | ACGIH | S-phenylmercapturic acid in urine | 25 µg/g creatinine | ACGIH 2014
d. | ACGIH | Trans,trans-muconic acid in urine | 500 µg/g creatinine | ACGIH 2014
d. | EPA | Carcinogenicity classification | Group A^m^ | IRIS 2015
d. | EPA | Oral slope factor | 1.5×10^−2^ – 5.5×10^−2^ per (mg/kg)/day | IRIS 2015
d. | EPA | Inhalation unit risk | 2.2×10^−6^ – 7.8×10^−6^ per µg/m^3^ | IRIS 2015
d. | EPA | RfC | 3×10^−2^ mg/m^3^ | IRIS 2015
d. | EPA | RfD | 4×10^−3^ mg/kg/day | IRIS 2015
d. | EPA | Superfund, emergency planning, and community right-to-know | | IRIS 2015
d. | EPA | Designated CERCLA hazardous substance | | EPA 2014d; 40 CFR 302.4
d. | EPA | Reportable quantity | 10 pounds^n^ | EPA 2014d; 40 CFR 302.4
d. | EPA | RCRA hazardous waste number | U019 | EPA 2014d; 40 CFR 302.4
d. | EPA | Effective date of toxic chemical release reporting | 01/01/87 | EPA 2014e; 40 CFR 372.65
d. | EPA | Standards for the management of specific hazardous wastes | | EPA 2014f; 40 CFR 266 Appendix V
d. | EPA | Risk specific doses (10^−5^) | | EPA 2014f; 40 CFR 266 Appendix V
d. | EPA | Unit risk | 8.3×10^−6^ m^3^/µg | EPA 2014f; 40 CFR 266 Appendix V
d. | EPA | RsD | 1.2 µg/m^3^ | EPA 2014f; 40 CFR 266 Appendix V
d. | EPA | Health-based limits for exclusion of waste-derived residues | 5×10^−3^ mg/kg | EPA 2014g; 40 CFR 266 Appendix VII
d. | DHHS | Carcinogenicity classification | Known to be a human carcinogen | NTP 2014

a Group 1: carcinogenic to humans.

b For substances that are considered to be carcinogenic, the guideline value is the concentration in drinking water associated with an upper-bound excess lifetime cancer risk of 10^−5^ (1 additional cancer per 100,000 of the population ingesting drinking water containing the substance at the guideline value for 70 years). Concentrations associated with upper-bound estimated excess lifetime cancer risks of 10^−4^ and 10^−6^ can be calculated by multiplying and dividing, respectively, the guideline value by 10.

c Skin notation: refers to the potential significant contribution to the overall exposure by the cutaneous route, including mucous membranes and the eyes, either by contact with vapors or, of probable greater significance, by direct skin contact with the substance.

d AEGL-1 is the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience notable discomfort, irritation, or certain asymptomatic nonsensory effects. AEGL-2 is the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience irreversible or other serious, long-lasting adverse health effects or an impaired ability to escape. AEGL-3 is the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience life-threatening health effects or death.

e Values denoted as having safety considerations against the hazard of explosion, whereas the Lower Explosive Limit (LEL) =14,000 ppm and each value should be ≥10% LEL.

f Value denoted as having extreme safety considerations against the hazard of explosion must be taken into account, whereas the LEL =14,000 ppm and each value should be ≥50% LEL.

g NIOSH potential occupational carcinogen.

h This standard applies to the industry segments exempt from the 1 ppm 8-hour TWA and 5 ppm STEL of the benzene standard at 1910.1028.

i H: carcinogenic to humans.

j This criterion is based on carcinogenicity of 10^−6^ risk.

k EPA has updated its national recommended water quality criteria for human health for 94 chemical pollutants to reflect the latest scientific information and EPA policies. This is the draft update to the value for benzene on the human health criteria table.

l A1: confirmed human carcinogen.

m Group A: known human carcinogen.

n Designated CERCLA hazardous substance pursuant to Section 311(b)(2) and 307(a) of the Clean Water Act, Section 112 of the Clean Air Act, and Section 3001 of RCRA.

ACGIH = American Conference of Governmental Industrial Hygienists; AEGL = Acute Emergency Exposure Guideline Levels; AIHA = American Industrial Hygiene Association; CERCLA = Comprehensive Environmetnal Response, Compensation, and Liability Act; CFR = Code of Federal Regulations; DWEL = drinking water equivalent level; EPA = Environmental Protection Agency; ERPG = emergency response planning guidelines; FDA = Food and Drug Administration; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; MCL = maximum contaminant level; MCLG = maximum contaminant level goal; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PEL = permissible exposure limit; RCRA = Resource Conservation and Recovery Act; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; RsD = risk specific dose; STEL = short-term expsoure limit; TLV = threshold limit values; TWA = time-weighted average; USC = United States Code; WHO = World Health Organization

## 9 REFERENCES

ACGIH. 2014. Benzene. Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists, 13.
Adami G, Larese F, Venier M, . 2006. Penetration of benzene, toluene and xylenes contained in gasolines through human abdominal skin in vitro. Toxicol in Vitro 20(8):1321–1330.16829017
Agency for Toxic Substances Disease Registry. 2007. Toxicological profile for benzene (update). USA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry, Division of Toxicology/Toxicology Information Branch. http://www.atsdr.cdc.gov/toxprofiles/tp3.pdf. March 10, 2015.
AIHA. 2014. Current ERPG Values (2014). Fairfax, VA: American Industrial Hygiene Association. https://www.aiha.org/get-involved/AIHAGuidelineFoundation/EmergencyResponsePlanningGuidelines/Documents/2014%20ERPG%20Values.pdf. March 4, 2015.
Alexander DD, Wagner ME. 2010. Benzene exposure and non-Hodgkin lymphoma: A meta-analysis of epidemiologic studies. J Occup Environ Med 52(2):169–189.20134348
Bai W, Chen Y, Yang J, . 2014a. Aberrant miRNA profiles associated with chronic benzene poisoning. Exp Mol Pathol 96(3):426–430. 10.1016/j.yexmp.2014.04.011.24780745
Bai W, Yang J, Yang G, . 2014b. Long non-coding RNA NR_045623 and NR_028291 involved in benzene hematotoxicity in occupationally benzene-exposed workers. Exp Mol Pathol 96(3):354–360. 10.1016/j.yexmp.2014.02.016.24613687
Bassig B, Friesen MC, Vermeulen R, . 2014. Occupational exposure to benzene and risk of non-Hodgkin lymphoma in a population-based cohort study of Chinese women in Shanghai. Occup Environ Med 71 Suppl 1:A40–41.
Bianchin JN, Nardini G, Merib J, . 2012. Simultaneous determination of polycyclic aromatic hydrocarbons and benzene, toluene, ethylbenzene and xylene in water samples using a new sampling strategy combining different extraction modes and temperatures in a single extraction solid-phase microextraction-gas chromatography-mass spectrometry procedure. J Chromatogr A 1233:22–29.22386255
Billet S, Paget V, Garcon G, . 2010. Benzene-induced mutational pattern in the tumour suppressor gene TP53 analysed by use of a functional assay, the functional analysis of separated alleles in yeast, in human lung cells. Arch Toxicol 84(2):99–107.19862502
Bird MG, Wetmore BA, Letinski DJ, . 2010. Influence of toluene co-exposure on the metabolism and genotoxicity of benzene in mice using continuous and intermittent exposures. Chem Biol Interact 184(1–2):233–239.20079720
Bogen KT, Sheehan PJ. 2014. Dermal versus total uptake of benzene from mineral spirits solvent during parts washing. Risk Anal 34(7):1336–1358.24495022
Brandao MM, Rego MA, Pugliese L, . 2005. Phenotype analysis of lymphocytes of workers with chronic benzene poisoning. Immunol Lett 101(1):65–70.15913788
Bulka C, Nastoupil LJ, McClellan W, . 2013. Residence proximity to benzene release sites is associated with increased incidence of non-Hodgkin lymphoma. Cancer 119(18):3309–3317.23896932
Carrieri M, Tranfo G, Pigini D, . 2010. Correlation between environmental and biological monitoring of exposure to benzene in petrochemical industry operators. Toxicol Lett 192(1):17–21.19628029
Chanvaivit S, Navasumrit P, Hunsonti P, . 2007. Exposure assessment of benzene in Thai workers, DNA-repair capacity and influence of genetic polymorphisms. Mutat Res 626(1–2):79–87. 10.1016/j.mrgentox.2006.09.007.17095285
Chatterjee A, Babu RJ, Ahaghotu E, . 2005. The effect of occlusive and unocclusive exposure to xylene and benzene on skin irritation and molecular responses in hairless rats. Arch Toxicol 79(5):294–301.15902427
Ciarrocca M, Tomei G, Fiaschetti M, . 2012. Assessment of occupational exposure to benzene, toluene and xylenes in urban and rural female workers. Chemosphere 87(7):813–819.22297198
Cole CE, Tran HT, Schlosser PM. 2001. Physiologically based pharmacokinetic modeling of benzene metabolism in mice through extrapolation from in vitro to in vivo. J Toxicol Environ Health A 62(6):439–465.11289318
DOE. 2012. Table 3: Protective action criteria (PAC) Rev 27 based on applicable 60-minute AEGLs, ERPGs, or TEELs (Chemicals listed by CASRN). Oak Ridge, TN: U.S. Department of Energy and Subcommittee on Consequence Assessment and Protective Actions (SCAPA). http://www.atlintl.com/DOE/teels/teel/Table3.pdf. March 4, 2015.
Emara AM, El-Bahrawy H. 2008. Green tea attenuates benzene-induced oxidative stress in pump workers. J Immunotoxicol 5(1):69–80.18382860
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency, Office of Environmental Information.
EPA. 2009. National primary drinking water regulations. Washington, DC: Office of Ground Water and Drinking Water, U.S. Environmental Protection Agency. EPA816F090004. http://water.epa.gov/drink/contaminants/upload/mcl-2.pdf. March 4, 2015.
EPA. 2011. 1999 National-scale air toxics assessment: 1999 Data tables. Technology transfer network. 1996 National-scale air toxics assessment. U.S. Environmental Protection Agency. http://epa.gov/ttn/atw/nata1999/tables.html. March 12, 2015.
EPA. 2012. 2012 Edition of the drinking water standards and health advisories. Washington, DC: Office of Water, U.S. Environmental Protection Agency. EPA822S12001. http://water.epa.gov/action/advisories/drinking/upload/dwstandards2012.pdf. March 4, 2015.
EPA. 2013a. National air toxics assessments. Technology transfer network. AIr toxics web site. U.S. Environmental Protection Agency. http://epa.gov/ttn/atw/natamain/index.html. January 28, 2015.
EPA. 2013b. The 2011 National Emissions Inventory. U.S. Environmental Protection Agency. http://www.epa.gov/ttn/chief/net/2011inventory.html. January 9, 2015.
EPA. 2013c. The Clean Air Act amendments of 1990 list of hazardous air pollutants. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/ttn/atw/orig189.html. March 4, 2015.
EPA. 2013d. Designation of hazardous substances. Table 116.4A-list of hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 116.4. http://www.gpo.gov/fdsys/pkg/CFR-2014-title40-vol22/pdf/CFR-2014-title40-vol22-sec116-4.pdf. March 4, 2015.
EPA. 2013e. Determination of reportable quantities for hazardous substances. Table 117.3-Reportable quantities of hazardous substances designated pursuant to Section 311 of the Clean Water Act. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 117.3. http://www.gpo.gov/fdsys/pkg/CFR-2014-title40-vol22/pdf/CFR-2014-title40-vol22-sec117-3.pdf. March 4, 2015.
EPA. 2013f. National recommended water quality criteria. Washington, DC: Office of Water, Office of Science and Technology, U.S. Environmental Protection Agency. http://water.epa.gov/scitech/swguidance/standards/criteria/current/index.cfm. January 8, 2014.
EPA. 2014a. Technology transfer network (TTN). Air quality system (AQS). Air data. U.S. Environmental Protection Agency. http://aqsdr1.epa.gov/aqsweb/aqstmp/airdata/download_files.html#Annual. September 15, 2014.
EPA. 2014b. Final AEGLs (162). Washington, DC: Office of Pollution Prevention and Toxics, U.S. Environmental Protection Agency. http://www.epa.gov/oppt/aegl/pubs/compiled_aegls_update_03oct2014.pdf. March 4, 2015.
EPA. 2014c. Draft: Updated National recommended water quality criteria-human health. Washington, DC: Office of Water, Office of Science and Technology, U.S. Environmental Protection Agency. http://water.epa.gov/scitech/swguidance/standards/criteria/current/hhdraft.cfm. March 4, 2015.
EPA. 2014d. Designation, reportable quantities, and notifications. Designation of hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 302.4, Subchapter J. http://www.gpo.gov/fdsys/pkg/CFR-2014-title40-vol28/pdf/CFR-2014-title40-vol28-sec302-4.pdf. March 4, 2015.
EPA. 2014e. Toxic chemical release reporting: Community right-to-know. Subpart D-Specific toxic chemical listings. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 372.65. http://www.gpo.gov/fdsys/pkg/CFR-2014-title40-vol28/pdf/CFR-2014-title40-vol28-sec372-65.pdf. March 4, 2015.
EPA. 2014f. Standards for the management of specific hazardous wastes and specific types of hazardous waste facilities. Appendix V - Risk specific doses (10−5). U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 266. http://www.gpo.gov/fdsys/pkg/CFR-2014-title40-vol27/pdf/CFR-2014-title40-vol27-part266-appV.pdf. March 4, 2015.
EPA. 2014g. Solid wastes. Standards for the management of specific hazardous wastes and specific types of hazardous waste facilities. Appendix VII - Health-based limits for exclusion of waste-derived residues. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 266. http://www.gpo.gov/fdsys/pkg/CFR-2014-title40-vol27/pdf/CFR-2014-title40-vol27-part266-appVII.pdf. March 4, 2015.
EPA. 2015. The ASPEN Model. Technology transfer network. 1996 National-scale air toxics assessment. U.S. Environmental Protection Agency. http://epa.gov/ttn/atw/nata/aspen.html January 28, 2015.
Es’haghi Z, Ebrahimi M, Hosseini M-S. 2011. Optimization of a novel method for determination of benzene, toluene, ethylbenzene, and xylenes in hair and waste water samples by carbon nanotubes reinforced sol-gel based hollow fiber solid phase microextraction and gas chromatography using factorial experimental design. J Chromatogr A 1218:3400–3406.21489540
FDA. 2014. Food for human consumption. Requirements for specific standardized beverages. Bottled water. Food and Drug Administration, Department of Health and Human Services. Code of Federal Regulations 21 CFR 165.110, Subpart B. http://www.gpo.gov/fdsys/pkg/CFR-2014-title21-vol2/pdf/CFR-2014-title21-vol2-sec165-110.pdf. March 4, 2015.
Fent KW, Eisenberg J, Snawder J, . 2014. Systemic exposure to PAHs and benzene in firefighters suppressing controlled structure fires. Ann Occup Hyg 58(7):830–845.24906357
Fracasso ME, Doria D, Bartolucci GB, . 2010. Low air levels of benzene: Correlation between biomarkers of exposure and genotoxic effects. Toxicol Lett 192(1):22–28.19427373
Fustinoni S, Campo L, Satta G, . 2012. Environmental and lifestyle factors affect benzene uptake biomonitoring of residents near a petrochemical plant. Environ Int 39(1):2–7.22208737
Gagne S. 2013. Determination of trans,trans-muconic acid in workers’ urine through ultra-performance liquid chromatography coupled to tandem mass spectrometry. Biomed Chromatogr 27(5):664–668.23225372
Garte S, Popov T, Georgieva T, . 2005. Biomarkers of exposure and effect in Bulgarian petrochemical workers exposed to benzene. Chem Biol Interact 153–154:247–251.
Garte S, Taioli E, Popov T, . 2008. Genetic susceptibility to benzene toxicity in humans. J Toxicol Environ Health A 71(22):1482–1489 18836923
George BJ, Schultz BD, Palma T, . 2011. An evaluation of EPA’s National-Scale Air Toxics Assessment (NATA): Comparison with benzene measurements in Detroit, Michigan. Atmos Environ 45:3301–3308.
Glass DC, Gray CN, Jolley DJ, . 2003. Leukemia risk associated with low-level benzene exposure. Epidemiology 14(5):569–577.14501272
Glass DC, Schnatter AR, Tang G, . 2014. Risk of myeloproliferative disease and chronic myeloid leukaemia following exposure to low-level benzene in a nested case-control study of petroleum workers. Occup Environ Med 71(4):266–274.24532441
Gross SA, Irons RD, Scott PK, . 2012. A case-control study of chronic myelomonocytic leukemia (CMML) in Shanghai, China: Evaluation of risk factors for CMML, with special focus on benzene. Arch Environ Occup Health 67(4):206–218.23074978
Gu SY, Zhang ZB, Wan JX, . 2007. Genetic polymorphisms in CYP1A1, CYP2D6, UGT1A6, UGT1A7, and SULT1A1 genes and correlation with benzene exposure in a Chinese occupational population. J Toxicol Environ Health A 70(11):916–924.17479406
Hirabayashi Y, Inoue T. 2010. Benzene-induced bone-marrow toxicity: A hematopoietic stem-cell-specific, aryl hydrocarbon receptor-mediated adverse effect. Chem Biol Interact 184(1–2):252–258.20035730
Hirabayashi Y, Yoon BI, Li GX, . 2008. Benzene-induced hematopoietic toxicity transmitted by AhR in wild-type mouse and nullified by repopulation with AhR-deficient bone marrow cells: Time after benzene treatment and recovery. Chemosphere 73(1 Suppl):S290–S294.18514254
Hoet P, De Smedt E, Ferrari M, . 2009. Evaluation of urinary biomarkers of exposure to benzene: Correlation with blood benzene and influence of confounding factors. Int Arch Occup Environ Health 82(8):985–995.19009306
Hoffmann MJ, Ji S, Hedli CC, . 1999. Metabolism of [^14^C]phenol in the isolated perfused mouse liver. Toxicol Sci 49(1):40–47.10367340
Hosgood HD, 3rd, Zhang L, Shen M, . 2009. Association between genetic variants in VEGF, ERCC3 and occupational benzene haematotoxicity. Occup Environ Med 66(12):848–853. Nihms227952.19773279
Hui X, Wester RC, Barbadillo S, . 2009a. In vitro percutaneous absorption of benzene in human skin. (Erratum in: Cutan Ocul Toxicol 28:191). Cutan Ocul Toxicol 28(2):65–70.19514929
Hui X, Wester RC, Barbadillo S, . 2009b. In vitro percutaneous absorption of benzene in human skin. (Erratum to: Cutan Ocul Toxicol 28(2):65-70). Cutan Ocul Toxicol 28:191.
IARC. 1982. Benzene. In: IARC monographs on the evaluation of the carcinogenic risk of chemicals to humans. Volume 29: Some industrial chemicals and dyestuffs. Lyon, France: World Health Organization, International Agency for Research on Cancer, 93–148.
IARC. 1987. IARC monographs on the evaluation of carcinogenic risks to humans. Overall evaluations of carcinogenicity: An updating of IARC monographs Volumes 1 to 42. Lyons, France: International Agency for Research on Cancer, 38–74.
IARC. 2012. Benzene. In: Chemical agents and related occupations. IARC Monographs on the Evaluation of Carcinogenic Risks to Humans. Vol. 100F. International Agency for Research on Cancer, 249–294. http://monographs.iarc.fr/ENG/Monographs/vol100F/mono100F-24.pdf. January 20, 2015.
IARC. 2015. Agents classified by the IARC monographs. Volumes 1–111. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Classification/ClassificationsCASOrder.pdf. March 4, 2015.
Ibrahim KS, Amer NM, El-Dossuky EA, . 2014. Hematological effect of benzene exposure with emphasis of muconic acid as a biomarker. Toxicol Ind Health 30(5):467–474.22933555
Ingelman-Sundberg M, Johansson I, Penttila KE, . 1988. Centrilobular expression of ethanol-inducible cytochrome P-450 (IIE1) in rat liver. Biochem Biophys Res Commun 157(1):55–60.2904264
IRIS. 2008. Benzene (CASRN 71-43-2). Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/iris/subst/0276.htm. March 4, 2015.
Ji Z, Weldon RH, Marchetti F, . 2012. Comparison of aneuploidies of chromosomes 21, X, and Y in the blood lymphocytes and sperm of workers exposed to benzene. Environ Mol Mutagen 53(3):218–226.22351378
Kane EV, Newton R. 2010. Benzene and the risk of non-Hodgkin lymphoma: A review and meta-analysis of the literature. Cancer Epidemiol 34(1):7–12.20075019
Katukam V, Kulakarni M, Syed R, . 2012. Effect of benzene exposure on fertility of male workers employed in bulk drug industries. Genet Test Mol Biomarkers 16(6):592–597.22304538
Kim YJ, Choi JY, Cho YH, . 2010. Micronucleus-centromere assay in workers occupationally exposed to low level of benzene. Hum Exp Toxicol 29(5):343–350. 10.1177/0960327110361500.20129955
Kim S, Lan Q, Waidyanatha S, . 2007. Genetic polymorphisms and benzene metabolism in humans exposed to a wide range of air concentrations. Pharmacogenet Genomics 17(10):789–801.17885617
Kim S, Vermeulen R, Waidyanatha S, . 2006. Using urinary biomarkers to elucidate dose-related patterns of human benzene metabolism. Carcinogenesis 27(4):772–781.16339183
Kirkeleit J, Ulvestad E, Riise T, . 2006. Acute suppression of serum IgM and IgA in tank workers exposed to benzene. Scand J Immunol 64(6):690–698.17083627
Knutsen JS, Kerger BD, Finley B, . 2013a. A calibrated human PBPK model for benzene inhalation with urinary bladder and bone marrow compartments. Risk Anal 33(7):1237–1251.23278103
Knutsen JS, Kerger BD, Finley B, . 2013b. Supporting information to “A calibrated human PBPK model for benzene inhalation with urinary bladder and bone marrow compartments” (Risk Anal 33(7):1237–1251). Risk Anal http://onlinelibrary.wiley.com/store/10.1111/j.1539-6924.2012.01927.x/asset/supinfo/risa1927-sup-0001-suppmat.docx?v=1&s=3521db6fd867880e3a455b5c4cf57f1a5601c814. January 6, 2015.23278103
Koop DR, Laethem CL, Schnier GG. 1989. Identification of ethanol-inducible P450 isozyme 3a (P450IIE1) as a benzene and phenol hydroxylase. Toxicol Appl Pharmacol 98(2):278–288.2711391
Kowalówka-Zawieja J, Zielinska-Psuja B, Przystanowicz J, . 2013. Influence of acetylsalicylic acid on hematotoxicity of benzene. Int J Occup Med Environ Health 26(5):802–812.24249093
Kumar A, Sushama A, Rohil V, . 2011. Prevention of benzene-induced genotoxicity in bone marrow and lung cells: Superiority of polyphenolic acetates to polyphenols. Arch Toxicol 85(9):1141–1150.21267547
Lagorio S, Ferrante D, Ranucci A, . 2013. Exposure to benzene and childhood leukaemia: A pilot case-control study. BMJ open 3(2).
Lan Q, Zhang L, Hakim F, . 2005. Lymphocyte toxicity and T cell receptor excision circles in workers exposed to benzene. Chem Biol Interact 153–154:111–115.
Lau A, Belanger CL, Winn LM. 2009. In utero and acute exposure to benzene: Investigation of DNA double-strand breaks and DNA recombination in mice. Mutat Res 676(1–2):74–82.19486867
Lee EH, Eum KD, Cho SI, . 2007. Acquired dyschromatopsia among petrochemical industry workers exposed to benzene. Neurotoxicology 28(2):356–363.16806479
Li B, Li YQ, Yang LJ, . 2009. Decreased T-cell receptor excision DNA circles in peripheral blood mononuclear cells among benzene-exposed workers. Int J Immunogenet 36(2):107–111.19228219
Lipscomb JC, Teuschler LK, Swartout J, . 2003. The impact of cytochrome P450 2E1-dependent metabolic variance on a risk-relevant pharmacokinetic outcome in humans. Risk Anal 23(6):1221–1238.14641897
Lipscomb JC, Teuschler LK, Swartout JC, . 2003. Variance of Microsomal Protein and Cytochrome P450 2E1 and 3A Forms in Adult Human Liver. Toxicol Mech Methods 13(1):45–51.20021182
Lovern MR, Maris ME, Schlosser PM. 1999. Use of a mathematical model of rodent in vitro benzene metabolism to predict human in vitro metabolism data. Carcinogenesis 20(8):1511–1520.10426800
Lovreglio P, Barbieri A, Carrieri M, . 2010. Validity of new biomarkers of internal dose for use in the biological monitoring of occupational and environmental exposure to low concentrations of benzene and toluene. Int Arch Occup Environ Health 83:341–356.19830448
Lovreglio P, D’Errico MN, Fustinoni S, . 2011. Biomarkers of internal dose for the assessment of environmental exposure to benzene. J Environ Monit 13(10):2921–2928.21909569
Lupo PJ, Symanski E, Waller DK, . 2011. Maternal exposure to ambient levels of benzene and neural tube defects among offspring: Texas, 1999-2004. Environ Health Perspect 119(3):397–402.20923742
Lv BH, Song SZ, Zhang Z, . 2014. Urinary S-phenylmercapturic acid as a key biomarker for measuring occupational exposure to low concentrations of benzene in Chinese workers: A pilot study. J Occup Environ Med 56(3):319–325.24561506
Manning CC, Schlosser PM, Tran HT. 2010. A multicompartment liver-based pharmacokinetic model for benzene and its metabolites in mice. Bull Math Biol 72(3):507–540.20041354
Marchetti F, Eskenazi B, Weldon RH, . 2012. Occupational exposure to benzene and chromosomal structural aberrations in the sperm of Chinese men. Environ Health Perspect 120(2):229–234.22086566
McHale CM, Lan Q, Corso C, . 2008. Chromosome translocations in workers exposed to benzene. J Natl Cancer Inst Monogr (39):74–77.18648008
Medeiros Vinci R, Jacxsens L, Van Loco J, . 2012. Assessment of human exposure to benzene through foods from the Belgian market. Chemosphere 88(8):1001–1007.22483726
Medinsky MA, Sabourin PJ, Lucier G, . 1989. A physiological model for simulation of benzene metabolism by rats and mice. Toxicol Appl Pharmacol 99(2):193–206.2734786
Modjtahedi BS, Maibach HI. 2008. In vivo percutaneous absorption of benzene in man: Forearm and palm. Food Chem Toxicol 46(3):1171–1174.18191010
NIOSH. 2015. Benzene. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. http://www.cdc.gov/niosh/npg/npgd0049.html. March 4, 2015.
NTP. 2007. NTP report on the toxicology and carcinogenesis study of benzene (CAS No. 71-43-2) in genetically modified haploinsufficient p16^Ink4a^/p19^Arf^ mice (gavage study). National Toxicology Program. http://ntp.niehs.nih.gov/ntp/htdocs/gmm_rpts/gmm8.pdf. January 28, 2015.
NTP. 2014. Benzene CAS No. 71-43-2. 13th Report on carcinogens. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. http://ntp.niehs.nih.gov/ntp/roc/content/profiles/benzene.pdf. March 4, 2015.
Orsi L, Monnereau A, Dananche B, . 2010. Occupational exposure to organic solvents and lymphoid neoplasms in men: Results of a French case-control study. Occup Environ Med 67(10):664–672.20837648
OSHA. 2013a. Toxic and hazardous substances. Table Z-2. Occupational Safety and Health Standards. Code of Federal Regulations 29 CFR 1910.1000, Subpart Z. http://www.gpo.gov/fdsys/pkg/CFR-2014-title29-vol6/pdf/CFR-2014-title29-vol6-sec1910-1000.pdf. March 4, 2015.
OSHA. 2013b. Toxic and hazardous substances. Benzene. Occupational Safety and Health Standards. Code of Federal Regulations 29 CFR 1910.1028, Subpart Z. http://www.gpo.gov/fdsys/pkg/CFR-2014-title29-vol6/pdf/CFR-2014-title29-vol6-sec1910-1028.pdf. March 4, 2015.
OSHA. 2014a. Occupational health and environmental controls. Gases, vapors, fumes, dusts, and mists. Threshold limit values of airborne contaminants for construction. Occupational Safety and Health Standards. Code of Federal Regulations 29 CFR 1926.55 App A. http://www.gpo.gov/fdsys/pkg/CFR-2014-title29-vol8/pdf/CFR-2014-title29-vol8-sec1926-55.pdf. March 4, 2015.
OSHA. 2014b. Toxic and hazardous substances. Benzene. Occupational Safety and Health Standards. Code of Federal Regulations 29 CFR 1926.1128, Subpart Z. http://www.gpo.gov/fdsys/pkg/CFR-2014-title29-vol8/pdf/CFR-2014-title29-vol8-sec1926-1128.pdf. March 4, 2015.
OSHA. 2014c. Occupational safety and health standards for shipyard employment. Toxic and hazardous substances. Air contaminants. Table Z - Shipyards. Occupational Safety and Health Standards. Code of Federal Regulations 29 CFR 1915.1000, Subpart Z. http://www.gpo.gov/fdsys/pkg/CFR-2013-title29-vol7/pdf/CFR-2013-title29-vol7-sec1915-1000.pdf. March 4, 2015.
OSHA. 2014d. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Benzene. Occupational Safety and Health Standards. Code of Federal Regulations 29 CFR 1915.1028. http://www.gpo.gov/fdsys/pkg/CFR-2014-title29-vol7/pdf/CFR-2014-title29-vol7-sec1915-1028.pdf. March 4, 2015.
Pandey AK, Gurbani D, Bajpayee M, . 2009a. In silico studies with human DNA topoisomerase-II alpha to unravel the mechanism of in vitro genotoxicity of benzene and its metabolites. (Erratum in: Mutat Res 671:100). Mutat Res 661:57–70.19059273
Pandey AK, Gurbani D, Bajpayee M, . 2009b. In silico studies with human DNA topoisomerase-II alpha to unravel the mechanism of in vitro genotoxicity of benzene and its metabolites. (Erratum to: Mutat Res 661:57-70). Mutat Res 671:100.
Park HJ, Oh JH, Yoon S, . 2008. Time dependent gene expression changes in the liver of mice treated with benzene. Biomark Insights 3:191–201.19578504
Pekari K, Vainiotalo S, Heikkila P, . 1992. Biological monitoring of occupational exposure to low levels of benzene. Scand J Work Environ Health 18(5):317–322.1439659
Poulin P, Krishnan K. 1995. An algorithm for predicting tissue: blood partition coefficients of organic chemicals from n-octanol: Water partition coefficient data. J Toxicol Environ Health 46(1):117–129.7666490
Ramakrishnan A, Lupo PJ, Agopian AJ, . 2013. Evaluating the effects of maternal exposure to benzene, toluene, ethyl benzene, and xylene on oral clefts among offspring in Texas: 1999-2008. Birth Defects Res A Clin Mol Teratol 97(8):532–537. Nihms511822.23893927
RePORTER. 2014. Benzene. National Institutes of Health, Research Portfolio Online Reporting Tools. http://projectreporter.nih.gov/reporter.cfm. August 18, 2014.
Rothman N, Bechtold WE, Yin SN, . 1998. Urinary excretion of phenol, catechol, hydroquinone, and muconic acid by workers occupationally exposed to benzene. Occup Environ Med 55(10):705–711.9930093
Rowe BL, Toccalino PL, Moran MJ, . 2007. Occurrence and potential human-health relevance of volatile organic compounds in drinking water from domestic wells in the United States. Environ Health Perspect 115(11):1539–1546.18007981
Rushton L, Romaniuk H. 1997. A case-control study to investigate the risk of leukaemia associated with exposure to benzene in petroleum marketing and distribution workers in the United Kingdom. Occup Environ Med 54(3):152–166.9155776
Saha S, Mukhopadhyay MK, Ghosh PD, . 2012. Effect of methanolic leaf extract of Ocimum basilicum L. on benzene-induced hematotoxicity in mice. Evid Based Complement Alternat Med: eCAM 2012:176385.22988471
Schmid TE, Eskenazi B, Marchetti F, . 2006. Increased human DNA strand damage is associated with occupational exposure to benzene. Environ Mol Mutagen 47(6):418.
Schnatter AR, Armstrong TW, Nicolich MJ, . 1996. Lymphohaematopoietic malignancies and quantitative estimates of exposure to benzene in Canadian petroleum distribution workers. Occup Environ Med 53(11):773–781.9038803
Schnatter AR, Glass DC, Tang G, . 2012. Myelodysplastic syndrome and benzene exposure among petroleum workers: An international pooled analysis. J Natl Cancer Inst 104(22):1724–1737.23111193
Schnatter RA, Kerzic PJ, Zhou Y, . 2010. Peripheral blood effects in benzene-exposed workers. Chem Biol Interact 184(1–2):174–181.20034484
Seaton MJ, Schlosser P, Medinsky MA. 1995. In vitro conjugation of benzene metabolites by human liver: Potential influence of interindividual variability on benzene toxicity. Carcinogenesis 16(7):1519–1527.7614685
Sharma S, Rana SV. 2010. Melatonin inhibits benzene-induced lipid peroxidation in rat liver. Arhiv Za Higijenu Rada I Toksikologiju (Archives of Industrial Hygiene and Toxicology) 61(1):11–18.20338863
Shen M, Zhang L, Lee KM, . 2011. Polymorphisms in genes involved in innate immunity and susceptibility to benzene-induced hematotoxicity. Exp Mol Med 43(6):374–378.21540635
Singh MP, Reddy MM, Mathur N, . 2009. Induction of hsp70, hsp60, hsp83 and hsp26 and oxidative stress markers in benzene, toluene and xylene exposed Drosophila melanogaster: Role of ROS generation. Toxicol Appl Pharmacol 235(2):226–243.19118569
Singh RK, Bansode FW. 2011. Benzene-induced histopathological changes and germ cell population dynamics in testes of Sprague Dawley rats. J Environ Biol 32(6):687–694.22471202
Sun P, Qian J, Zhang ZB, . 2008. Polymorphisms in phase I and phase II metabolism genes and risk of chronic benzene poisoning in a Chinese occupational population. Carcinogenesis 29(12):2325–2329.18784359
Sun P, Qiu Y, Zhang Z, . 2009a. Association of genetic polymorphisms, mRNA expression of p53 and p21 with chronic benzene poisoning in a Chinese occupational population. Cancer Epidemiol Biomarkers Prev 18(6):1821–1828.19505915
Sun P, Zhang Z, Wan J, . 2009b. Association of genetic polymorphisms in GADD45A, MDM2, and p14^ARF^ with the risk of chronic benzene poisoning in a Chinese occupational population. Toxicol Appl Pharmacol 240(1):66–72.19596022
Sun P, Zhang Z, Wu F, . 2007. Association of the genetic polymorphism of EPHX1 and EPHX2 with the susceptibility to chronic benzene poisoning. Front Med China 1(3):320–326.24573875
Swaen GM, van Amelsvoort L, Twisk JJ, . 2010. Low level occupational benzene exposure and hematological parameters. Chem Biol Interact 184(1–2):94–100.20074561
TRI13 2014. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access. Office of Environmental Information. U.S. Environmental Protection Agency. Toxics Release Inventory. http://www.epa.gov/triexplorer/. November 4, 2014.
Tsutsumi M, Lasker JM, Shimizu M, . 1989. The intralobular distribution of ethanol-inducible P450IIE1 in rat and human liver. Hepatology 10(4):437–446.2673969
Tunsaringkarn T, Suwansaksri J, Soogarun S, . 2011. Genotoxic monitoring and benzene exposure assessment of gasoline station workers in metropolitan Bangkok: Sister chromatid exchange (SCE) and urinary trans, trans-muconic acid (t,t-MA). Asian Pacific J Cancer Prev 12(1):223–227.
USITC. 2014. HTS-270710: Benzene. First unit of quantity by country name and first unit of quantity for all countries. U.S. domestic exports. Annual data. http://dataweb.usitc.gov/. January 9, 2015.
Uzma N, Kumar B, Salar K, . 2008. In vitro and in vivo evaluation of toxic effect of benzene on lymphocytes and hepatocytes. Internet Scientific Publications 6(2). https://ispub.com/IJTO/6/2/7846. January 26, 2015.
Verma Y, Rana SV. 2008. Effects of progesterone on benzene toxicity in rats. Arh Hig Rada Toksikol 59(1):1–9.18407866
Vinci RM, Canfyn M, De Meulenaer B, . 2010. Determination of benzene in different food matrices by distillation and isotope dilution HS-GC/MS. Anal Chim Acta 672(1–2):124–129.20579500
Vlaanderen J, Lan Q, Kromhout H, . 2011. Occupational benzene exposure and the risk of lymphoma subtypes: A meta-analysis of cohort studies incorporating three study quality dimensions. Environ Health Perspect 119(2):159–167.20880796
Vlaanderen J, Lan Q, Kromhout H, . 2012. Occupational benzene exposure and the risk of chronic myeloid leukemia: A meta-analysis of cohort studies incorporating study quality dimensions. Am J Ind Med 55(9):779–785.22729623
Waidyanatha S, Rothman N, Li G, . 2004. Rapid determination of six urinary benzene metabolites in occupationally exposed and unexposed subjects. Anal Biochem 327(2):184–199.15051535
Wetmore BA, Struve MF, Gao P, . 2008. Genotoxicity of intermittent co-exposure to benzene and toluene in male CD-1 mice. Chem Biol Interact 173(3):166–178.18455711
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. September 9, 2014.
WHO. 2011. Guidelines for drinking-water quality. Geneva, Switzerland: World Health Organization. http://whqlibdoc.who.int/publications/2011/9789241548151_eng.pdf?ua=1. September 9, 2014.
Wu F, Zhang Z, Wan J, . 2008. Genetic polymorphisms in hMTH1, hOGG1 and hMYH and risk of chronic benzene poisoning in a Chinese occupational population. Toxicol Appl Pharmacol 233(3):447–453.18848840
Xing C, Marchetti F, Li G, . 2010. Benzene exposure near the U.S. permissible limit is associated with sperm aneuploidy. Environ Health Perspect 118(6):833–839.20418200
Yang J, Bai W, Niu P, . 2014. Aberrant hypomethylated STAT3 was identified as a biomarker of chronic benzene poisoning through integrating DNA methylation and mRNA expression data. Exp Mol Pathol 96(3):346–353. 10.1016/j.yexmp.2014.02.013.24613686
Yokley K, Tran HT, Pekari K, . 2006. Physiologically-based pharmacokinetic modeling of benzene in humans: A Bayesian approach. Risk Anal 26(4):925–943.16948686
Yoon BI, Hirabayashi Y, Kawasaki Y, . 2002. Aryl hydrocarbon receptor mediates benzene-induced hematotoxicity. Toxicol Sci 70(1):150–156.12388843
Yoon BI, Li GX, Kitada K, . 2003. Mechanisms of benzene-induced hematotoxicity and leukemogenicity: cDNA microarray analyses using mouse bone marrow tissue. Environ Health Perspect 111(11):1411–1420.12928149
Yu K, Yang KY, Ren XZ, . 2007. Amifostine protects bone marrow from benzene-induced hematotoxicity in mice. Int J Toxicol 26(4):315–323.17661222
Zahran S, Weiler S, Mielke HW, . 2012. Maternal benzene exposure and low birth weight risk in the United States: A natural experiment in gasoline reformulation. Environ Res 112:139–146.22177084
Zhang GH, Ye LL, Wang JW, . 2014. Effect of polymorphic metabolizing genes on micronucleus frequencies among benzene-exposed shoe workers in China. Int J Hyg Environ Health 217(7):726–732.24698387
Zhang J, Yin L, Liang G, . 2011a. Detection of CYP2E1, a genetic biomarker of susceptibility to benzene metabolism toxicity in immortal human lymphocytes derived from the Han Chinese Population. Biomed Environ Sci 24(3):300–309.21784317
Zhang L, Lan Q, Guo W, . 2005. Use of OctoChrome fluorescence in situ hybridization to detect specific aneuploidy among all 24 chromosomes in benzene-exposed workers. Chem Biol Interact 153–154:117–122.
Zhang L, Lan Q, Ji Z, . 2012. Leukemia-related chromosomal loss detected in hematopoietic progenitor cells of benzene-exposed workers. Leukemia 26(12):2494–2498.22643707
Zhang L, Rothman N, Li G, . 2007. Aberrations in chromosomes associated with lymphoma and therapy-related leukemia in benzene-exposed workers. Environ Mol Mutagen 48(6):467–474.17584886
Zhang L, Ye FL, Chen T, . 2011b. Trans, trans-muconic acid as a biomarker of occupational exposure to high-level benzene in China. J Occup Environ Med 53(10):1194–1198.21915070