# CONTRIBUTORS & REVIEWERS

## CHEMICAL MANAGER TEAM

- Nickolette Roney, M.P.H.
  ATSDR, Division of Toxicology and Human Health Sciences, Atlanta, GA
- Lisa Ingerman, Ph.D., DABT
  SRC, Inc., North Syracuse, NY