# VERSION HISTORY

Date | Description
December 1989 | Final toxicological profile released
November 2017 | Update of data in Chapters 2, 3, and 7