# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding BCME in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for BCME.

Table 7-1 Regulations and Guidelines Applicable to Bis(Chloromethyl)Ether

Agency | Description | Information | Reference
Air
EPA | RfC | No data | IRIS 2002
WHO | Air quality guidelines | No data | WHO 2010
Water & Food
EPA | Drinking water standards and health advisories | No data | EPA 2012
EPA | National primary drinking water regulations | No data | EPA 2009
EPA | RfD | No data | IRIS 2002
WHO | Drinking water quality guidelines | No data | WHO 2017
FDA | EAFUS | No data^a^ | FDA 2013
Cancer
ACGIH | Carcinogenicity classification | A1^b,c^ | ACGIH 2001, 2016
HHS | Carcinogenicity classification | Known to be a human carcinogen^d^ | NTP 2016
EPA | Carcinogenicity classification | Group A^e,f^ | IRIS 2002
IARC | Carcinogenicity classification | Group 1^g,h^ | IARC 2012, 2017
Occupational
ACGIH | TLV | 0.001 ppm (0.0047 mg/m^3^) | ACGIH 2001, 2016
OSHA | Requirements for areas containing a carcinogen | Does not pertain to solid or liquid mixtures containing <0.1% by weight or volume | OSHA 2016
NIOSH | REL | Potential occupational carcinogen | NIOSH 2016
Emergency Criteria
EPA | AEGLs-air | | EPA 2016
EPA | AEGL 1 | NR^i^ | EPA 2016
EPA | AEGL 2 | | EPA 2016
EPA | 10-minute | 0.055 ppm | EPA 2016
EPA | 30-minute | 0.055 ppm | EPA 2016
EPA | 60-minute | 0.044 ppm | EPA 2016
EPA | 4-hour | 0.028 ppm | EPA 2016
EPA | 8-hour | 0.020 ppm | EPA 2016
EPA | AEGL 3 | | EPA 2016
EPA | 10-minute | 0.23 ppm | EPA 2016
EPA | 30-minute | 0.23 ppm | EPA 2016
EPA | 60-minute | 0.18 ppm | EPA 2016
EPA | 4-hour | 0.11 ppm | EPA 2016
EPA | 8-hour | 0.075 ppm | EPA 2016
DOE | PACs-air | | DOE 2016a
DOE | PAC-1^j^ | 0.004 ppm | DOE 2016a
DOE | PAC-2^j^ | 0.044 ppm | DOE 2016a
DOE | PAC-3^j^ | 0.18 ppm | DOE 2016a

a The EAFUS list of substances contains ingredients added directly to food that FDA has either approved as food additives or listed or affirmed as GRAS.

b A1: confirmed human carcinogen.

c Based on pulmonary cancer and nasal tumors in experimental animal studies and among exposed workers.

d Based on sufficient evidence of carcinogenicity from studies in humans.

e Group A: human carcinogen.

f Based on statistically significant increases in lung tumors (oat cell carcinomas) observed in six studies of exposed workers and bioassay data from rats and mice.

g Group 1: carcinogenic to humans.

h Based on sufficient evidence in humans for cancer of the lung and sufficient evidence of carcinogenicity in experimental animals.

i NR = not recommended due to insufficient data.

j Definitions of PAC terminology are available from DOE (2016b).

ACGIH = American Conference of Governmental Industrial Hygienists; AEGL = acute exposure guideline levels; AIHA = American Industrial Hygiene Association; GRAS = generally recognized as safe; HHS = Department of Health and Human Services; DOE = Department of Energy; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; ERPG = emergency response planning guidelines; FDA = Food and Drug Administration; IARC = International Agency for Research on Cancer; IRIS = Integrated Risk Information System; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = Protective Action Criteria; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TLV = threshold limit values; WHO = World Health Organization