# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Table 4-1 lists common synonyms, trade names and other pertinent identification information for BCME.

Table 4-1 Chemical Identity of Bis(Chloromethyl)Ether

Characteristic | Information | Reference
Chemical name | Bis(chloromethyl)ether | NLM 1988
Synonym(s) and registered trade name(s) | Oxybis (chloromethane); dichlorodimethyl ether; monochloromethyl ether | NLM 1988
Chemical formula | C_2_H_4_Cl_2_O | Weast 1985
Chemical structure | [image]
Identification numbers:
CAS Registry | 542-88-1 | NLM 1988

CAS = Chemical Abstracts Services

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Table 4-2 lists important physical and chemical properties of BCME.

Table 4-2 Physical and Chemical Properties of Bis(Chloromethyl)Ether

Property | Information | Reference
Molecular weight | 114.96 | Weast 1985
Color | Colorless | Windholz 1983
Physical state | Liquid | Windholz 1983
Melting point | −41.5°C | Weast 1985
Boiling point | 104°C | Weast 1985
Density at 20°C | 1.328 | Weast 1985
Odor | No data
Odor threshold:
Water | No data
Air | No data
Solubility:
Water at 25°C | 22,000^a^ | Mabey et al. 1982
Organic solvents | Miscible | Weast 1985
Partition coefficients:
Log K_ow_ | −0.38^a^ | Mabey et al. 1982
Log K_oc_ | 0.08 | Mabey et al. 1982
Vapor pressure at 20°C | 30 | Mabey et al. 1982
Henry’s law constant at 25°C | 2.1×10^−4^ | Mabey et al. 1982
Autoignition temperature | No data
Flashpoint | 19°C | HSDB 1988
Flammability limits | No data
Conversion factors
ppm (v/v) to mg/m^3^ | 1 ppm=4.7 mg/m^3^ | ACGIH 1986
in air (20°C) | 1 mg/m^3^=0.21 ppm

a Calculated values. Due to the rapid hydrolysis of BCME in water, significant concentrations in water would not be expected to occur.