# APPENDIX B LITERATURE SEARCH FRAMEWORK FOR BCME

The objective of the toxicological profile is to evaluate the potential for human exposure and the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to BCME.

## B.1 LITERATURE SEARCH AND SCREEN

A literature search and screen was conducted to identify studies examining health effects, toxicokinetics, mechanisms of action, susceptible populations, biomarkers, and chemical interactions data for BCME. ATSDR primarily focused on peer-reviewed articles without publication date or language restrictions. Non-peer-reviewed studies that were considered relevant to the assessment of the health effects of BCME have undergone peer review by at least three ATSDR-selected experts who have been screened for conflict of interest. The inclusion criteria used to identify relevant studies examining the health effects of BCME are presented in Table B-1.

Table B-1 Inclusion Criteria for the Literature Search and Screen

Health Effects; Species; Human; Laboratory mammals; Route of exposure; Inhalation; Oral; Dermal (or ocular); Parenteral (these studies will be considered supporting data); Health outcome; Death; Systemic effects; Body weight effects; Respiratory effects; Cardiovascular effects; Gastrointestinal effects; Hematological effects; Musculoskeletal effects; Hepatic effects; Renal effects; Dermal effects; Ocular effects; Endocrine effects; Immunological effects; Neurological effects; Reproductive effects; Developmental effects; Other noncancer effects; Cancer
Toxicokinetics; Absorption; Distribution; Metabolism; Excretion; PBPK models; Biomarkers; Biomarkers of exposure; Biomarkers of effect; Interactions with other chemicals

### B.1.1 Literature Search

The current literature search was intended to update the health effects sections of the existing toxicological profile for BCME (ATSDR 1989), thus, the literature search was restricted to studies published between January 1987 to March 2017. The following main databases were searched in March 2017:

- PubMed
- National Library of Medicine’s TOXLINE
- Scientific and Technical Information Network’s TOXCENTER

The search strategy used the chemical names, Chemical Abstracts Service (CAS) numbers, synonyms, and Medical Subject Headings (MeSH) terms for BCME. The query strings used for the literature search are presented in Table B-2.

The search was augmented by searching the Toxic Substances Control Act Test Submissions (TSCATS), NTP website, and National Institute of Health Research Portfolio Online Reporting Tools Expenditures and Results (NIH RePORTER) databases using the queries presented in Table B-3. Additional databases were searched in the creation of various tables and figures, such as the TRI Explorer, the Substance priority list (SPL) resource page, and other items as needed. Regulations applicable to BCME were identified by searching international and U.S. agency websites and documents.

Review articles were identified and used for the purpose of providing background information and identifying additional references. ATSDR also identified reports from the grey literature, which included unpublished research reports, technical reports from government agencies, conference proceedings and abstracts, and theses and dissertations.

Table B-2 Database Query Strings

Database search date | Query string
PubMed
03/2017 | ((77382IHE37[rn] OR 542-88-1[rn] OR “Bis(Chloromethyl) Ether”[MeSH] OR “Bis(Chloromethyl) Ether”[nm]) AND (1987/01/01 : 3000[dp] OR 1987/01/01 : 3000[mhda])) OR ((“sym-Dichloromethyl ether”[tw] OR “1,1’-Dichlorodimethyl ether”[tw] OR “alpha, alpha’-Dichlorodimethyl ether”[tw] OR “Bis(chloromethyl) ether”[tw] OR “Chloro(chloromethoxy)methane”[tw] OR “Chloromethyl ether”[tw] OR “Dichlordimethylaether”[tw] OR “Dimethyl-1,1’-dichloroether”[tw] OR “Monochloromethyl ether”[tw] OR “Oxybis(chloromethane)”[tw] OR “sym-Dichloro-dimethyl ether”[tw] OR “sym-Dichloromethyl ether”[tw] OR “1,1’-oxybis(1-chloro-Methane”[tw] OR “Bis(chloromethyl)ether”[tw] OR “Dichloromethyl ether”[tw]) AND (1987/01/01 : 3000[dp] OR 1987/01/01 : 3000[crdat] OR 1987/01/01 : 3000[edat]))
Toxline
03/2017 | ( “sym-dichloromethyl ether” OR “1 1’-dichlorodimethyl ether” OR “alpha alpha’-dichlorodimethyl ether” OR “bis ( chloromethyl ) ether” OR “chloro ( chloromethoxy ) methane” OR “chloromethyl ether” OR “dichlordimethylaether” OR “dimethyl-1 1’-dichloroether” OR “monochloromethyl ether” OR “oxybis ( chloromethane ) ” OR “sym-dichloro-dimethyl ether” OR “sym-dichloromethyl ether” OR “1 1’-oxybis ( 1-chloro-methane” OR “bis ( chloromethyl ) ether” OR “dichloromethyl ether” OR 542-88-1 [rn] ) AND 1987:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) AND NOT PubMed [org] AND NOT pubdart [org]
Toxcenter
03/2017 | FILE ‘TOXCENTER’ ENTERED AT 14:37:16 ON 17 MAR 2017; CHARGED TO COST=EH011.13.01.01; L49 583 SEA 542-88-1; L50 571 SEA L49 NOT TSCATS/FS; L51 508 SEA L50 NOT PATENT/DT; L52 206 SEA L51 AND PY>=1987; ACTIVATE TOXQUERY/Q; ---------; L53 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?); L54 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT, IT); L55 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50); L56 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT; L57 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?); L58 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?); L59 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR DIETARY OR DRINKING(W)WATER?); L60 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE)); L61 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?); L62 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM? OR OVUM?); L63 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?); L64 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?); L65 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR SPERMATOB? OR SPERMATOC? OR SPERMATOG?); L66 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?); L67 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?); L68 QUE (ENDOCRIN? AND DISRUPT?); L69 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?); L70 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?); L71 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?); L72 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR NEOPLAS?); L73 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?); L74 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?); L75 QUE (NEPHROTOX? OR HEPATOTOX?); L76 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?); L77 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?); L78 QUE L53 OR L54 OR L55 OR L56 OR L57 OR L58 OR L59 OR L60 OR L61 OR L62 OR L63 OR L64 OR L65 OR L66 OR L67 OR L68 OR L69 OR L70 OR L71 OR L72 OR L73 OR L74 OR L75 OR L76 OR L77; L79 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR SWINE OR PORCINE OR MONKEY? OR MACAQUE?); L80 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE); L81 QUE L78 OR L79 OR L80; L82 QUE (NONHUMAN MAMMALS)/ORGN; L83 QUE L81 OR L82; L84 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL? OR PRIMATES OR PRIMATE?); L85 QUE L83 OR L84; ---------; L86 158 SEA L52 AND L85; L87 18 SEA L86 AND MEDLINE/FS; L88 28 SEA L86 AND BIOSIS/FS; L89 99 SEA L86 AND CAPLUS/FS; L90 13 SEA L86 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS); L91 145 DUP REM L87 L88 L90 L89 (13 DUPLICATES REMOVED); L*** DEL 18 S L86 AND MEDLINE/FS; L*** DEL 18 S L86 AND MEDLINE/FS; L92 18 SEA L91; L*** DEL 28 S L86 AND BIOSIS/FS; L*** DEL 28 S L86 AND BIOSIS/FS; L93 23 SEA L91; L*** DEL 99 S L86 AND CAPLUS/FS; L*** DEL 99 S L86 AND CAPLUS/FS; L94 91 SEA L91; L*** DEL 13 S L86 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS); L*** DEL 13 S L86 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS); L95 13 SEA L91; L96 127 SEA (L92 OR L93 OR L94 OR L95) NOT MEDLINE/FS; SAVE TEMP L96 CHLOROM/A; D SCAN L96

Table B-3 Strategies to Augment the Literature Search

Source | Query and number screened when available
TSCATS ^a^
03/2017 | Compound searched: 542-88-1
NTP
03/2017 | “542-88-1” OR “sym-Dichloromethyl ether” OR “1,1’-Dichlorodimethyl ether” OR “alpha,alpha’-Dichlorodimethyl ether” OR “Bis(chloromethyl) ether” OR “Chloro(chloromethoxy)methane” OR “Chloromethyl ether” OR “Dimethyl-1,1’-dichloroether” OR “Monochloromethyl ether” OR “Oxybis(chloromethane)” OR “sym-Dichloro-dimethyl ether” OR “sym-Dichloromethyl ether” OR “1,1’-oxybis(1-chloro-Methane” OR “Bis(chloromethyl)ether” OR “Dichloromethyl ether”
NIH RePORTER
05/2017 | Active projects; “sym-Dichloromethyl ether” OR “1,1’-Dichlorodimethyl ether” OR “alpha,alpha’-Dichlorodimethyl ether” OR “Bis(chloromethyl) ether” OR “Chloro(chloromethoxy)methane” OR “Chloromethyl ether” OR “Dichlordimethylaether” OR “Dimethyl-1,1’-dichloroether” OR “Monochloromethyl ether” OR “Oxybis(chloromethane)” OR “sym-Dichloro-dimethyl ether” OR “sym-Dichloromethyl ether” OR “1,1’-oxybis(1-chloro-Methane” OR “Bis(chloromethyl)ether” OR “Dichloromethyl ether”
Other | Identified throughout the assessment process

a Several versions of the TSCATS database were searched, as needed, by CASRN including TSCATS1 via Toxline (no date limit), TSCATS2 via https://yosemite.epa.gov/oppts/epatscat8.nsf/ReportSearch?OpenForm (date restricted by EPA receipt date), and TSCATS via CDAT (date restricted by ‘Mail Received Date Range’), as well as google for recent TSCA submissions.

The 2017 results were:

- Number of records identified from PubMed, TOXLINE, and TOXCENTER (after duplicate removal): 310
- Number of records identified from other strategies: 25
- Total number of records to undergo literature screening: 335

### B.1.2 Literature Screening

A two-step process was used to screen the literature search to identify relevant studies on BCME:

- Title and abstract screen
- Full text screen

Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered relevant (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 335
- Number of studies considered relevant and moved to the next step: 32

Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 32
- Number of studies cited in the health effects sections of the existing toxicological profile (December, 1989): 28
- Total number of studies cited in the health effects sections of the updated profile: 39

A summary of the results of the literature search and screening is presented in Figure B-1.

Figure B-1 March 2017 Literature Search Results and Screen for BCME