# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Human Health Sciences, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Division of Toxicology and Human Health Sciences, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-57, Atlanta, Georgia 30329-4027.

## Bis(chloromethyl)ether (BCME) Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Bis(chloromethyl)ether (BCME)
CAS Numbers: | 542-88-1
Date: | December, 1989
| March, 2017—Updated literature search
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL.

Rationale for Not Deriving an MRL: The acute-duration inhalation database was not considered suitable for derivation of an MRL because the only study reporting effects at nonlethal concentrations involved a single 7-hour exposure to BCME and only examined a limited number of potential endpoints.

Drew et al. (1975) exposed rats and hamsters to concentrations ≥0.7 ppm for 7 hours. The effects observed in the rats included increases in lung weight at 0.7 ppm, tracheal epithelial hyperplasia at 0.7 ppm, and tracheal and bronchial hyperplasia and squamous metaplasia at 2.1 ppm. In the hamsters, exposure to 0.7 ppm resulted in increases in lung weight and pneumonitis; tracheal and bronchial hyperplasia and hyperplasia with atypia were observed at 2.1 ppm. In both species, exposure to 0.7 ppm resulted in ≥90% deceases in lifespan. Repeated exposure of rats and hamsters to 1 ppm for 10 days resulted in decreases in lifespan, extreme irritability, and subarachnoid hemorrhage (rats only) (Drew et al. 1975).

Agency Contact (Chemical Manager): Nickolette Roney, M.P.H.

## Bis(chloromethyl)ether (BCME) Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Bis(chloromethyl)ether (BCME)
CAS Numbers: | 542-88-1
Date: | December, 1989
| March, 2017—Updated literature search
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate
MRL: | 0.0003 ppm
Critical Effect: | Respiratory damage
Reference: | Leong et al. 1981
Point of Departure: | NOAEL of 0.1 ppm
Uncertainty Factor: | 100
LSE Graph Key: | 10
Species: | Rat

MRL Summary: An intermediate-duration inhalation MRL of 0.0003 ppm was derived for BCME. The MRL is based on a NOAEL of 0.1 ppm for the lack of respiratory effects in rats exposed to BCME for 6 months (Leong et al. 1981). The NOAEL was adjusted for intermittent exposure, converted to an equivalent concentration in humans, and divided by an uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

Selection of the Critical Effect: A small number of studies have evaluated the toxicity of BCME following intermediate-duration inhalation studies; most of the studies focused on the carcinogenicity of BCME. In the only study examining a wide range of potential noncancerous endpoints, Leong et al. (1981) did not report non-neoplastic alterations in the major tissues and organs examined in rats exposed concentrations as high as 0.1 ppm for 6 months. Additional findings reported in this study included an increase in the incidence of nasal tumors and increases in mortality in the post-exposure period in rats exposed to 0.1 ppm and increases in pulmonary adenomas in mice dying post-exposure in the 0.1 ppm group. At 1 ppm, respiratory distress and weight loss were observed in mice exposed for 82 exposure days (Leong et al. 1971) and subarachnoid hemorrhage and extreme irritability were observed in rats and hamsters exposed for 30 days (Drew et al. 1975); increases in mortality were observed in all three species. The available data suggest that the respiratory tract and nervous system maybe sensitive targets of toxicity for BCME. An acute-duration study in rats and hamsters support the identification of the respiratory tract as a sensitive target. Increases in lung weight and tracheal hyperplasia were observed in rats and hamsters exposed to 0.7 ppm for 7 hours and followed for a lifetime (Drew et al. 1975). At 2.1 ppm, tracheal and bronchial hyperplasia and squamous metaplasia (rats only) were also observed.

Selection of the Principal Study: The Leong et al. (1981) study was selected as the principal study because it identified a NOAEL for respiratory effects, the presumed critical effect.

Summary of the Principal Study:

Leong BKJ, Kociba RI, Jersey GC. 1981. A lifetime study of rats and mice exposed to vapors of bis(chloromethyl) ether. Toxicol Appl Pharmacol 58:269–281 7245201

Groups of 120 male Sprague Dawley rats were exposed to 1, 10, or 100 ppb (0.001, 0.01, or 0.1 ppm) bis(chloromethyl)ether 6 hours/day, 5 days/week for 6 months and observed over a lifetime; a control group of 120 rats were held under ambient conditions without chamber exposure. The following parameters were used to assess toxicity: body weight (weekly for 3 months and monthly thereafter), hematology evaluation (in 10 rats/group at 12 weeks in control and 0.1 ppm groups, in all groups at day 1 post-exposure, in 4 rats/group on post-exposure day 5, and in the 4 rats/group in control, 0.001, and 0.01 ppm groups at study week 104), organ weight (heart, brain, liver kidneys, and testes in 4 rats/group sacrificed 1 day post-exposure) and histopathology of the major tissues and organs, including the nasal cavity, in 4 rats/group sacrificed 1 or 5 days post-exposure and in rats dying early.

The percentages of animals dying during the exposure period were 0.8, 1.7, 0.8, and 3.3% in the control, 0.001, 0.01, and 0.1 ppm groups, respectively. Although statistical significance was not reported, a Fisher Exact test conducted by ATSDR did not find a statistically significant increase in mortality during the exposure period. Most animals in the 0.1 ppm group died during the first 7 post-exposure months. No increases in post-exposure mortality were observed in the 0.001 or 0.01 ppm groups. No significant alterations in body weight gain, hematological alterations, or organ weight were observed. No treatment-related non-neoplastic lesions were observed in rats sacrificed 1 or 5 days post-exposure. A significant increase in the incidence of nasal esthesioneuroepitheliomas was observed during the post-exposure period. Evidence of respiratory infection was observed in animals in the 0.1 ppm group sacrificed due to morbidity during the exposure period. Similar infectious lesions were observed in the controls and 0.001 and 0.01 ppm groups. The investigators noted that cultures often revealed the presence of Corynebacterium kutscheri.

Selection of the Point of Departure for the MRL: The NOAEL of 0.1 ppm for the lack of respiratory effects was selected as the basis of the MRL.

Adjustment for Intermittent Exposure: The NOAEL was adjusted for intermittent exposure (6 hours/day, 5 days/week)

Human Equivalent Concentration: The NOAEL adjusted was converted to a human equivalent concentration.

Uncertainty Factor: The human equivalent NOAEL was divided by a total uncertainty factor of 100:

- 10 for extrapolation from animals to humans
- 10 for human variability

Other Additional Studies or Pertinent Information that Lend Support to this MRL: As noted previously, acute-duration inhalation studies have also identified the respiratory tract as a sensitive target of toxicity.

Agency Contact (Chemical Manager): Nickolette Roney, M.P.H.

## Bis(chloromethyl)ether (BCME) Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Bis(chloromethyl)ether (BCME)
CAS Numbers: | 542-88-1
Date: | December, 1989
| March, 2017—Updated literature search
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL.

Rationale for Not Deriving an MRL: No chronic-duration inhalation studies were identified for BCME.

Agency Contact (Chemical Manager): Nickolette Roney, M.P.H.

## Bis(chloromethyl)ether (BCME) Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Bis(chloromethyl)ether (BCME)
CAS Numbers: | 542-88-1
Date: | December, 1989
| March, 2017—Updated literature search
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL.

Rationale for Not Deriving an MRL: No acute-duration oral studies were identified for BCME.

Agency Contact (Chemical Manager): Nickolette Roney, M.P.H.

## Bis(chloromethyl)ether (BCME) Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Bis(chloromethyl)ether (BCME)
CAS Numbers: | 542-88-1
Date: | December, 1989
| March, 2017—Updated literature search
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration oral MRL.

Rationale for Not Deriving an MRL: No intermediate-duration oral studies were identified for BCME.

Agency Contact (Chemical Manager): Nickolette Roney, M.P.H.

## Bis(chloromethyl)ether (BCME) Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Bis(chloromethyl)ether (BCME)
CAS Numbers: | 542-88-1
Date: | December, 1989
| March, 2017—Updated literature search
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL.

Rationale for Not Deriving an MRL: No chronic-duration oral studies were identified for BCME.

Agency Contact (Chemical Manager): Nickolette Roney, M.P.H.