# CHAPTER 8 REFERENCES

*Cited in text

+ Cited in supplemental document

*ACGIH. 1986. Documentation of the threshold limit values and biological exposure indices. 5th ed. Cincinnati, OH: American Conference of Governmental Industrial Hygienists, Inc.
*ACGIH. 2016. Dichloroethyl ether. TLVs and BEIs based on the documentation of the threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists, May 11, 2017.
*AIHA. 2015. Current ERPG Values (2015). Fairfax, VA: American Industrial Hygiene Association. https://www.aiha.org/get-involved/AIHAGuidelineFoundation/EmergencyResponsePlanningGuidelines/Documents/2015%20ERPG%20Levels.pdf. March 22, 2016.
*Amoore JE, Hautala E. 1983. Odor as an aid to chemical safety: Odor thresholds compare with threshold limit values and volatilities for 214 industrial chemicals in air and water dilution. J Appl Toxicol 3:272–290.6376602
AOAC. 1984. Fumigant residues. Volatile fumigants in grain. Gas chromatographic method. Section 29.071. Official methods of analysis of the Association of Official Analytical Chemists, 14th ed. Arlington, VA: Association of Official Analytical Chemists Inc., 547–548.
*ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634.
*ATSDR. 2017. Bis(2-chloroethyl)ether. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry, Centers for Disease Control and Prevention. http://www.atsdr.cdc.gov/SPL/resources/index.html. October 6, 2017.
*Ballering LA, Nivard MJ, Vogel EW. 1996. Characterization by two-endpoint comparisons of the genetic toxicity profiles of vinyl chloride and related etheno-adduct forming carcinogens in Drosophila. Carcinogenesis 17(5):1083–1092.8640917
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486.3222488
*Barnes D, Bellin J, DeRosa C, . 1987. Reference dose (RfD): description and use in health risk assessments. Volume I, Appendix A: Integrated risk information system supportive documentation. Washington, DC: US Environmental Protection Agency, Office of Health and Environmental Assessment. EPA 600886032a.
+Bell A, Jones AT. 1958. Fumigation with dichloroethyl ether and chlordane: Hysterical sequelae. Med J Australia 2:258–263.13589320
*Berck B. 1965. Determination of fumigant gases by gas chromatography. J Agric Food Chem 13:373–377.
Berg GL, ed. 1981. Farm chemicals handbook. Willoughby, OH: Meister Publishing Company, C-109.
*Betowski LD, Pyle SM, Ballard JM, . 1987. Thermospray LC/MS/MS/ analysis of wastewater for disperse azo dyes. Biomed Environ Mass Spectrom 14:343–354.2959343
*Bolt HM. 1984. Metabolism of genotoxic agents: Halogenated compounds. In: Monitoring human exposure to carcinogenic and mutagenic agents. Proceedings of a Joint Symposium, Espoo, Finland, December 1983. IARC Scientific Publication 59.
*Browning E. 1965. Toxicity and metabolism of industrial solvents. New York: Elsevier, 513.
*Buckman Laboratories. 1988. Selected information on DCEE. Letter from Buckman Laboratories to D. Ozolins, USEPA. October 20, 1988.
*Callahan MA, Slimak MW, Gabrel NW, . 1979. Halogenated aliphatic hydrocarbons, halogenated ethers, monocyclic aromatics, phthalate sters, polycyclic aromatic hydrocarbons, nitrosamines, and miscellaneous compounds. Washington, DC: U.S. Environmental Protection Agency, Office of Water Planning and Standards, 65-l to 65-7. PB80204381.
+*Carpenter CP, Smyth HF. 1946. Chemical burns of the rabbit cornea. Am J Opthamol 29:1363–1372.
*Carpenter CP, Smyth HF, Pozzani UC. 1949. The assay of acute vapor toxicity and the grading and interpretation of results of 96 chemical components. J Ind Hyg Toxicol 31:343–346.15407114
*Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
*CLPSD. 1988. Contract laboratory program statistical database. Viar and Company. Alexandria, VA. August 10.
DeWalle FB, Chian ESK. 1981. Detection of trace organics in well water near a solid waste landfill. J Am Water Works Assoc 73:206–211.
*DOE. 2016a. Table 3: Protective Action Criteria (PAC) Rev. 29 based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. May 2016. Oak Ridge, TN: U.S. Department of Energy. https://sp.eota.energy.gov/pac/teel/Revision_29_Table3.pdf. February 28, 2017.
*DOE. 2016b. Protective Action Criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29 for Chemicals of Concern - May 2016. Oak Ridge, TN: U.S. Department of Energy. https://energy.gov/ehss/protective-action-criteria-pac-aegls-erpgs-teels-rev-29-chemicals-concern-may-2016. February 28, 2017.
*Dojlido JR. 1979. Investigations of biodegradability and toxicity of organic compounds. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development. EPA600279163..
+*Dow Chemical. 1958. Results of repeated exposures of laboratory animals to the vapor of dichlorodiethyl ether at a concentration of 69 mm. Midland, MI: The Dow Chemical Company.
*Drake KD, Myer JR. 1992. Acute oral toxicity of DCEE (dichloroethyl ether) in rats and mice. Int J Toxicol 1(3):163–164.
*Dressman RC, Fair J, McFarren EF. 1977. Determinative method for analysis of aqueous sample extracts for bis(2-chloro)ethers and dichlorobenzenes. Environ Sci Technol 11:719–721.
*Elkins HB. 1959. The chemistry of industrial toxicology. New York, NY: John Wiley and Sons, Inc.
EPA. 1975. Initial scientific and miniorganic review of dolpat. Draft Report. Washington, DC: U.S. Environmental Protection Agency, Office of Pesticide Programs.
*EPA. 1980a. Ambient water quality criteria for chloroalkyl ethers. Washington, DC: U.S. Environmental Protection Agency, Office of Water Regulations and Standards. EPA 440580030.
*EPA. 1980b. Hazardous waste; identification and listing; final and interim rules. U.S. Environmental Protection Agency. Fed Regist 45:33084–33133.
*EPA. 1980c. Guidelines and methodology used in the preparation of health effect assessment chapters of the consent decree water criteria documents. U.S. Environmental Protection Agency. Fed Regist 45:79347–79357.
*EPA. 1982a. Haloethers-Method 611. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring and Support Laboratory, 611-l to 611-7. EPA600482057.
*EPA. 1982b. Base/neutrals and acids-method 625. Methods for organic chemical analysis of municipal and industrial wastewater. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring and Support Laboratory, 625-l to 625-19. EPA600482057.
EPA. 1983. Treatability manual, volume I, treatability data. Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development. EPA600282001a.
*EPA. 1984. Semivolatile organic compounds by isotope dilution GC-MS - Method 1625, Revision B. Washington, DC: U.S. Environmental Protection Agency, 1625-1 to 1625-44.
*EPA. 1985. Notification requirements; reportable quantity adjustments; final rule and proposed rule. Part II. U.S. Environmental Protection Agency. Fed Regist 50:13456–13522.
*EPA. 1986a. Gas chromatography/mass spectrometry for semivolatile organics: packed column technique-Method 8250. Test methods for evaluating solid wastes, SW-846, 3rd ed. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response, 8250-l to 8250-30.
*EPA. 1986b. Gas chromatography/mass spectrometry for semivolatile organics: capillary column technique-Method 8270. Test methods for evaluating solid wastes, SW-846, 3rd ed. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response, 8270-1 to 8270-32.
*EPA. 1986c. Capillary column analysis of semivolatile organic compounds by gas chromatography/fourier transform infrared (GC/FT-IR) spectrometry - Method 8410. Test methods for evaluating solid wastes, SW-846, 3rd ed. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response, 8410-l to 8410-17.
*EPA. 1987a. Health and environmental effects document for haloethers. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. ECAOGINGo14.
*EPA. 1987b. Extremely hazardous substances list and threshold planning quantities; emergency planning and release notification requirements; final rule. Part II. U.S. Environmental Protection Agency. Fed Regist 52:13378–13410.
*EPA. 1987c. Hazardous substances; reportable quantity adjustments; proposed rule. U.S. Environmental Protection Agency. Fed Regist 50:8140–8171.
*EPA. 1987d. Part II. List (Phase 1) of hazardous constituents for ground-water monitoring; final rule. U.S. Environmental Protection Agency. Fed Regist 52:25942–25953.
*EPA. 1988, Integrated Risk Information System -- computer printout for bis(2-chloroethyl) ether. Washington, DC: U.S. Environmental Protection Agency. August, 1988.
*EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency, Office of Environmental Information. EPA260B05001.
*EPA. 2009. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency, Office of Ground Water and Drinking Water. EPA816F090004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. February 28, 2017.
*EPA. 2012. Drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency, Office of Water. EPA822S12001. https://www.epa.gov/sites/production/files/2015-09/documents/dwstandards2012.pdf. May 11, 2017.
*EPA. 2016. Acute Exposure Guideline Levels (AEGLs) values. U.S. Environmental Protection Agency. https://www.epa.gov/aegl/access-acute-exposure-guideline-levels-aegls-values#chemicals. February 28, 2017.
*FDA. 2013. Everything added to food in the United States (EAFUS). Washington, DC: U.S. Food and Drug Administration. http://www.accessdata.fda.gov/scripts/fcn/fcnnavigation.cfm?rpt=eafuslisting. February 28, 2017.
*Foureman P, Mason JM, Valencia R, . 1994. Chemical mutagenesis testing in Drosophila. IX. Results of 50 coded compounds tested for the National Toxicology Program. Environ Mol Mutagen 23(1):51–63.8125083
*FSTRAC. 1988. Summary of state and federal drinking water standards and guidelines. Federal-State Toxicology and Regulatory Alliance Committee. March, 1988.
*Gurka DF, Titus R, Griffiths PR, . 1987. Evaluation of an improved single-beam gas chromatography/fourier transform infrared interface for environmental analysis. Anal Chem 59:2362–2369.3674448
+*Gwinner LM, Laib RJ, Filser JG, . 1983. Evidence of chloroethylene oxide being the reactive metabolite of vinyl chloride toward DNA: Comparative studies with 2,2-dichlorodiethyl ether. Carcinogenesis 4:1483–1486.6196138
*Hake CL, Rowe BK. 1963. Ethers. In: Patty FA (ed). Industrial Hygiene and Toxicology (2nd revised edition), Vol II. New York: John Wiley and Sons, 1673–1677.
Hawley GG. 1977. Condensed chemical dictionary. 9th ed. New York: Van Nostrand Reinhold Company, 280.
*Hawthorne SB. 1988. 1988 Workshop on supercritical fluid chromatography. Amer Lab 88:6–8.
*HSDB. 1988. Hazardous Substances Data Base - computer printout for bis(2-chloroethyl) ether. August, 1988.
*IARC. 1975. IARC monographs on the evaluation of the carcinogenic risk of chemicals to man: some aziridines, N-, S- and O-mustards and selenium. Volume 9. Bis(2-chloroethyl) ether. Lyon, France: International Agency for Research on Cancer, 117–123.
*IARC. 1987. IARC monographs on the evaluation of carcinogenic risks to humans. Overall evaluations of carcinogenicity: An updating of IARC monographs volumes 1 to 42. Supplement 7. Lyon, France: International Agency for Research on Cancer, 56–74.
*IARC. 1999. Bis(2-chloroethyl)ether. IARC Monographs on the evaluation of carcinogenic risks to humans. Volume 71. Re-evaluation of some organic chemicals, hydrazine and hydrogen peroxide. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Monographs/vol71/mono71-66.pdf. May 10, 2017.
*IARC. 2017. Agents classified by the IARC Monographs , Volumes 1–118. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Classification/List_of_Classifications.pdf. May 10, 2017.
*IRIS. 2002. Bis(chloroethyl)ether (BCEE); CASRN 111-44-4. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0137_summary.pdf. May 11, 2017.
+*Innes JRM, Ulland BM, Valerio MG, . 1969. Bioassay of pesticides and industrial chemicals for tumorigenicity in mice. J Natl Cancer Inst 42:1101–1114.5793189
Jorgenson TA, Rushbrook CJ, Newell GW, . 1977. Study of the mutagenic potential of bis(2-chloroethyl) and bis(chloroisopropy1) ethers in mice by the heritable translocation test. (Abstract). Toxicol Appl Pharmacol 41:196–197.
+*Jorgenson TA, Rushbrook CJ, Newell GW, . 1978. Study of the mutagenic potential of bis(2-chloroethyl) and bis(2-chloroisopropyl) ethers in mice by the heritable translocation test. Mutat Res 53:124. (Abstract).
*Kincannon DF, Lin YS. 1986. Microbial degradation of hazardous wastes by land treatment. In: Proceedings of the 40th industrial waste conference (May 14, 15, 16, 1985). Boston, MA: Ann Arbor Science.
Kleopper RD, Fairless BJ. 1972. Characterization of organic components in a municipal water supply. Environ Sci Technol 6:1036–1037.
*Korfmacher WA, Holder CL, Betowski LD, . 1987. Identification of two glucuronide metabolites of doxylamine via thermospray/mass spectrometry and thermospray/mass spectrometry/mass spectrometry. J Anal Toxicol 11:182–184.3626532
*Krishnan K, Anderson ME, Clewell HJ, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
*Lingg RD, Kaylor WH, Pyle SM, . 1979. Thiodiglycolic acid: A major metabolite of bis(2-chloroethyl) ether. Toxicol Appl Pharmacol 47:23–34.425117
+*Lingg RD, Kaylor WJ, Pyle SM, . 1982. Metabolism of bis(2-chloroethyl) ether and bis(chloroisopropy1) ether in the rat. Arch Environ Contam Toxicol 11:173–183.6807217
*Ludzack FJ, Ettinger MB. 1963. Biodegradability of organic chemicals isolated from rivers. Purdue University. Eng Bull Ext Ser 115:278–282.
*Mabey WR, Smith JH, Podoll RT . 1982. Aquatic fate process data for organic priority pollutants. Washington, DC: U.S. Environmental Protection Agency, Office of Water Regulations and Standards. EPA440481014. PB87169090.
*Maronpot RR, Haseman JK, Boorman GA, . 1987. Liver lesions in B6C3Fl mice: The National Toxicology Program, experience and position. Arch Toxicol (Supplement l0):l0–26.
*McNally ME, Wheeler JR. 1988. Supercritical fluid extraction coupled with supercritical fluid chromatography for the separation of sulfonylurea herbicides and their metabolites from complex matrices. J Chromatogr 435:63–71.3350898
*Michael LC, Pellizari ED, Wiseman RW. 1988. Development and evaluation of a procedure for determining volatile organics in water. Environ Sci Technol 22:565–570.22195629
*Monsen RM. 1986. The Chlorex treatability study: Environmental fate in facultative anaerobic and aerobic waste stabilization ponds. (Ph.D. dissertation). Available from University Microfilms International, Dissertation Information Service, Ann Arbor, MI.
*Muller G, Norpoth K. 1979. Identification of S-(carboxymethyl)-Lcysteine and thiodiglycolic acid, urinary metabolites of 2,2’-bis-(chloroethyl)-ether in the rat. Cancer Lett 7:299–305.509409
NAS. 1977. National Academy of Sciences. Drinking water and health. Washington, DC: National Academy Press, 711.
*NAS/NRC. 1989. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC, 15–35.
*NATICH. 1987. NATICH data base report on state, local and EPA air toxic activities. July, 1987. Research Triangle Park, NC: National Air Toxic Information Clearinghouse. U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards.
*NIOSH. 1984. sym-Dichloroethyl ether-method 1004. NIOSH Manual of Analytical Methods, 3rd ed. Cincinnati, OH: National Institute for Occupational Safety and Health, 1004-l to 1004-3.
*NIOSH. 1985. Pocket guide to chemical hazards. Washington, DC: U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health.
*NIOSH. 2016. Dichloroethyl ether. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. https://www.cdc.gov/niosh/npg/npgd0196.html. May 11, 2017.
*NLM. 1988. National Library of Medicine - Chemline database printout for bis(2-chloroethyl) ether. August, 1988.
+*Norpoth K, Heger M, Muller G, . 1986. Investigations of metabolism, genotoxic effects and carcinogenicity of 2,2-dichlorodiethyl ether. J Cancer Res Clin Oncol 112:125–130.3771621
*NTP. 2016. Report on Carcinogens, Fourteenth Edition. CASRN Index in MS Excel. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html#P. February 28, 2017.
*OSHA. 2016a. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Standards. Code of Federal Regulations 29 CFR 1910.1000 https://www.gpo.gov/fdsys/pkg/CFR-2016-title29-vol6/pdf/CFR-2016-title29-vol6-sec1910-1000.pdf. March 6, 2017.
*OSHA. 2016b. Subpart D Occupational health and environment controls. Section 1926.55 - Gases, vapors, fumes, dusts, and mists. Appendix A to Part 1926.55 - threshold limit values of airborne contaminants for construction. Occupational Safety and Health Standards. Code of Federal Regulations 29 CFR 1926.55 https://www.gpo.gov/fdsys/pkg/CFR-2016-title29-vol8/pdf/CFR-2016-title29-vol8-sec1926-55.pdf. March 6, 2017.
*OSHA. 2016c. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z - Shipyards. Occupational Safety and Health Standards. Code of Federal Regulations 29 CFR 1915.1000 https://www.gpo.gov/fdsys/pkg/CFR-2016-title29-vol7/pdf/CFR-2016-title29-vol7-sec1915-1000.pdf. March 6, 2017.
*Pellizzari ED, Sheldon LS, Bursey JR . 1985, Master scheme for the analysis of organic compounds in water. Part I. State-of-the-art review of analytical operation. Athens, GA: U.S. Environmental Protection Agency, Environmental Research Laboratory.
*Quinto I, Radman M. 1987. Carcinogenic potency in rodents versus genotoxic potency in E. coli: A correlation analysis for bifunctional alkylating agents. Mutat Res 181:235–242.3317026
Rannug U, Gothe R, Wachtmeister CA. 1976. The mutagenicity of chloroethylene oxide, chloroacetaldehyde, 2-chloroethanol and chloroacetic acid, conceivable metabolites of vinyl chloride. Chem Biol Interact 12:251–263.767010
*Sakazaki H, Ueno H, Umetani K, . 2001. Immunotoxicological evaluation of environmental chemicals utilizing mouse lymphocyte mitogenesis test. J Health Sci 47(3):258–271.
+*Schrenk HH, Patty FA, Yant WP. 1933. Acute response of guinea pigs to vapors of some new commercial organic compounds. Public Health Reports 48:1389–1398.19315426
Shirasu Y, Moriya M, Kato K, . 1975. Mutagenicity screening of pesticides in microbial systems. (Abstract). Mutat Res 31:268–269.
*Simmon VF, Kauhanen K, Tardiff RG. 1977. Mutagenic activity of chemicals identified in drinking water. In: Scott D, Bridges BA, Sobels FH (eds). Progress in genetic toxicology, 249–258.
Simmon VF. 1978. Structured correlations of carcinogenic and mutagenic alkyl halides. In: Structural correlates of carcinogenesis and mutagenesis. A guide to testing priorities. Washington, DC: U.S. Food and Drug Administration. FDA781046.
Sittig M, ed. 1980. Chloroalkyl ethers. In: Priority toxic pollutants: Heath impacts and allowable limits. Park Ridge, NJ: Noyes Data Corp.
Sittig M. 1985, Bis(2-chloroethyl)ether. Handbook of toxic hazardous chemicals and carcinogens, 2nd ed. Park Ridge NJ: Noyes Data Publication 323–325.
+*Smyth HF, Carpenter CP. 1948. Further experience with the range finding test in the industrial toxicology laboratory. J Ind Hyg Toxicol 30:63–68.18895731
*Staples CA, Werner AF, Hoogheem TJ. 1985. Assessment of priority pollutant concentrations in the United States using STORET database. Environ Toxicol Chem 4:131–142.
*Tabak HH, Quave SA, Mashni CI, . 1981. Biodegradability studies with organic priority pollutant compounds. J Water Pollut Control Fed 53:1503–1518.
*Ternay AL. 1976. Contemporary organic chemistry. Philadelphia, PA: W.B, Saunders Company, 146–147.
+*Theiss JC, Stoner GD, Shimkin MB, . 1977. Test for carcinogenicity of organic contaminants of United State drinking waters by pulmonary tumor response in strain A mice. Cancer Res 37:2717–2720.872098
*TRI16 2017. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access. Office of Environmental Information. U.S. Environmental Protection Agency. Toxics Release Inventory. http://www.epa.gov/triexplorer/. September 29, 2017.
+*Union Carbide. 1948. The toxicity of dichloroethyl ether. Union Carbide Corporation, Danbury CT. Rpt 11-39 (updated on 3-12-48, and also subsequently to address FIFRA regulations).
+*Van Duuren BL, Katz C, Goldschmidt BM, . 1972. Carcinogenicity of halo-ethers. II. Structure-activity relationship of analogues of bis(chloromethyl)ether. J Natl Cancer Inst 48:1431–1439.5030957
*Vanderlaan M, Watkins BE, Stanker L. 1988. Environmental monitoring by immunoassay. Environ Sci Technol 22:247–254.22288854
*Veith GD, Macek KJ, Petrocelli SR, . 1980. An evaluation of using partition coefficients and water solubility to estimate bioconcentration factors for organic chemicals in fish. In: Aquatic toxicology. Proceedings of the third annual symposium on aquatic toxicology. Philadelphia, PA: American Society for Testing and Materials, 116–129.
*Verschueren K. 1977. Handbook of environmental data on organic chemicals. New York: Van Nostrand Reinhold Company, 232–233.
Verschueren K. 1983. Bis(2-chloroethyl)ether. Handbook of environmental data on organic chemicals. New York: Van Nostrand Reinhold Company, 489–490.
Walters SM. 1986. Cleanup of samples. Analytical methods for pesticides and plant growth regulators, Vol 15. Zweig, G, Sherma E, Eds., Chapter 3. New York, NY: Academic Press, 67–110.
*Weast RC, ed. 1985. CRC handbook of chemistry and physics. 66th ed. Boca Raton, FL: CRC Press.
+*Weisburger EK, Ulland BM, Nam J, . 1981. Carcinogenicity tests of certain environmental and industrial chemicals. J Natl Cancer Inst 67:75–88.6942197
*WHO. 2010. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. January 08, 2014.
*WHO. 2017. Guidelines for drinking-water quality. Fourth edition incorporating the first addendum. Geneva, Switzerland: World Health Organization. http://apps.who.int/iris/bitstream/10665/254637/1/9789241549950-eng.pdf?ua=1. February 28, 2017.
*Wilson JT, Enfield CG, Dunlap WJ, . 1981. Transport and fate of selected organic pollutants in a sandy soil. J Environ Qua1 10:501–506.
*Windholz M, ed. 1983. The Merck Index. Tenth edition. Rahway, NJ: Merck & Co., Inc.