# CONTRIBUTORS & REVIEWERS

## CHEMICAL MANAGER TEAM

- Carolyn Harper, Ph.D.
- ATSDR, Division of Toxicology and Human Health Sciences, Atlanta, GA
- Lisa Ingerman, Ph.D., DABT
- SRC, Inc., North Syracuse, NY