# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Table 4-1 lists common synonyms, trade names and other pertinent identification information for BCEE.

Table 4-1 Chemical Identity of Bis(2-Chloroethyl)Ether

Characteristic | Information | Reference
Chemical name | Bis(2-chloroethyl) ether | IARC 1975
Synonym(s) and registered trade name(s) | 1,1’-Oxybis(2-chloro) ethane; bis(chloroethyl) ether; bis(β-chloroethyl)ether; sym-dichloroethylether; 2,2’-dichloro-diethyl ether; 2-dichloroethyl ether; dichloroethyl ether; dichloroethyl oxide; DCEE; Chlorex | IARC 1975
Chemical formula | C_4_H_8_Cl_2_O | Weast 1985
Chemical structure | [image]
Identification numbers:
CAS Registry | 111-44-4 | NLM 1988

CAS = Chemical Abstracts Service

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Table 4-2 lists important physical and chemical properties of BCEE.

Table 4-2 Physical and Chemical Properties of Bis(2-Chloroethyl)Ether

Property | Information | Reference
Molecular weight | 143.04 | Weast 1985
Color | colorless, clear | Windholz 1983
Physical state | Liquid | Windholz 1983
Melting point | -24.5 | Weast 1985
Boiling point | 178 | Weast 1985
Density at 20°C | 1.2199 | Weast 1985
Odor | pungent | Windholz 1983
Odor threshold:
Air | 0.049 | Amoore and Hautala 1983
Solubility:
Water at 20°C | 10,700 | Hake and Rowe 1963
Water at 20°C | 10,200 | Verschueren 1977
Water at 20°C | 17,200 | Veith et al. 1980
Organic solvents | soluble | Weast 1985
Partition coefficients:
Log K_ow_ | 1.58 | Callahan et al. 1979
Log K_ow_ | 1.5 | Mabey et al. 1982
Log K_ow_ | 1.1 | Veith et al. 1980
Log K_oc_ | 1.1 | Mabey et al. 1982
Vapor pressure at 20°C | 0.71 | Verschueren 1977
Henry’s law constant at 25°C | 1.31E-05 | Mabey et al. 1982
Autoignition temperature | 369
Flashpoint | 55
Flammability limits | No data
Conversion factors:
ppm (v/v) to mg/m^3^ in air (25°C) | 1 ppm • 5.85 mg/m | Verschueren 1977
mg/m^3^ to ppm (v/v) in air (25°C) | 1 mg/m^3^ • 0.17 ppm | Verschueren 1977