# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Human Health Sciences, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Division of Toxicology and Human Health Sciences, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-57, Atlanta, Georgia 30329-4027.

## Bis(2-chloroethyl)ether (BCEE) Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Bis(2-chloroethyl)ether (BCEE)
CAS Numbers: | 111-44-4
Date: | December 1989
Date: | March 2017—Updated literature search
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL.

Rationale for Not Deriving an MRL: The acute-duration inhalation database was not considered suitable for derivation of an MRL because the study design and results of the only available study were poorly reported, had a lack of incidence data, and only examined a limited number of potential endpoints.

Schrenk et al. (1933) reported slight nasal irritation in guinea pigs exposed to 35 ppm BCEE for up to 15 hours. At higher concentrations (≥105 ppm), lung congestion, edema, and hemorrhage; loss of consciousness and decreased motility; and death were observed. Eye irritation as evidenced as squinting at ≥105 ppm and lacrimation at ≥260 ppm were also noted. The investigators did not report whether other potential endpoints were examined or whether a histological examination of the respiratory tract was conducted.

Agency Contact (Chemical Manager): Carolyn Harper, Ph.D.

## Bis(2-chloroethyl)ether (BCEE) Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Bis(2-chloroethyl)ether (BCEE)
CAS Numbers: | 111-44-4
Date: | December 1989
Date: | March 2017—Updated literature search
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate
MRL: | 0.02 ppm
Critical Effect: | Decreased body weight gain
Reference: | Dow Chemical 1958
Point of Departure: | LOAEL of 69 ppm
Uncertainty Factor: | 1,000
LSE Graph Key: | 4
Species: | Rat

MRL Summary: An intermediate-duration inhalation MRL of 0.02 ppm was derived for BCEE. The MRL is based on a LOAEL of 69 ppm for increases in body weight gain in rats exposed to BCEE for 130 days (Dow Chemical 1958). The LOAEL was adjusted for intermittent exposure, converted to an equivalent concentration in humans, and divided by an uncertainty factor of 1,000 (10 for the use of a LOAEL, 10 for extrapolation from animals to humans, and 10 for human variability).

Selection of the Critical Effect: The Dow Chemical (1958) study examined a wide range of potential endpoints, including the lungs; the only adverse finding was a decrease in body weight gain. This effect was also observed in guinea pigs similarly exposed (Dow Chemical 1958).

Selection of the Principal Study: The Dow Chemical (1958) study is the only available intermediate-duration inhalation study.

Summary of the Principal Study:

Dow Chemical. 1958. Results of repeated exposures of laboratory animals to the vapor of dichlorodiethyl ether at a concentration of 69 mm. Midland, MI: The Dow Chemical Company.

Groups of 15 male and 15 female rats were exposed to 0 or 69 ppm BCEE 7 hours/day, 5 days/week for 130 days. The following parameters were used to assess toxicity: clinical signs, body weight, organ weight, gross necropsy, histopathology, and hematological parameters. A decrease in body weight gain was observed in male rats; a decrease was also observed in females, but the was less marked. No alterations in red blood cell, white blood cell, hemoglobin, neutrophil, lymphocyte, or blood urea nitrogen levels were observed. No alterations in organ weight or histopathology were observed in the lungs, heart, liver, or kidneys were observed.

Selection of the Point of Departure for the MRL: The LOAEL of 69 ppm for decreased body weight gain was selected as the basis of the MRL.

Adjustment for Intermittent Exposure: The LOAEL was adjusted for intermittent exposure (7 hours/day, 5 days/week)

Human Equivalent Concentration: The LOAEL was converted to a human equivalent concentration.

Uncertainty Factor: The human equivalent LOAEL was divided by a total uncertainty factor of 1,000:

- 10 for use of a LOAEL
- 10 for extrapolation from animals to humans
- 10 for human variability

Other Additional Studies or Pertinent Information that Lend Support to this MRL: A decrease in body weight gain was also observed in rats receiving gavage administration of 25 mg/kg BCEE for 78 weeks.

Agency Contact (Chemical Manager): Carolyn Harper, Ph.D.

## Bis(2-chloroethyl)ether (BCEE) Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Bis(2-chloroethyl)ether (BCEE)
CAS Numbers: | 111-44-4
Date: | December 1989
Date: | March 2017—Updated literature search
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL.

Rationale for Not Deriving an MRL: No chronic-duration inhalation studies were identified for BCEE.

Agency Contact (Chemical Manager): Carolyn Harper, Ph.D.

## Bis(2-chloroethyl)ether (BCEE) Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Bis(2-chloroethyl)ether (BCEE)
CAS Numbers: | 111-44-4
Date: | December 1989
Date: | March 2017—Updated literature search
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL.

Rationale for Not Deriving an MRL: Available data on the acute-duration oral toxicity of BCEE is limited to LD_50_ studies in rats and mice (Drake and Myer 1992; Smyth and Carpenter 1948).

Agency Contact (Chemical Manager): Carolyn Harper, Ph.D.

## Bis(2-chloroethyl)ether (BCEE) Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Bis(2-chloroethyl)ether (BCEE)
CAS Numbers: | 111-44-4
Date: | December 1989
Date: | March 2017—Updated literature search
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration oral MRL.

Rationale for Not Deriving an MRL: No intermediate-duration oral studies were identified for BCEE.

Agency Contact (Chemical Manager): Carolyn Harper, Ph.D.

## Bis(2-chloroethyl)ether (BCEE) Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Bis(2-chloroethyl)ether (BCEE)
CAS Numbers: | 111-44-4
Date: | December 1989
Date: | March 2017—Updated literature search
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL.

Rationale for Not Deriving an MRL: Two studies have evaluated the chronic toxicity of BCEE (Innes et al. 1969; Weisburger et al. 1981); however, the primary focus of both studies was carcinogenicity. The only noncancer endpoint reported was a decrease in body weight gain observed in rats administered 25 (females only) or 50 mg/kg BCEE twice per week for 18 months (Weisburger et al. 1981).

Agency Contact (Chemical Manager): Carolyn Harper, Ph.D.