# 8 REGULATIONS AND ADVISORIES

The international and national regulations and guidelines regarding barium and barium compounds in air, water, and other media are summarized in Table 8-1.

ATSDR has derived an intermediate-duration oral MRL of 0.2 mg barium/kg/day for barium. This MRL is based on a NOAEL of 65 mg barium/kg/day and a LOAEL of 115 mg barium/kg/day for increased kidney weight in female rats (NTP 1994) and an uncertainty factor of 100 (10 to account for animal to human extrapolation, and 10 for human variability) and modifying factor of 3 to account for the lack of an adequate developmental toxicity study

ATSDR has derived a chronic-duration oral MRL of 0.2 mg barium/kg/day for barium. The MRL is based on a BMDL_05_ of 61 mg barium/kg/day for nephropathy in male mice (NTP 1994) and an uncertainty factor of 100 (10 to account for animal to human extrapolation and 10 for human variability) and modifying factor of 3 to account for the lack of an adequate developmental toxicity study.

EPA (IRIS 2006) has derived an oral reference dose (RfD) for barium of 0.2 mg/kg/day, based on a BMDL_05_ of 63 mg/kg/day for nephropathy in male mice (NTP 1994) and an uncertainty factor of 300 (10 to account for animal to human extrapolation, 10 for human variability, and 3 for database deficiencies, particularly the lack of a two-generation reproductive toxicity study and an adequate investigation of developmental toxicity). EPA (IRIS 2006) has not recommended an inhalation reference concentration (RfC) for barium at this time.

Using their 1986 guidelines, EPA has determined that barium is not classifiable as a human carcinogen and has assigned it the cancer classification, Group D (IRIS 2006). Using their recent guidelines, EPA determined that barium is considered not likely to be carcinogenic to humans following oral exposure and its carcinogenic potential cannot be determined following inhalation exposure (IRIS 2006).

Table 8-1 Regulations and Guidelines Applicable to Barium and Barium Compounds

Agency | Description | Information | Reference
[underlined: INTERNATIONAL]
Guidelines:
IARC | Carcinogenicity classification | No data | IARC 2004
WHO | Air quality guidelines | No data | WHO 2000
| Drinking water quality guidelines | 0.7 mg/L | WHO 2004
[underlined: NATIONAL]
Regulations and Guidelines:
a. Air
ACGIH | TLV (TWA) | | ACGIH 2004
| Barium and soluble compounds (as Ba) | 0.5 mg/m^3^
| Barium sulfate | 10 mg/m^3^
NIOSH | REL (TWA) | | NIOSH 2005a, 2005b
| Barium chloride^a^ | 0.5 mg/m^3^ | NIOSH 2005a, 2005b
| Barium sulfate | 10 mg/m^3^ (total); 5.0 mg/m^3^ (respiratory)
| IDLH
| Barium chloride | 50 mg/m^3^
| Barium sulfate | No data
OSHA | PEL (8-hour TWA) for general industry | | OSHA 2005c; 29 CFR 1910.1000
| Barium, soluble compounds (as Ba) | 0.5 mg/m^3^
| Barium sulfate | 15 mg/m^3^ (total dust); 5.0 mg/m^3^ (respirable fraction)
| PEL (8-hour TWA) for construction industry | | OSHA 2005b; 29 CFR 1926.55
| Barium, soluble compounds (as Ba) | 0.5 mg/m^3^
| PEL (8-hour TWA) for shipyard industry | | OSHA 2005a; 29 CFR 1915.1000
| Barium, soluble compounds (as Ba) | 0.5 mg/m^3^
| Barium sulfate | 15 mg/m^3^ (total dust); 5.0 mg/m^3^ (respirable fraction)
b. Water
EPA | Drinking water standards and health advisories | | EPA 2004
| 1-day health advisory for a 10-kg child | 0.7 mg/L
| 10-day health advisory for a 10-kg child | 0.7 mg/L
| National primary drinking water standards | | EPA 2002a
| MCLG | 2.0 mg/L
| MCL | 2.0 mg/L
| Reportable quantities of hazardous substances (barium cyanide) designated pursuant to Section 311 of the Clean Water Act | 10 pounds | EPA 2005b; 40 CFR 117.3
| Water quality criteria for human health consumption of: | | EPA 2002b
| Water + organism | 1.0 mg/L
| Organism only | No data
c. Food
FDA | Bottled drinking water | 2.0 mg/L | FDA 2004; 21 CFR 165.110
d. Other
ACGIH | Carcinogenicity classification | A4^b^ | ACGIH 2004
EPA | Carcinogenicity classification | Group D^c^ | IRIS 2006
| RfC | Not recommended at this time
| RfD | 0.2 mg/kg/day
NTP | Carcinogenicity classification | No data | NTP 2005

a The REL also applies to other soluble barium compounds (as Ba) except barium sulfate.

b A4: not classifiable as a human carcinogen

c Group D: not classifiable as to human carcinogenicity

ACGIH = American Conference of Governmental Industrial Hygienists; CFR = Code of Federal Regulations; DWEL = drinking water equivalent level; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; MCL = maximum contaminant level; MCLG = maximum contaminant level goal; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TLV = threshold limit values; TWA = time-weighted average; WHO = World Health Organization