# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Barium is an alkaline earth metal with an atomic number of 56 and is classified in Group IIA of the periodic table of elements. Its outer shell of electrons has a 6s^2^ configuration. Because barium is highly reactive, it exists in the environment in the +2 oxidation state, which is its only oxidation state.

Barium forms useful alloys with aluminum and magnesium, which are used as getters in electronic tubes to remove residual gases (Genter 2001). Barium is also used as a deoxidizer for steel and other metals (Boffito 2002).

Barium reacts with several other elements to form commercially-important compounds. Of these, eight barium compounds are covered in this chapter: barium acetate, barium carbonate, barium chloride, barium cyanide, barium, hydroxide, barium oxide, barium sulfate, and barium sulfide. Their chemical formulas, structures, synonyms, and identification numbers, in addition to those for barium metal, are listed in Table 4-1.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Metallic barium is a silvery-white soft metal, but takes on a silver-yellow color when exposed to air (Boffito 2002; Genter 2001). Like other alkaline earth metals, barium decomposes in water, evolving hydrogen gas. Barium oxidizes readily in moist air. In powdered form, barium reacts violently with air. Because of its high reactivity, barium does not exist as the metal in the environment; it exists in a combined state with other elements.

The barium compounds, barium acetate, barium chloride, barium cyanide, barium hydroxide, and barium oxide, are quite soluble in water. Barium carbonate and sulfate are poorly soluble in water. Barium oxide reacts rapidly with carbon dioxide in water to form barium hydroxide and barium carbonate (Dibello et al. 2003). Barium sulfide slowly decomposes in water, forming barium hydroxide and barium hydrosulfide. Barium sulfide is also known to undergo slow oxidation in solution to form elemental sulfur and various oxidized sulfur species including the sulfite, thiosulfate, polythionates, and sulfate. The water solubility of barium compounds increases with decreasing pH (IPCS 1991).

Table 4-1 Chemical Identity of Barium and Barium Compounds^a^

Characteristic | Barium | Barium acetate | Barium carbonate | Barium chloride | Barium cyanide | Barium hydroxide | Barium oxide | Barium sulfate | Barium sulfide
Synonyms | No data | Acetic acid, barium salt; barium diacetate | Carbonic acid, barium salt; barium monocarbonate; Pigment White 10; BW-C3; BW-P | Barium dichloride; NCI-C61074; SBa 0108E | Barium dicyanide | Barium dihydroxide; barium hydroxide lime; caustic baryta | Barium monoxide; barium protoxide; baryta; calcined baryta | Artificial heavy spar; artificial barite; baridol; barytes; blanc fixe; C.I. Pigment White 21; Citobaryum; Enamel White; E-Z-Paque; Solbar; precipitated barium sulphate; sulfuric acid, barium salt^f^ | Barium suphide
Trade names | No data | No data | No data | No data | No data | No data | No data | No data | No data
Chemical formula | Ba | Ba(C_2_H_3_O_2_)_2_ | BaCO_3_ | BaCl_2_ | Ba(CN)_2_ | Ba(OH)_2_ | BaO | BaSO_4_ | BaS
Chemical structure | Ba | [image] | [Ba^2+^] [CO_3_^2−^] | [Ba^2+^] [Cl^−^]_2_ | [Ba^2+^] [CN^−^]_2_ | [Ba^2+^] [OH^−^]_2_ | [Ba^2+^] [O^2−^] | [Ba^2+^] [SO_4_^2−^] | [Ba^2+^] [S^2−^]
Identification numbers:
CAS registry | 7440-39-3 | 543-80-6 | 513-77-9 | 10361-37-2 | 542-62-1 | 17194-00-2 | 1304-28-5 | 7727-43-7 | 21109-95-5
NIOSH RTECS | CQ8370000^b^ | AF4550000^b^ | CQ8600000^b^ | CQ8750000^b^ | CQ8785000^b^ | CQ9200000^b^ | CQ9800000^b^ | CR0600000^b^ | CR0660000^b^
EPA hazardous waste | D005 | No data | D005 | D005 | PO13/D003/D005 | D005 | No data | D005 | No data
DOT/UN/NA/IMCO shipping | UN1440/IMO 4.3 | No data | UN 1564/IMO 6.1 | UN 1564/IMO 6.1 | UN 1565/IMO 6.1 | UN 1564/IMO 6.1 | UN1884 | UN1564/IMO6.1 | UN1564/IMDG6.1^c^
HSDB | 4481 | No data | 950 | 2633 | 403 | 1605 | 215-127-9 | 231-784-4 | 244-214-4
EINECS | 231-149-1 | 208-849-0 | 208-167-3 | 233-788-1 | 208-822-3 | 241-234-5 | No data | 5041 | No data
NCI | No data | No data | No data | No data | No data | No data | No data | No data | No data

a All information obtained from HSDB 2007 and ChemIDplus 2007 except where noted

b RTECS 2007

c Kresse et al. 2007

CAS = Chemical Abstracts Service; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/Intergovernmental Maritime Dangerous Goods Code; EINECS = European Inventory of Existing Commercial chemical Substances; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; RTECS = Registry of Toxic Effects of Chemical Substances

Information regarding the physical and chemical properties of barium and barium compounds is located in Table 4-2.

Table 4-2 Physical and Chemical Properties of Barium and Barium Compounds^a^

Property | Barium | Barium acetate | Barium carbonate | Barium chloride | Barium cyanide | Barium hydroxide | Barium oxide | Barium sulfate | Barium sulfide
Molecular weight | 137.327 | 255.416 (anhydrous) 273.431 (monohydrate) | 197.336 | 208.232 (anhydrous); 244.263 (dihydrate)^e^ | 189.361 | 171.342 (anhydrous); 189.357 (monohydrate); 315.464 (octahydrate) | 153.326 | 233.391 | 169.393
Physical description | Silvery-yellow metal; cubic | White powder (anhydrous); white crystals (monohydrate) | White orthorhombic crystals | White hygroscopic orthorhombic crystals (anhydrous); white monoclinic crystals (dihydrate) | White crystalline powder | White powder (anhydrous, monohydrate); white monoclinic crystals (octahydrate) | White-yellow powder; cubic and hexagonal crystals | White orthorhombic crystals | Colorless cubic crystals or gray powder
Melting point | 727 °C | Decomposes at 110 °C (monohydrate) | 1,555 °C | 962 °C (anhydrous); decomposes at approximately 120 °C (dihydrate) | No data | 408 °C (anhydrous); decomposes at 78 °C (octahydrate) | 1,972 °C | 1,580 °C | 2,229 °C
Boling point | 1,897 °C | No data | No data | 1,560 °C (anhydrous) | No data | No data | No data | No data | No data
Density | 3.62 g/cm^3^ | 2.47 g/cm^3^ (anhydrous); 2.19 g/cm^3^ (monohydrate) | 4.2865 g/cm^3^ | 3.9 g/cm^3^ (anhydrous); 3.097 g/cm^3^ (dihydrate) | No data | 3.743 g/cm^3^ (monohydrate); 2.18 g/cm^3^ (octahydrate) | 5.72 g/cm^3^ (cubic) | 4.49 g/cm^3^ | 4.3 g/cm^3^
Specific gravity | No data | 2.02 (below 24.7 °C)^b^ | No data | No data | No data | 4.495 (anhydrous)^h^ | 5.32 (hexagonal)^b^ | 4.50^b^ | No data
Odor | No data | No data | Odorless^c^ | Odorless^g^ | No data | No data | Odorless^g^ | Odorless^d^ | Sulfurous
Odor threshold | No data | No data | No data | No data | No data | No data | No data | No data | No data
Solubility:
Water | Reacts with water | 79.2 g/100 g water at 25 °C | 0.0014 g/100 g water at 20 °C; soluble in dilute HCl, HNO_3_, and acetic acid^d^; soluble in NH_4_Cl and NH_4_NO_3_ solutions^d^ | 37.0 g/100 g water at 25 °C | 800 g/L (at 14 °C)^e^ | 4.91 g/100 g water at 25 °C | 1.5 g/100 g water at 20 °C | 00.00031 g/100 g water at 20 °C | 8.94 g/100 g water at 25 °C
Organic solvents | Slightly soluble in ethanol | Slightly soluble in ethanol (monohydrate) | Insoluble in alcohol^e^ | Insoluble in ethanol (dehydrate) | 180 g/L (in 70% alcohol at 14 °C)^e^ | Soluble in methanol^d^ | Soluble in ethanol; insoluble in acetone | Insoluble in ethanol | No data
Partition coefficients | No data | No data | No data | No data | No data | No data | No data | No data | No data
Vapor pressure | 6.65×10^−4^ mmHg (at 630 °C)^f^; 0.998 mmHg (at 1,050 °C)^f^ | No data | Essentially zero^g^ | Essentially zero^g^ | No data | 0 mm Hg at 15 °C (monohydrate)^i^; 11.4 mm Hg at 15 °C (water vapor pressure of octahydrate)^i^ | Essentially zero^g^ | No data | No data
Henry’s law coefficients | No data | No data | No data | No data | No data | No data | No data | No data | No data
Autoignition temperature | No data | No data | Nonflammable^c^ | No data | Nonflammable^c^ | No data | No data | No data | No data
Flashpoint | No data | No data | Nonflammable^c^ | No data | Nonflammable^c^ | No data | No data | No data | No data
Flammability limits | Explosion hazard if exposed to moist air^d^ | No data | Nonflammable^c^ | No data | Nonflammable^c^ | No data | Produces heat on contact with water or steam^k^ | Noncombustible^k^ | Flammable by spontaneous chemical reactions^k^
Conversion factors | No data | No data | No data | No data | No data | No data | No data | No data | No data
Explosive limits | No data | No data | No data | No data | No data | Explosive >216 °C^j^ | Contact with CO_2_ may cause explosion^k^ | Heating with aluminum may cause violent explosions^k^ | Air, moisture, or acid fumes may cause it to ignite^k^

a All information obtained from Lide 2005 except where noted

b Dibello et al. 2003

c DOT 2005

d Budavari et al. 2001

e Weast 1989

f Boffito 2002

g NIOSH/OSHA 1978

h Perry and Chilton 1973

i Preisman and Davis 1948

j HSDB 2007

k Lewis 2000