# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Environmental Medicine, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology and Environmental Medicine, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-32, Atlanta, Georgia 30333.

## Barium, Soluble Salts Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Barium, Soluble Salts
CAS Numbers:
Date: | August 2007
Profile Status: | Final
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 23
Species: | Rat

[underlined: Minimal Risk Level]: 0.2 [X] mg/kg/day [ ] ppm

[underlined: Reference]: NTP. 1994. Toxicology and carcinogenesis studies of barium chloride dihydrate (CAS No. 10326–27-9) in F344/N rats and B6C3F1 mice (drinking water studies). Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health, National Toxicology Program. NTP TR 432.

[underlined: Experimental design]: Groups of 10 male and 10 female F344/N rats were administered 0, 125, 500, 1,000, 2,000, or 4,000 ppm barium chloride dihydrate in drinking water for 90 days. Using measured body weights and water consumption, the investigators estimated the daily barium doses to be 0, 10, 30, 65, 110, and 200 mg barium/kg/day for males and 0, 10, 35, 65, 115, and 180 mg barium/kg/day for females. Neurobehavioral tests (spontaneous motor activity, grip strength, tail flick latency, startle response, hindlimb foot splay) were performed prior to exposure and after 45 and 90 days of exposure. Cardiovascular testing (heart rate, blood pressure, and electrocardiogram) was conducted prior to exposure and after 45 and 91 days of exposure. Organ weights (adrenal gland, brain, heart, liver, kidney, lung, testis, thymus), blood analysis for hematological and clinical chemistry (barium, sodium, potassium, calcium, and phosphorus levels) alterations, and histological examination of major tissues and organs (only in the 200/180 mg/kg/day group) were conducted at termination; kidney, liver, spleen, and thymus of male and female rats in the 110/115 mg/kg/day groups and adrenal gland, heart, and salivary gland of female rats in the 115 mg/kg/day group were also examined microscopically.

[underlined: Effect noted in study and corresponding doses]: Exposure-related deaths were observed during the last week in 30% of the males and 10% of the females exposed to 200/180 mg barium/kg/day. Significant decreases in final body weights were also observed in the 200 mg barium/kg/day males (13% lower than controls) and 180 mg barium/kg/day females (8% lower than controls); significant decreases in water consumption (approximately 30% lower than controls) were also observed at this dose level. Marginal, but statistically significant, decreases in undifferentiated motor activity was observed in all groups of rats exposed to barium for 90 days, except females exposed to 115 mg barium/kg/day; no other alterations in neurobehavioral performance were observed. No significant alterations in heart rate, blood pressure, or EKG readings were observed. Significant increases in serum phosphorus levels were observed in males in the 110 and 200 mg barium/kg/day groups and females in the 35, 65, 115, and 180 mg barium/kg/day groups; however, the investigators noted that these increases were probably an artifact from hemolysis of collected blood samples. Significant increases in absolute and relative kidney weights were observed in females exposed to 115 or 180 mg barium/kg/day and increases in relative kidney weights were also observed in males at 200 mg barium/kg/day. An increase in relative kidney weight was also observed in the females exposed to 65 mg barium/kg/day. The magnitude of the increases in relative kidney weights were 7, 14, and 19% in the females exposed to 65, 115, and 180 mg barium/kg/day and 12% in males exposed to 200 mg barium/kg/day.;Minimal to mild, focal to multifocal dilatation of the proximal convoluted tubules of the outer medulla and renal cortex was observed in three male and three female rats in the 200/180 mg barium/kg/day group. The small increase in relative kidney weight (7%) observed in the female rats exposed to 65 mg barium/kg/day was not considered biologically significant because it is not supported by an increase in histological alterations in the kidney at 65 or 115 mg barium/kg/day or in rats exposed to 75 mg barium/kg/day for 2 years (NTP 1994).

[underlined: Dose and end point used for MRL derivation]: The MRL is based on a NOAEL of 65 mg barium/kg/day for increased absolute and relative kidney weight. The increased kidney weight was considered an early indicator of potentially more serious effects in the kidney. A NOAEL/LOAEL approach was used to derive the MRL because none of the available benchmark dose models provided an adequate fit to the absolute or relative kidney weight data.

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]: 100

- [ ] 10 for use of a LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Modifying Factor used in MRL derivation]: 3

- [X] 3 for database deficiences

A modifying factor of 3 was included to account for deficiencies in the oral toxicity database, particularly the need for an additional developmental toxicity study. Decreases in pup birth weight and a nonstatistically significant decrease in live litter size were observed in the offspring of rats exposed to 180/200 mg Ba/kg/day as barium chloride in drinking water prior to mating (Dietz et al. 1992). Maternal body weight gain and water consumption were not reported, thus it is not known if the decreases in pup body weight were secondary to maternal toxicity or direct effect on the fetus. No developmental effects were observed in mice at the highest dose tested (200 mg Ba/kg/day) (Dietz et al. 1992). One other study examined the potential for developmental toxicity in orally exposed animals (Tarasenko et al. 1977). However, because the study was poorly reported and no incidence data or statistical analysis were presented in the published paper, the reported findings of increased mortality and systemic toxicity in the offspring of an unspecified species orally exposed to barium during conception and pregnancy can not be adequately evaluated. The Dietz et al. (1992) study was designed to be a mating trial and did not expose the animals during gestation; thus, database is lacking an adequate study to evaluate the potential for barium to induce developmental effects.

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? No. Doses were calculated by the investigators using measured drinking water consumption and body weight data.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? Not applicable.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: There are limited data on the toxicity of barium in humans following repeated doses. Wones et al. (1990) found no significant alterations in blood pressure or ECG readings, relative to initial baseline measurements in men experimentally exposed to up to 0.2 mg barium/kg/day as barium chloride in drinking water for 4 week (Wones et al. 1990). These findings are supported by several animal studies that did not find significant alterations in blood pressure or ECG readings in rats exposed to 150–180 mg barium/kg/day in drinking water for 13 or 16 weeks, respectively (McCauley et al. 1985; NTP 1994). A study by Perry et al. (1983, 1985, 1989) found significant increases in blood pressure in rats administered 8.6 or 11 mg barium/kg/day as barium chloride in drinking water for 1 or 4 months, respectively. The reason for the differences between the results from the Perry et al. (1983, 1985, 1989) study and the NTP (1994) and McCauley et al. (1985) studies is not known. It is possible that the diet used in the Perry et al. (1983, 1985, 1989) study influenced the results. In this study, the rats were fed a low-mineral diet; the calcium content of the rye-based diet was 3.8 mg/kg, which is lower than the concentration recommended for maintenance, growth, and reproduction of laboratory rats (NRC 1995b).

The results of studies by McCauley et al. (1985) and NTP (1994) suggest that the kidney is the most sensitive target of toxicity in rats and mice. In the McCauley et al. (1985) study, glomerular alterations consisting of fused podocytes and thickening of the capillary basement membrane were found in rats exposed to 150 mg barium/kg/day in drinking water for 16 weeks. This lesion was found in uninephrectomized Sprague Dawley rats, Dahl salt-sensitive rats, and Dahl salt-resistant rats. In the NTP (1994) rat study, significant increases in absolute and relative kidney weights were observed in female rats exposed to 115 or 180 mg barium/kg/day and in males exposed to 200 mg barium/kg/day. A statistically significant increase in relative kidney weight was also observed in the females exposed to 65 mg barium/kg/day; however, the increase was small (7%) and was not considered biologically significant. At 200 and 180 mg barium/kg/day, minimal to mild dilatation of the proximal renal cortex was observed in the males and females, respectively; an increase in mortality (30%) was also observed in the males exposed to 200 mg barium/kg/day. In mice, mild to moderate nephropathy (characterized as tubule dilatation, regeneration, and atrophy) was observed in 100% of the males exposed to 450 mg barium/kg/day and 90% of the females exposed to 495 mg barium/kg/day; no renal lesions were observed at the next lowest dose level (205 and 200 mg barium/kg/day in males and females, respectively). Other effects observed at the 450/495 mg barium/kg/day dose level included weight loss, spleen and thymus atrophy, and increased mortality (60% of the males and 70% of females died after 5 weeks of exposure).

Other end points that have been examined in rats and mice include neurotoxicity, reproductive toxicity, and developmental toxicity. In male and female rats, slight decreases in undifferentiated motor activity were observed at 10 mg barium/kg/day and higher. However, with the exception of female rats exposed to 200 mg barium/kg/day, the difference between motor activity in the barium-exposed rats and the controls was less than 20%; this was not considered to be biologically significant. At 200 mg barium/kg/day, the difference was 30%, which was considered to be adverse. No significant alterations were found in performance on the remaining neurobehavioral tests (grip strength, tail flick latency, startle response, and hindlimb foot splay). In mice, a significant decrease in forelimb grip strength was observed in females exposed to 495 mg barium/kg/day; this may have been due to debilitation. No other alterations in neurobehavioral performance were found. No effects on reproductive tissues or reproductive performance were observed in rats or mice exposed to approximately 200 mg barium/kg/day (Dietz et al. 1992; NTP 1994). Pre-mating exposure to 180/200 mg barium/kg/day resulted in decreased litter size and body weight in rat offspring; the NOAEL for these effects was 110/115 mg barium/kg/day (Dietz et al. 1992). No developmental effects were observed in mice exposed to 200 mg barium/kg/day (Dietz et al. 1992).

[underlined: Agency Contacts (Chemical Managers)]: Cassandra Smith and Yee-Wan Stevens

## Barium, Soluble Salts Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Barium, Soluble Salts
CAS Numbers:
Date: | August 2007
Profile Status: | Final
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [ ] Intermediate [X] Chronic
Graph Key: | 49
Species: | Mouse

[underlined: Minimal Risk Level]: 0.2 [X] mg barium/kg/day [ ] ppm

[underlined: Reference]: NTP. 1994. Toxicology and carcinogenesis studies of barium chloride dihydrate (CAS No. 10326–27-9) in F344/N rats and B6C3F1 mice (drinking water studies). U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health, National Toxicology Program, Research Triangle Park, NC. NTP TR 432.

[underlined: Experimental design]: Groups of 60 male and 60 female B6C3F1 mice were administered 0, 500, 1,250, or 2,500 ppm barium chloride dehydrate in drinking water for 2 years. Using measured body weights and water consumption, the investigators estimated the daily barium doses to be 0, 30, 75, and 160 mg barium/kg/day for males and 0, 40, 90, and 200 mg barium/kg/day for females. Organ weights, blood analysis for hematological and clinical chemistry (barium, sodium, potassium, calcium, and phosphorus levels, and alanine aminotransferase, creatine kinase, lactate dehydrogenase, and gamma-glutamyltransferase activities) alterations (measured after 15 months), and histological examination of major tissues and organs were conducted at termination.

[underlined: Effect noted in study and corresponding doses]: Increased mortality attributed to renal lesions was observed in the 160/200 mg/kg/day group. Decreased body weights (<7%) were observed in the barium-exposed mice. The investigators noted that a moderate to marked weight loss was observed in animals dying early. No significant alterations in hematology or clinical chemistry parameters were observed. A significant increase in the incidence of nephropathy was observed in male and female mice exposed to 160/200 mg/kg/day. The nephropathy was characterized by extensive regeneration of cortical and medullary tubule epithelium, tubule dilatation, hyaline cast formation, multifocal interstitial fibrosis, and glomerulosclerosis in some kidneys. The incidence of nephropathy was 1/50, 0/50, 2/48, and 19/50 in the males and 0/50, 2/53, 1/50, and 37/50 in the females, respectively. The average severity of the nephropathy was 3.6 (moderate to marked) for both the males and females in the 160/200 mg/kg/day group. An increased incidence of lymphoid depletion in the spleen and decreased relative and absolute spleen were also observed in the 160/200 mg/kg/day group; however, this was attributed to debilitation associated with nephropathy rather than a direct effect on the spleen. No significant increases in the incidences of neoplasms were observed.

[underlined: Dose and end point used for MRL derivation]: Benchmark dose analysis of the dose-response data (Table A-1) for nephropathy in male and female mice exposed to barium chloride in drinking water for 2 years (NTP 1994) was conducted. EPA’s Benchmark Dose Software (version 1.3.2) was used to fit nine mathematical models to the incidence data. Model fit was judged by the p-values associated with the chi-square goodness-of-fit statistic generated by the models and visual inspection of the plot of observed and predicted values. As assessed by the chi-square goodness-of-fit test, several models in the software provided adequate fits to the data for the incidence of nephropathy in male and female mice (x^2^ p-value ≥0.1). As assessed by lowest Akaike Information Criterion (AIC), the logistic model for the male mouse data and the gamma model for the female mouse data provide the greatest fit. The results of the benchmark dose analysis are presented in Table A-2.

Table A-1 Incidence of Nephropathy in Male and Female Mice Exposed to Barium Chloride in Drinking Water for 2 Years (NTP 1994)

Water concentration (ppm) | Dose (mg barium/kg/day) | Incidence
Males
0 | 0 | 1/50
500 | 30 | 0/50
1,250 | 75 | 2/48
2,500 | 160 | 19/50
Females
0 | 0 | 0/50
500 | 40 | 2/53
1,250 | 90 | 1/50
2,500 | 200 | 37/50

Table A-2 Predictions from Models for Doses Associated with 10 and 5% Extra Risk for the Incidence of Nephropathy in Male and Female Mice Exposed to Barium in Drinking Water for 2 Years (NTP 1994)

Model | BMD_10_ mg/kg/day | BMDL_10_ mg/kg/day | BMD_5_ mg/kg/day | BMDL_5_ mg/kg/day | x^2^ p-value | AIC
Male mice
Logistic | 103.96 | 87.26 | 80.06 | 61.13 | 0.28 | 99.34
Probit | 96.13 | 80.07 | 71.96 | 54.66 | 0.13 | 100.11
Log-probit^a^ | 99.73 | 77.90 | 83.39 | 59.54 | 0.31 | 100.25
Gamma^b^ | 102.31 | 80.06 | 84.94 | 59.65 | 0.31 | 100.28
Log-logistic^a^ | 104.44 | 80.50 | 86.43 | 59.69 | 0.31 | 100.32
Weibull^b^ | 106.59 | 81.79 | 87.63 | 59.54 | 0.31 | 100.35
Quantal quadratic | 82.83 | 69.51 | 57.80 | 48.5 | 0.14 | 101.89
Multi-stage^c^ | 82.83 | 69.14 | 57.80 | 44.97 | 0.14 | 101.89
Quantal linear | NA | NA | NA | NA | 0.0032 | 111.94
Female mice
Gamma^b^ | 125.59 | 101.49 | 113.96 | 87.66 | 0.34 | 90.89
Log-probit^a^ | 134.85 | 100.63 | 125.10 | 88.39 | 0.17 | 92.84
Log-logistic^a^ | 147.43 | 101.75 | 137.35 | 87.01 | 0.17 | 92.84
Weibull^b^ | 153.60 | 102.66 | 142.51 | 84.95 | 0.17 | 92.84
Logistic | NA | NA | NA | NA | 0.08 | 92.35
Probit | NA | NA | NA | NA | 0.03 | 94.03
Quantal quadratic | NA | NA | NA | NA | 0.01 | 102.21
Multi-stage^c^ | NA | NA | NA | NA | 0.01 | 102.21
Quantal linear | NA | NA | NA | NA | 0.00 | 126.61

a slope restricted to >1

b restrict power ≥1

c restrict betas ≥0

degree of polynomial = 2; NA = not applicable

The BMDL_05_ for male mice was selected as the point of departure for deriving the chronic-duration oral MRL. Data from the male mice were used because they identify a lower BMDL than the female data. The predicted 5% incidence approach was selected over the other two approaches as a precaution due to the severity of the observed effects (moderate to marked severity nephropathy), which resulted in marked weight loss and increased mortality.

[ ] NOAEL [ ] LOAEL [X] BMDL

[underlined: Uncertainty Factors used in MRL derivation]: 300

- [ ] 10 for use of a LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Modifying Factor used in MRL derivation]: 3

- [X] 3 for database deficiences

A modifying factor of 3 was included to account for deficiencies in the oral toxicity database, particularly the need for an additional developmental toxicity study. Decreases in pup birth weight and a nonstatistically significant decrease in live litter size were observed in the offspring of rats exposed to 180/200 mg Ba/kg/day as barium chloride in drinking water prior to mating (Dietz et al. 1992). Maternal body weight gain and water consumption were not reported, thus it is not known if the decreases in pup body weight were secondary to maternal toxicity or direct effect on the fetus. No developmental effects were observed in mice at the highest dose tested (200 mg Ba/kg/day) (Dietz et al. 1992). One other study examined the potential for developmental toxicity in orally exposed animals (Tarasenko et al. 1977). However, because the study was poorly reported and no incidence data or statistical analysis were presented in the published paper, the reported findings of increased mortality and systemic toxicity in the offspring of an unspecified species orally exposed to barium during conception and pregnancy can not be adequately evaluated. The Dietz et al. (1992) study was designed to be a mating trial and did not expose the animals during gestation; thus, database is lacking an adequate study to evaluate the potential for barium to induce developmental effects.

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? No. Doses were calculated by the investigators using measured drinking water consumption and body weight data.

[underlined: Was a conversion used from intermittent to continuous exposure]? Not applicable.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Several studies have examined the toxicity of barium following chronic-duration exposure. Significant increases in blood pressure were observed in rats exposed to 0.8 mg barium/kg/day as barium chloride in drinking water for 16 months (Perry et al. 1983, 1985, 1989); the NOAEL for this effect was 0.17 mg barium/kg/day. At higher doses (7.2 mg barium/kg/day), depressed rates of cardiac contraction, reduced cardiac electrical conductivity, and decreased cardiac ATP levels were observed. As noted in the discussion of the intermediate-duration oral MRL, interpretation of the results of this study is limited due to the low mineral diet which may have supplied inadequate levels of calcium.

No adverse effects were observed in rats exposed to 60 mg barium/kg/day as barium chloride in drinking water for 2 years (NTP 1994), 15 mg barium/kg/day to an unspecified barium compound in drinking water for 68 weeks (McCauley et al. 1985), or 0.7 mg barium/kg/day as barium acetate in drinking water for a lifetime (Schroeder and Mitchener 1975a). In mice exposed to barium chloride in drinking water for 2 years, marked renal nephropathy was observed at 160 mg barium/kg/day; the increased incidence of nephropathy in the next lowest dose group (75 mg barium/kg/day) was not statistically significant. Other adverse effects observed at 160 mg barium/kg/day included weight loss and increased mortality.

The animal data provide suggestive evidence that the kidney is the most sensitive target of toxicity. A serious LOAEL of 160 mg barium/kg/day was identified for nephropathy in mice (NTP 1994); the NOAEL identified in this study is 75 mg/kg/day. Although no kidney lesions were observed in rats exposed to doses as high as 60 mg barium/kg/day (NTP 1994), the doses utilized in the study may not have been high enough to cause kidney damage. Biologically significant kidney alterations were observed at 115 mg barium/kg/day and higher in rats exposed for an intermediate duration (NTP 1994).

[underlined: Agency Contacts (Chemical Managers)]: Cassandra Smith and Yee-Wan Stevens