# 8 REFERENCES

* Cited in text

Aamand J, Jorgensen C, Arvin E, 1989. Microbial adaptation to degradation of hydrocarbons in polluted and unpolluted groundwater. Journal of Contaminant Hydrology 4:299–312.
* ACGIH. 1990. Threshold limit values and biological exposure indices for 1990–1991. American Conference of Governmental Industrial Hygienists. Cincinnati, OH.
* Ainsworth RW. 1960. Petrol-vapour poisoning. Br Med J 1:1547–1548.13792185
* Air Force. 1981. Analysis and environmental fate of Air Force distillate and high density fuels. Contract no. F0863580-C-0122. Tyndall &r Force Base, FL. Document no. ESL-TR-81–54.
* Air Force. 1989. Gasoline. In: The installation restoration program toxicology guide. Volume 4. Contract no. DE-AC05–840R21400. Wright-Patterson Air Force Base, OH. Document no. 65-l-65–46.
Aksoy M. 1989. Hematotoxicity and carcinogenicity of benzene. Environ Health Persp 82: 193– 197.
Alden CL. 1986. A review of unique male rat hydrocarbon nephropathy. Toxicol Pathol 14:109-111.2424069
Amacher DE, Zelljadt I. 1983. The morphological transformation of Syrian hamster embryo cells by chemicals reportedly non-mutagenic to Salmonella typhimurium. Carcinogenesis 4:291–295.6339095
* Andersson K, Nilsson CA, Nygren O. 1984. Anew method for the analysis of tetramethyllead in blood. Stand J Work Environ Health 10:51–55.
Angelescu E, Gurau P, Pogonaru G, 1990. Conversion of alkanes into gasoline on ZSM-5 zeolite catalysts. Revue Roumaine de Chimie 35:229–237.
* Anonymous. 1989. Toxicology update: Gasoline. J Appl Toxico1 9:203–210.
API. 1973. Final report on teratology study in rats. Washington, DC: American Petroleum Institute. Document no. FYI-AX-0183–0239.
API. 1976. Evaluation of three month inhalation toxicity of two motor fuels. API contract PS-6. Washington, DC: American Petroleum Institute. Document no. FYI-OTS-0885–0439.
API. 1979. Underground movement of gasoline on groundwater and enhanced recovery by surfactants. Washington, DC: American Petroleum Institute. Publication no. 4317.
API. 1980. Acute toxicity tests: Unleaded motor gasoline. API #PS-6. Washington, DC: American Petroleum Institute. Document no. FYI-OTS-0l8l-0100IN.
* API. 1982. Histopathological analysis of spinal cord of animals exposed to gasoline. Washington, DC: American Petroleum Institute. Document no. FYI-AX-0183–0143SU.
API. 1983a. Four-week oral nephrotoxicity screening study in male Fischer-344 rats: Phases I and II. Washington, DC: American Petroleum Institute. Document no. FYI-AX-1283–028OIN.
API. 1983b. Kidney effects of inhaled unleaded gasoline--comprehensive and critical summary of observations in rats and mice. Washington, DC: American Petroleum Institute. Document no. SEHQ-0483–0422.
API. 1983~. Motor fuel chronic inhalation study. Volume 1. Washington, DC: American Petroleum Institute. Document no. 8EHQ-0383–0422.
API. 1987. The L5178Y Tk +/− mouse lymphoma mutagenesis assay with API 220°-208°F distillate fraction of unleaded gasoline. Contract PS-61. Washington, DC: American Petroleum Institute. Document no. FYI-AX- 1187–0536.
* API. 1988. Unscheduled DNA synthesis in rat primary hepatocytes with PS-6 unleaded gasoline, its evaporation residue and a DMSO extract. Washington, DC: American Petroleum Institute. Document no. FYI-AX-1288–0576.
* API. 1991. Basic petroleum data book: Petroleum industry statistics. Vol. XI: January 1991. Washington, DC: American Petroleum Institute.
Ametz BB, Nicolich MJ. 1990. Modelling of environmental lead contributors to blood lead in human. Int Arch Occup Environ Health 62:397–402.2228261
Askergren A, Allgen LG, Karlsson C, 1981. Studies on kidney function in subjects exposed to organic solvents: 1. Excretion of albumin and B-Zmicroglobulin in the urine. Acta Med Stand 209:479–483.
*ASTM. 1989. Standard specification for gasoline. 1989 Annual book of ASTM standards: Petroleum products, lubricants, and fossil fuels. American Society for Testing and Materials. 1–14.
Astrand I. 1975. Uptake of solvents in the blood and tissues of man: A review. Stand J Work Environ Health 1: 199–218.
Astrand I. 1983. Effect of physical exercise on uptake, distribution and elimination of vapors in man. In: Fiserova-Bergerova V, ed. Modeling of inhalation exposure to vapors: Uptake, distribution and elimination. Boca Raton, FL: Chemical Rubber Company Press, 2:107–130.
* Atlas RM. 1981. Microbial degradation of petroleum hydrocarbons: An environmental perspective.crobial Rev 45: 180–209.
Atlas RM, Bartha R. 1973. Stimulated biodegradation of oil slicks using oleophilic fertilizers. Environ Sci Technol 7538–541.
* ATSDR. 1989. Toxicological profile for toluene. Agency for Toxic Substances and Disease Registry, Atlanta, GA.
* ATSDR. 1990. Toxicological profiles for 1,3-butadiene, 1,2-dibromoethane, ethylbenzene and xylene. Agency for Toxic Substances and Disease Registry, Atlanta, GA.
* ATSDR. 1991. Toxicological profiles for benzene and lead. Agency for Toxic Substances and Disease Registry, Atlanta, GA.
* ATSDR. 1992. Toxicological profiles for jet fuels, Otto fuel II, and fuel oils. Agency for Toxic Substances and Disease Registry, Atlanta, GA.
* Baarson K, Snyder CA, Green J, 1982. The hematotoxic effects of inhaled benzene on peripheral blood, bone marrow, and spleen cells are increased by ingested ethanol. Toxicol Appl Pharmacol 64:393–404.7135393
Baehr AL. 1987. Selective transport of hydrocarbons in the unsaturated zone due to aqueous and vapor phase partitioning. Water Resour Res 23:1926–1938.
Bailey EM, Meagher JF. 1986. Modeling the effect of ethanol gasoline blend usage on ozone formation in urban areas. J Air Pollut Control Assoc 36:808–812.
Baker JM. 1986. Ecological changes in Milford Haven during its history as an oil port. In: Baher JM, ed. Marine ecology and oil pollution. New York, NY: John Wiley and Sons, 55–66.
* Banner W Jr, Walson PD. 1983. Systemic toxicity following gasoline aspiration. Am J Emerg Med 1:292–294.6680634
* Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxico1 Pharmacol 8:471–486.
Battye W, Brown P, Misenheimer D, 1981. Control of hydrocarbon emissions from gasoline loading by refrigeration systems. Research Triangle Park, NC: Industrial Environmental Research Lab. EPA/600/7–8 l/l 21.
* Beamon RF, Siegel CJ, Landers G, 1976. Hydrocarbon ingestion in children: A six-year retrospective study. JACEP 5:771–775.1018351
* Beck LS, Hepler DI, Hansen KL. 1983. The acute toxicology of selected petroleum hydrocarbons. In: MacFarland HN, Holdsworth LE, MacGregor JA, , eds. Proceedings on the 1st Symposium on the toxicology of petroleum hydrocarbons, Washington, DC: American Petroleum Institute. May 1982. 1–12.
* Belkin F, Hable MA. 1988. Analysis of gasoline in water using a stripping preconcentration procedure. Bull Environ Contam Toxicol 40:244–248.3349196
Bender AP, Parker DL, Johnson RA, 1989. Minnesota highway maintenance worker study: Cancer mortality. Am J Ind Med 15:545–556.2741960
Benner BA Jr, Gordon GE, Wise SA. 1989. Mobile sources of atmospheric polycyclic aromatic hydrocarbons: A roadway tunnel study. Environ Sci Technol 23:1269–1278.
* Berglund PM, Petersson G. 1990. Hazardous petrol hydrocarbons from refuelling with and without vapor recovery. Sci Total Environ 91:49–57.2321000
Berry WD, Brammer JD. 1977. Toxicity of water-soluble gasoline fractions to fourth-instar larvae of the mosquito Aedes aegypti L. Environ Pollut 13:229–234.
*Boeckx RL, Post1 B, Coodin FJ. 1977. Gasoline sniffing and tetraethyl lead poisoning in children. Pediatrics 60:140–145.887326
Bolla-Wilson K, Wilson RJ, Bleecker ML. 1988. Conditioning of physical symptoms after neurotoxic exposure. J Occup Med 30:684–686.2460600
Bomhard E, Marsmann M, Rtihl-Fehlert C, 1990. Relationships between structure and induction of hyaline droplet accumulation in the renal-cortex of male-rats by aliphatic and alicyclic hydrocarbons. Arch Toxico1 64:530–538.
* Bond AM, McLachlan NM. 1986. Direct determination of tetraethyllead and tetramethyllead in gasoline by high-performance liquid chromatography with electrochemical detection at mercury electrodes. Anal Chem 58:756–758.
Booze RM, Mactutus CF. 1990. Developmental exposure to organic lead causes permanent hippocampal damage in Fischer-344 rats. Experientia 46:292–297.2311721
Borghoff SJ, Miller AB, Bowen JP, 1991. Characteristics of chemical-binding to alpha-2uglobulin in vitro - evaluating structure-activity-relationships. Toxico1 Appl Pharmacol 107:228–238.
Borghoff SJ, Short BG, Swenberg JA. 1990a. Biochemical-mechanisms and pathology of alpha-2u-globulin nephropathy. Ann Rev Pharmacol Toxico1 30:349–367.
Borghoff SJ, Youtsey NL, Swenberg JA. 1990b. Alpha-2u-globulin nephropathy (a2u-N) and renal cell proliferation in male rats exposed to European high test and PS-6 unleaded gasoline. Society of Toxicology 29th Annual Meeting, Miami, FL, February 12–16, 1990. Washington, DC: Society of Toxicology.
* Borghoff SJ, Youtsey NL, Swenberg JA. 1992. A comparison of European high test gasoline and PS-6 unleaded gasoline in their abilities to induce g,-globulin nephropathy and renal cell proliferation. Toxicology Letters (AMST) 63(1):21–33.
* Boniston Labs. 1985. Four-week oral nephrotoxicity screening study in male F344 rats. Submitted to American Petroleum Institute, Washington, DC by Borriston Laboratories, Inc., Temple Hills, MD. Doc# FYI-AX-0385–0280 SU.
* Bossert I, Bartha R. 1984. The fate of petroleum in soil ecosystems. In: Atlas RM, ed. Petroleum microbiology. New York, NY: MacMillan Publishing Company, 435–473.
* Bouchard DC, Mravik SC, Smith GB. 1990. Benzene and naphthalene sorption on soil contaminated with high molecular weight residual hydrocarbons from unleaded gasoline. Chemosphere 21:975–989.
Braddock JN. 1987. Factors influencing the composition and quantity of passenger car refueling emissions: Part 2. Washington, DC: U.S. Environmental Protection Agency. EPA/600/D-87–234. 37.
Brady JF, Xiao F, Gapac JM, 1990. Alteration of rat liver microsomal monooxygenase activities by gasoline treatment. Arch Toxico1 64:677–679.
Brandt L, Nilsson PG, Mitelman F. 1978. Occupational exposure to petroleum products in men with acute non-lymphocytic leukemia. Br Med J 1:533.630211
* Bronstein AC, Currance PL. 1988. Emergency care or hazardous materials exposure. Washington, DC: The C.V. Mosby Comp., 175–176.
* Brown RH. 1988. Determination of gasoline hydrocarbons in industrial air by two-stages (chromosorb/charcoal) adsorption, thermal desorption and capillary gas chromatography. IARC Sci Pub1 243–251.
* Brugnone F, Pasini F, Perbellini L, 1986. Analysis of environmental pollutants in the breath and blood of humans. Chem Environ Proc Int Conf 403–409.
Brzecki A, Misztal S, Kostolowski R. 1973. Neurological symptoms and labyrinthine irritability in persons occupationally exposed to the action of certain organic solvents. Ann Acad Med Lodz 14:55–60.
* Buchet JP. 1988. Determination of phenol and its glucurono- and sulfoconjugates in urine by gas chromatography. In: Fishbein L, O’Neill JK, eds. Environmental carcinogens method of analysis and exposure measurement. Vol. 10--benzene and alkylated benzenes. New York, NY: Oxford University Press, 28 l-286.
* Buchwald H. 1966. The calorimetric determination of phenol in air and urine with a stabilized diazonium salt. Ann Occup Hyg 9:7–14.5900993
* Budavari S, O’Neil MJ, Smith A, , eds. 1989. The Merck index: An encyclopedia of chemicals, drugs, and biologicals. Rahway, NJ: Merck and Co., Inc, 4269.
Bums CB, Godwin IR. 1991. A comparison of the effects of inorganic and alkyllead compounds on human erythrocytic delta-aminolevulinic-acid dehydratase (ALAD) activity in vitro. J Appl Toxicol 11:103–111.2061546
Busey WM, Cockrell BY. 1984. Nonneoplastic exposure-related renal lesions in rats following inhalation of unleaded gasoline vapors. In: Mehlman MA, Hemstreet GP III, Thorpe JJ, , eds. Advances in modem environmental toxicology. Vol. 7: Renal effects of petroleum hydrocarbons. Princeton, NJ: Princeton Scientific Publishers, Inc., 57–64.
* Butterworth BE, Smith-Oliver T, Earle L, 1989. Use of primary cultures of human hepatocytes in toxicology studies. Cancer Res 49:1075–1084.2917345
Byrd DS, Gilmore JT, Lee RH. 1983. Effects of decreased use of lead in gasoline on the soil of a highway. Environ Sci Technol 17:121–123.22295965
* Calabrese EJ. 1978. Pollutants and high-risk groups: The biological basis of increased human susceptibility to environmental and occupational pollutants. New York, NY: John Wiley and Sons, 43–44, 99.
* Carlson DH. 1981. Right middle lobe aspiration pneumonia following gasoline siphonage [letter]. Chest 80:246–247.
* Camevale A, Chiarotti M, De Giovanni N. 1983. Accidental death by gasoline ingestion: Case report and toxicological study. Am J Forensic Med Pathol 4:153–157.6859002
* Carroll HG, Abel GG. 1973. Chronic gasoline inhalation. South Med J 66:1429–1430.4760330
* Carroquino MJ, Gersberg RM, Dawsey WJ, 1992. Toxicity reduction associated with bioremediation of gasoline-contaminated groundwaters. Bulletins of Environmental Contamination and Toxicology 49(2):224–23 1.
* CELDS. 1991. Computer-Environmental Legislative Data Systems. University of Illinois, Urbana, IL. June 20, 1991.
Charbonneau M, Short BG, Lock EA, 1987. Mechanism of petroleum-induced sex-specific protein droplet nephropathy and renal cell proliferation in Fischer-344 rats: Relevance to humans. In: Hemphill DD, ed. Trace substances in environmental health, 21st Annual Conference, St. Louis, MO. Columbia, MO: University of Missouri. 263–273.
* Chessare JB, Wodarcyk K. 1988. Gasoline sniffing and lead poisoning in a child. Am Fam Physician 38:181–182.
* Cline PV, Delfino JJ, Rao PSC, 1991. Partitioning of aromatic constituents into water from gasoline and other complex solvent mixtures. Environ Sci Technol 25:914–920.
* CLPSD. 1989. Contract Laboratories Statistical Database. U.S. Environmental Protection Agency, Washington, DC. July 1989.
Coker DT, Christian F, Claydon MF, 1988. Survey of exposures to gasoline vapour. NTIS/PB88–108188. Issue 02.
* Coleman WE, Munch JW, Streicher RP, 1984. The identification and measurement of components in gasoline, kerosene, and no. 2 fuel oil that partition into the aqueous phase after mixing. Arch Environ Contam Toxico1 13:171–178.
* Conaway CC, Schreiner CA, Cragg ST. 1984. Mutagenicity evaluation of petroleum hydrocarbons. In: MacFarland HN, Holdsworth CE, MacGregor JA, , eds. Advances in modem environmental toxicology. Volumn VI. Applied toxicology petroleum hydrocarbons, Princeton, NJ: Princeton Scientific Publishers, Inc., 89–107.
Concawe. 1992. Gasolines. Report No. 92/103. Brussels.
Cooper P. 1980. A whiff of petrol. Food Cosmet Toxico1 18:433–434.
Cooper S. 1981. Infrared breath alcohol analysis following inhalation of gasoline fumes. J Anal Toxico1 5:198–199.
Corapcioglu MY, Baehr A. 1985. Immiscible contaminant transport in soils and groundwater with an emphasis on petroleum hydrocarbons: System of differential equations vs single cell model. Water Science and Technology 17:23–37.
* Corapcioglu MY, Hossain MA. 1990. Theoretical modeling of biodegradation and biotransformation of hydrocarbons in subsurface environments. J Theor Biol 142503–516.
* Coulehan JL, Hirsch W, Brillman J, 1983. Gasoline sniffing and lead toxicity in Navajo adolescents. Pediatrics 7 1: 113– 117.
* CRCS. 1985. Unleaded gasoline. CRCS, Inc., Rockville, MD. Contract no. 68–01-6650.
CRISP. 1991. Computer Retrieval of Information on Scientific Projects. National Library of Medicine. Medlars Toxline File.
CRIS/USDA. 1991. Gasoline. Current Research Information Program/U.S. Department of Agriculture, Beltsville, MD. May 1991.
* Cupitt LT. 1980. Project summary: Fate of toxic and hazardous materials in the air environment. Research Triangle Park, NC: U.S. Environmental Research Laboratory, U.S. Environmental Protection Agency. EPA-600/53–80-084.
Das M, Bhargava SK, Kumar A, 1991. An investigation of environmental impact on health of workers at retail petrol pumps. Annals of Occupational Hygiene 35(3):347–352.1888105
* Davis A, Shafer LF, Bell ZG, 1960. The effects on human volunteers of exposure to air containing gasoline vapor. Archives of Environmental Health 1:548–554.13720134
* Dell’Acqua R, Bush B, Egan J. 1976. Identification of gasoline contamination of groundwater by gas chromatography. J Chromatogr 128:271–280.1002783
DHHS. 1986. A proportionate mortality ratio analysis of gasoline station attendants and automobile mechanics in New Hampshire. Washington, DC: Department of Health and Human Services. Document no. FYI-OTS-1286–0522.
Dibble JT, Bartha R. 1979a. Effect of environmental parameters on the biodegradation of oil sludge. Appl Environ Microbial 37:729–739.
Dibble JT, Bartha R. 1979b. Rehabilitation of oil-inundated agricultural land: A case history. Soil Science 128:56–60.
* Dietrich DR, Swenberg JA. 1991. NCI-Black Reiter (NBR) male rats fail to develop renal disease following exposure to agents that induce alpha-2p-globulin (alpha-2u) nephropathy. Fundam Appl Toxico1 16:749–762.
* Dimock CW, Lake JL, Norwood CB, 1980. Field and laboratory methods for investigating a marine gasoline spill. Environ Sci Technol 14:1472–1475.22279990
DOE. 1982. Summary statistics. Washington, DC: U.S. Department of Energy. Petroleum supply monthly 12–33.
* DOE. 1989a. Petroleum supply annual 1989. Vol. 1. Washington, DC: U.S. Department of Energy.
* DOE. 1989b. Petroleum supply annual 1989. Vol. 2. Washington, DC: U.S. Department of Energy.
* DOE. 1989c. Transport and environmental chemistry of selected C_1_, and C_2_ chlorinated compounds and petroleum hydrocarbons in soils and groundwater. Contract no. W-7405-Eng-48. Department of Energy. UCRL-53952.
*DOE. 1990. Petroleum supplv monthly: October 1990. Washington, DC: U.S. Department of Energy.
* DOI. 1984. A study of the mechanisms controlling gasoline hydrocarbon partitioning and transport in groundwater systems. Contract no. 14–08-001-G-832. Reston, VA: U.S. Geological Survey, U.S. Department of the Interior. Project no. 370706.
* Domask WG. 1984. Introduction to petroleum hydrocarbons: Chemistry and composition in relation to petroleum-derived fuels and solvents. In: Mehlman MA, Hemstreet GP, Thorpe JJ, , eds. Advances in modem environmental toxicology. Vol. VII: Renal effects of petroleum hydrocarbons. Princeton, NJ: Princeton Scientific Publishers, Inc., 1-23.
* Donaldson SG, Miller GC, Miller WW. 1992. Remediation of gasoline-contaminated soil by passive volatilization. Journal of Environmental Quality 21(1):94–102.
* Dooley JF, Skinner MJ, Roy TA, 1988. Evaluation of the genotoxicity of API reference unleaded gasoline. In: Cooke M, Dennis AJ, eds. Polynuclear aromatic hydrocarbons: A decade of progress. Proceedings of The Tenth International Symposium. Columbus, OH: Battelle Press, 179–194.
Doskin VA. 1971. Effect of age on the reaction to a combination of hydrocarbons. Hyg Sanit 36:379–384.
* Dossing M, Loft S, Sonne J, 1988. Antipyrine and metronidazole metabolism during occupational exposure to gasoline. Int Arch Occup Environ Health 60: 115-l 18.3346081
* DOT. 1989a. Hazardous materials table. U.S. Department of Transportation. Code of Federal Regulations. 49 CFR 172.101.
* DOT. 1989b. Hazardous materials table and hazardous materials communications regulations. U.S. Department of Transportation. Federal Regulations 54:39501–39505.
Dowd RM. 1984. Leaking underground storage tanks. Environ Sci Technol 18:309A.
Dresen MD, Hoffman F, Lovejoy S Jr. 1987. Subsurface distribution of hydrocarbons in the building 403 area at LLNL. Washington, DC: U.S. Department of Energy. NTIS/DE86015098. Issue 08.
* Drinker P, Yaglou CP, Warren MF. 1943. The threshold toxicity of gasoine vapor. Journal of Industrial Hygiene and Toxicology 25:225–232.
Dunker AM. 1990. Relative reactivity of emissions from methanol-fueled and gasoline-fueled vehicles in forming ozone. Environ Sci Technol 24:853–862.
Eastwell HD. 1979. Petrol-inhalation in aboriginal towns: Its remedy: The homelands movement. Med J Aust 2:221–224.514145
Edminister SC, Bayer MJ. 1985. Recreational gasoline sniffing: Acute gasoline intoxication and latent organolead poisoning: Case reports and literature review. J Emerg Med 3:365–370.3938984
* Edwards JW, Priestly BG. 1993. Sister chromatid exchanges in lymphocytes of petroleum retailers. British Journal of Industrial Medicine 50(2):149–154.8435347
Ehrhardt M. 1987. Photo-oxidation products of fossil fuel components in the water of Hamilton Harbour, Bermuda. Marine Chemistry 22:85–94.
* Eiceman GA, Fleischer ME, Leasure CS. 1987. Sensing of petrochemical fuels in using headspace analysis with photoionization-ion mobility spectrometry. Int J Environ Anal Chem 28:279–296.
* Ellenhorn MJ, Barceloux DG, eds. 1988. Medical toxicology: Diagnosis and treatment of human poisoning. New York, NY: Elsevier Science Publishing Comp., Inc., 840–844, 940–946.
Enterline PE, Viren J. 1985. Epidemiologic evidence for an association between gasoline and kidney cancer. Environ Health Perspect 62:303–3 12.4085434
EPA. 1977a. Regulation of fuels and fuel additives. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 80.
EPA. 1977b. Regulation of fuels and fuel additives; information and reports; liability provisions. U.S. Environmental Protection Agency. Federal Register 42: 45306–45307.
* EPA. 1979a. Atmospheric reaction products of organic compounds. Washington, DC: U.S. Environmental Protection Agency. EPA-560/12–79-001.
EPA. 1979b. Water-related environmental fate of 129 priority pollutants. Vol. I and II. Washington, D.C.: U.S. Environmental Protection Agency. EPA-440/4–79-029a and -029b.
EPA. 1980a. Control of air pollution from new motor vehicles and motor vehicle engines; gaseous emission regulations for 1984 and later model year heavy-duty engines. Environmental Protection Agency. Federal Register 45:4136–4149.
EPA. 1980b. Control of air pollution from new motor vehicles and motor vehicle engines; gaseous emission regulations for 1984 and later model year light-duty engines. Environmental Protection Agency. Federal Register 45:63734–63784.
EPA. 1980~. Control of air pollution from new motor vehicles and new motor vehicle engines: Certification and test procedures. Code of Federal Regulations 40 CFR 86.
EPA. 1980d. Fate of toxic and hazardous materials in the air environment. Research Triangle Park, NC: U.S. Environmental Protection Agency, Environmental Sciences Research Laboratory.
* EPA. 1983a. Standards of performance for bulk gasoline terminals. U.S. Environmental Protection Agency. Code-of Federal Regulations. 40 CFR 60.500.
* EPA. 1983b. Standards of performance for new stationary sources; bulk gasoline terminals. U.S. Environmental Protection Agency. Federal Register 48:37578–37598.
EPA. 1984a. Estimation of the public health risk from exposure to gasoline vapor via the gasoline marketing system. Washington, DC: U.S. Environmental Protection Agency.
EPA. 1984b. Evaluation of air pollution regulatory strategies for gasoline marketing industry. Washington, DC: U.S. Environmental Protection Agency. EPA-450/3–84-012a.
* EPA. 1985a. Regulation of fuels and fuel additives. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 80.
* EPA. 1985b. Regulation of fuels and fuel additives; banking of lead rights. U.S. Environmental Protection Agency. Federal Register 50: 13116–13128.
* EPA. 1985~. Regulation of fuels and fuel additives; gasoline lead content. U.S. Environmental Protection Agency. Federal Register 50:9386–9399.
EPA. 1986. Gasoline exposures in the petroleum industry. Washington, DC: U.S. Environmental Protection Agency. Document no. 40–8689170.
* EPA. 1987a. Evaluation of the carcinogenicity of unleaded gasoline. Washington, DC: U.S. Environmental Protection Agency. EPA/600/6–87/001.
EPA. 1987b. Atmospheric persistence of eight air toxics. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA/600/3–87/004.
EPA. 1988a. Control of air pollution from new motor vehicles and new motor vehicle engines: Certification and test procedures. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 86.
EPA. 1988b. Control of air pollution from new motor vehicles and new motor vehicle engines; certification and test procedures; gasoline lead content. U.S. Environmental Protection Agency. Federal Register 53:470–478.
* EPA. 1988~. On-site gas analysis of gasoline components using a field-designed gas chromatographmass spectrometer. Washington, DC: U.S. Environmental Protection Agency. EPA/600/D-89089.
EPA. 1989a. Control of air pollution from new motor vehicles and new motor vehicle engines: Certification and test procedures. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 86.
EPA. 1989b. Control of air pollution from new motor vehicles and new motor vehicle engines; test procedures for light-duty vehicles and light-duty trucks and selective enforcement auditing lightduty vehicles, light-duty trucks and heavy-duty engines. U.S. Environmental Protection Agency. Federal Register 54:2118–2127.
EPA. 1990a. Certification programs for banking and trading of oxides of nitrogen and particulate emission credits for heavy-duty engines. U.S. Environmental Protection Agency. Federal Register 55:30584–30589.
EPA. 1990b. Control of air pollution from new motor vehicles and new motor vehicle engines: Certification and test procedures. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 86.
* EPA. 1990~. Interim methods for development of inhalation reference doses. Washington, DC: U.S. Environmental Protection Agency. EPA/600/890/066A.
* EPA. 1990d. Regulation of fuels and fuel additives. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 80.
* EPA. 1990e. Volatility regulations for gasoline and alcohol blends sold in calendar years 1989 and beyond. U.S. Environmental Protection Agency. Federal Register 55:25833–25836.
* EPA. 1991. Alphq,-globulin: Association with chemically-induced renal toxicity and neoplasia in the male rat. Washington, DC: U.S. Environmental Protection Agency. EPA/625/3–91/019F.
* Ervin ME, Manshe MG. 1990. Petroleum distillates and turpentine. In: Haddad LM, Winchester JF, eds., Clinical management of poisoning and drug overdose. Philadelphia, PA: W.B. Saunders Comp., 1177–1186.
* Esposito GG, Jacobs BW. 1977. Chromatographic determination of aromatic hydrocarbons in ambient air. Am Ind Hyg Assoc J 38:401–407.900028
Fabia J, Thuy TD. 1974. Occupation of father at time of birth of children dying of malignant diseases. Br J Prev Sot Med 28:98–100.
* FAO. 1977. Impact of oil on the marine environment. Food and Agriculture Organization of the United Nations, Rome. 13–41, 48–52.
FEDRIP. 1990. Federal Research in Progress: Gasoline. Dialog Information Services, Inc. Palo Alto, CA. April 1991.
* Feliciano. 1984. Leaking underground storage tanks: A potential environmental problem. Washington, DC: Library of Congress, Congressional Research Service, January 11. Report no. 84–508ENR
Ferry DG, Temple WA, McQueen EG. 1980. Toxicity of methanol/petrol mixtures. Proceedings International Symposium Alcohol Fuels Technolology 3:1–9.
Fieldner AC, Katz SH, Kinney SP. 1921. Permeability of oxygen breathing apparatus to gasoline vapors. Technical Paper 272. U.S. Bureau of Mines.
Fiserova-Bergerova V, Hughes HC. 1983. Species differences on bioavailability of inhaled vapor and gases. In: Fiserova-Bergerova V, ed. Modeling of inhalation exposure to vapors: Uptake distribution and elimination. Boca Raton, FL: CRC Press, 2:97–106.
Flegal AR, Coale KH. 1989. Trends in lead concentrations in major U.S. rivers and their relation to historical changes in gasoline-lead consumption. Water Res Bull 25:1275–1277.
Flodin U, Edling C, Axelson 0. 1984. Clinical studies of psychoorganic syndromes among workers with exposure to solvents. Am J Ind Med 5:287–295.6720692
Flowers TH, Pulford ID, Duncan HJ. 1984. Studies on the breakdown of oil in soil. Environmental Pollution (Series B) 8:71–82.
Foo SC. 1990. Benzene exposure from gasoline vapor. Inst Chem Eng Symp Ser 120:355–361.
Foo SC. 1991. Benzene pollution from gasoline usage. Sci Total Environ 103:19–26.1857958
Fortenberry JD. 1985. Gasoline sniffing. Am J Med 79:740–744.3907347
Franchini I, Cavatorta A, Falzoi M, 1983. Early indicators of renal damage in workers exposed to organic solvents. Int Arch Occup Environ Health 52:1–9.6603422
Gabele PA. 1990. Characterization of emissions from a variable gasoline/ methanol fueled car. J Air Waste Manage Assoc 40:296–304.1691650
* Gallassi R, Montagna P, Pazzaglia P, 1980. Peripheral neuropathy due to gasoline sniffing: A case report. Eur Neurol 19:419–421.6254778
* Garg BD, Olson MJ, Demyan WF, 1988. Rapid postexposure decay of alpha 2u-globulin and hyaline droplets in the kidneys of gasoline-treated male rats. J Toxico1 Environ Health 24:145–160.
* Garg BD, Olson MJ, Li LC, 1989. Phagolysosomal alterations induced by unleaded gasoline in epithelial cells of the proximal convoluted tubules of male rats: Effect of dose and treatment duration. J Toxico1 Environ Health 26: 101– 118.
* Garrettson LK. 1990. Lead. In: Haddad LM, Winchester JF, eds. Clinical management’of poisoning and drug overdose. 2nd ed. Philadelphia, PA: W.B. Saunders Comp, 1020–1023.
Gerhardsson de Verdier M, Palto N, Steineck G, 1992. Occupation exposures and cancer of the colon and rectum. American Journal of Industrial Medicine 22(3):291–303.1519614
* Gerin M, Viau C, Talbot D, 1988. Aviation gasoline: Comparative subchronic nephrotoxicity study in the male rat. Toxico1 Lett 44:13–19.
* Ghassemi M, Par&loo A, Quinlivan S. 1984. Physical and chemical characteristics of some widely used petroleum fuels: A reference data base for assessing similarities and differences between synfuel and petrofuel products. Energy Sources 7:377–401.
Gibson JE, Bus JS. 1988. Current perspectives on gasoline (light hydrocarbons)-induced male rat nephropathy. Ann NY Acad Sci 534:481–485.3389675
* Goldfrank LR, Kulberg AG, Bresnitz EA. 1990. Hydrocarbons. In: Golfrank’s toxicological emergencies. 4th ed. East Norwalk, CT: Appleton and Lange. 759–768.
* Goldings AS, Stewart RM. 1982. Organic lead encephalopathy: Behavioral change and movement disorder following gasoline inhalation. J Clin Psychiatry 43:70–72.7056707
* Goldstein BD. 1977. Hematotoxicity in humans. J Toxico1 Environ Health Suppl 2:69–105.
Goldsworthy TL, Sprankle CS, Strasser J, 1989. Cell replication in male and female mouse liver after inhalation exposure to unleaded gasoline. Society of Toxicology, 28th Annual Meeting, Atlanta, GA. Washington, DC: Society of Toxicology.
* Goodheart RS, Dunne JW. 1994. Petrol sniffers encephalopathy - A study of 25 patients. Medical Journal of Australia 160(4): 178–181.8309387
* Graham DR. 1990. Solvent abuse. In: Haddad LM, Winchester JF, eds. Clinical management of poisoning and drug overdose. 2nd ed. Philadelphia, PA: W.B. Saunders Comp., 1256–1260.
Green D. 1982. Gasoline use in the United States. In: Petroleum monthly, May 1982. Washington, DC: Energy Information Administration, U.S. Department of Energy.
* Grufferman S, Walker FW. 1982. Supraglottitis following gasoline ingestion. Ann Emerg Med 11:368–370.7091798
Guldberg PH, Round MM. 1990. Exposure and health risk assessment for gasoline and gasoline vapors. Pittsburgh, PA: Air and Waste Management Association, 83rd Annual Meeting and Exhibition.
* Gunster DG, Gillis CA, Bonnevie NL, 1993. Petroleum and hazardous chemical spills in Newark Bay, New Jersey, USA from 1982 to 1991. Environmental Pollution 82(3):245–253.15091773
* Hadley PW, Armstrong R. 1991. “Where’s the benzene?” Examining California (USA) ground-water quality surveys. Ground Water 29(1):35–40.
Hadnagy W, Seemayer NH. 1988. Cytotoxic and genotoxic effects of extract of particulate emission from a gasoline-powered engine. Environ Mol Mutagen 12:385–396.2461301
Hadnagy W, Seemayer NH. 1989. Genotoxicity of particulate emissions from gasoline-powered engines evaluated by short-term bioassays. Experimental Pathology 37:43–50.2484031
* Haines JR, Alexander M. 1974. Microbial degradation of high-molecular-weight alkanes. Appl Microbial 28:1084–1085.
* Halder CA, Holdsworth CE, Cockrell BY, 1985. Hydrocarbon nephropathy in male rats: Identification of the nephrotoxic components of unleaded gasoline. Toxicol Ind Health 1:67–88.3842552
* Halder CA, Van Gorp GS, Hatoum NS, 1986a. Gasoline vapor exposures: Part I. Characterization of workplace exposures. Am Ind Hyg Assoc J 47:164–172.3706142
Halder CA, Van Got-p GS, Hatoum NS, 1986b. Gasoline vapor exposures: Part II. Evaluation of the nephrotoxicity of the major C,/C, hydrocarbon components. Am Ind Hyg Assoc J 47:173–175.3706143
* Halder CA, Wame TM, Hatoum NS. 1984. Renal toxicity of gasoline and related petroleum naphthas in male rats. Adv Mod Environ Toxico1 7:73–88.
* Hall DMB, Ramsey J, Shwartz MS, 1986. Neuropathy in a petrol sniffer. Arch Dis Child 61:900–901.3021070
* Hansbrough JF, Zapata-Sirvent R, Dominic W, 1985. Hydrocarbon contact injuries. J Trauma 25:250–252.3981678
* Hansen KS, Sharp FR. 1978. Gasoline sniffing, lead poisoning, and myoclonus. JAMA 240:1375–1376.682330
* Harman AW, Frewin DB, Priestly BG. 1981. Induction of microsomal drug metabolism in man and in the rat by exposure to petroleum. Br J Ind Med 38:91–97.7470408
Harrington JM. 1987. Health experience of workers in the petroleum manufacturing and distribution industry: A review of the literature. Am J Ind Med 12:475–497.3318414
* Hathaway DL, Andrews CB. 1990. Fate and transport modeling of organic compounds from a gasoline spill. In: Petroleum hydrocarbon and organic chemicals in ground water: Prevention, detection and restoration. Houston, TX: S. S. Papadopulos and Associates, Inc., 563–576.
* HAZDAT. 1992. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA.
HEI. 1987. Gasoline vapor exposure and human cancer: Evaluation of existing scientific information and recommendations for future research. Report of the Institutes’ Health Review Committee, September 1985. Health Effects Institute. Cambridge, MA. 17–47.
Heinonen T, Elovaara E, Sade L., 1983. Effect of various solvents on the xenobiotic biotransformation in the liver and the kidneys of the rat: A comparative study. In: Rydstriim J, Montelius J, Bengtsson M, eds. Extrahepatic drug metabolism and chemical carcinogenesis. New York, NY: Elsevier Science Publishers. 29–33.
Higginson J, Muir C, Buffle PA. 1984. The epidemiology of renal carcinoma in humans with a note on the effect of exposure to gasoline. In: Mehlman MA, Hemstreet GP, Thorpe JJ, , eds. Advances in modem environmental toxicology. Vol 7: Renal effects of petroleum hydrocarbons. Princeton, NJ: Princeton Scientific Publishers, Inc., 203–226.
Hoag GE, Marley MC. Gasoline residual saturation in unsaturated uniform aquifer materials. J Environ Eng 112:586–604.
Hoffman H, Vervalin CH. 1990. Re-reformulating gasoline. Hydrocarbon Processing 69:15, 19.
* Hoffman DL, Swanson BZ Jr, Lutins ND. 1980. Gasoline-induced mucositis. J Am Dent Assoc 100:217.6928154
* Hogstedt B, HolmCn A, Karlsson A, 1991. Gasoline pump mechanics had increased frequencies and sizes of micronuclei in lymphocytes stimulated by pokeweed mitogen. Mut Res 26351–55.
Holmberg PC. 1979. Central-nervous system defects in children born to mothers exposed to organic solvents during pregnancy. Lancet 2:177–179.89284
Holmberg PC. 1980. Congenital defects of the central nervous system and occupational factors during pregnancy: A case referent study. Am J Ind Med 1:167–176.7342764
* Hood CB. 1973. Gasoline. In: Hampel CA, Hawley GG, eds. The encyclopedia of chemistry. 3rd ed. New York, NY: Van Nostrand Reinhold Company, 491–493.
Horowitz A, Atlas RM. 1977. Response of microorganisms to an accidental gasoline spillage in an arctic freshwater ecosystem. Appl Environ Microbial 33:1252–1258.
Hung LT, Gardos G, Szabo TK. 1990. Production of motor fuels by pyrolysis oil hydrocracking under severe conditions: II. Hungarian Journal of Industrial Chemistry 18:23–32.
* Hunter AGW, Thompson D, Evans JA. 1979. Is there a fetal gasoline syndrome? Teratology 20:75–79.515965
* IARC. 1989. IARC monographs on the evaluation of carcinogenic risks to humans. Vol. 45: Occupational exposures in petroleum refining; crude oil and major petroleum fuels. Lyon, France: World Health Organization, International Agency for Research on Cancer, 159–201.
* Ikebuchi J, Kotoku S, Yahsiki M, 1986. Gas chromatographic and gas chromatographic-mass spectrometric determination of gasoline in a case of gasoline vapor and alcohol poisoning. Am J Forensic Med Pathol 7:146–150.3740011
* Irving WS, Grumbles TG. 1979. Benzene exposures during gasoline loading at bulk marketing terminals. Am Ind Hyg Assoc J 40:468–473.484462
Jackson JE, Bertsch FM. 1990. Conversion of methanol to gasoline: A new mechanism for formation of the first carbon-carbon bond. J Am Chem Sot 112:9085–9092.
Jakobsson R, Ahlbom A, Bellander T, 1993. Acute myeloid leukemia among petrol station attendants. Archives of Environmental Health 48(4):255–259.8357276
Jamison VW, Raymond RL, Hudson JO Jr. 1975. Biodegradation of high-octane gasoline in groundwater. Dev Ind Microbial 16:305–312.
* Jamison VW, Raymond RL, Hudson JO. 1976. Biodegradation of high-octane gasoline. In: Sharpley JM, Kaplan AM, eds. Proceedings International Biodegradation Symposium 3rd. Essex, England, 187–196.
* Janssen S, Van Der Geest S, Meijer S, 1988. Impairment of organ function after oral ingestion of refined petrol. Intensive Care Med 14:238–240.3379185
Jeltes R, den Tonkelaar WA M. 1972. Gas chromatography versus infra-red spectrometry for determination of mineral oil dissolved in water. Water Res 6:271–278.
Jungers RH, Lee RE Jr, Von Lehmden DJ. 1975. The EPA National Fuels Surveillance Network: I. Trace constituents in gasoline and commercial gasoline fuel additives. Environ Health Perspect 10:143–150.1157783
* Kadamani S, Asal NR, Nelson RY. 1989. Occupational hydrocarbon exposure and risk of renal cell carcinoma. Am J Ind Med 15:131–141.2729279
* Kaelan C, Harper C, Vieira BI. 1986. Acute encephalopathy and death due to petrol sniffing: Neuropathological findings. Aust N Z J Med 16:804–807.3471199
* Kanai H, Inoye V, Goo R, 1991. Gas chromatographic mass-spectrometric analysis of polar components in weathered gasoline/water matrix as an aid in identifying gasoline. Anal Lett 24:115–128.
Kavet R. 1987. The health effects institute assessment of refueling vapors: A case study. Proceedings of the 80th Annual Meeting of APCA, New York, NY, June 21–26. 2: l-23.
* Kawai T, Yamaoka K, Uchida Y, 1991. Exposure to vapors of benzene and other aromatic solvents in tank truck loading and delivery. J Bull Environ Contam Toxico1 46:1–8.
* Keamey CA, Dunham DB. 1986. Gasoline vapor exposure at a high volume service station. Am Ind Hyg Assoc J 47:535–539.3766396
Keenlyside RA. 1984. The gasoline-sniffing syndrome. In: Grandjean P, Grandjean E, eds. Biological effects of organolead compounds. Boca Raton, FL: CRC Press, 219–225.
Kerkhoff MJ, Lee TM, Allen ER, 1985. Spectral fingerprinting of polycyclic aromatic hydrocarbons in-high-volume ambient air samples by constant energy synchronous luminescence spectroscopy. Environ Sci Technol 19:695–699.22166029
Kimura K, Hara K, Nagata T. 1989. A newly designed apparatus for testing blood levels of fuel vapor. Forensic Sci Int 40:57–61.2466743
* Kimura K, Nagata T, Hara K, 1988. Gasoline and kerosine components in blood - a forensic analysis. Hum Toxico1 7:299–305.
Kitchen DN. 1984. Neoplastic renal effects of unleaded gasoline in Fischer-344 rats. In: Mehlman MA, Hemstreet GP, Thorpe JJ, , eds. Advances in modem environmental toxicology. Vol. 7: Renal effects of petroleum hydrocarbons. Princeton, NJ: Princeton Scientific Publishers, Inc., 65–72.
* Kovanen J, Somer H, Schroeder P. 1983. Acute myopathy associated with gasoline sniffing. Neurology 33:629–631.6682500
Kramer WH. 1982. Ground-water pollution from gasoline. Ground Water Monit Rev 2:18–22.
* Kramer WH. 1989. Benzene exposure assessment of underground storage tank contractors. Appl Ind Hyg 4:269–272.
* Kuehnel E, Fisher P. 1986. Acute renal injury limited to the upper poles following gasoline ingestion. Kidney Int 29:304.
* Kullman GJ, Hill RA. 1990. Indoor air quality affected by abandoned gasoline tanks. Appl Occup Environ Hyg 5:36–37.
Kulmala M, Riihiluoma V, Raunemaa T. 1986. Particle emission from gasoline powered vehicles: Emission and deposition under different traffic density situations. Journal of Aerosol Science 17:629–631.
* Kumar P, Gupta BN, Pandya KP, 1988. Behavioral studies in petrol pump workers. Int Arch Occup Environ Health 61:35–38.3198282
* Kuna RA, Ulrich CE. 1984. Subchronic inhalation toxicity of two motor fuels. Journal of the American College of Toxicology 3:2 17–229.
* Lane JC. 1980. Gasoline and other motor fuels. In: Grayson M, Eckroth D, eds. Kirk-Othmer encyclopedia of chemical technology. New York, NY: John Wiley and Sons, 652-676, 694–695.
Lange E. 1982. Psychopathology of chronic cerebral gasoline poisoning. Samml Zwangl Abh Geb Psychiatr Neurol 50:225–229.7157118
Latimer JS, Hoffman EJ, Hoffman G, 1990. Sources of petroleum hydrocarbons in urban runoff. Water Air Soil Pollut 52: l-2 1.
Layton TR, Grant KJ, Villella ER. 1984. Gasoline injection. J Toxico1 Clin Toxico1 21:409–412.
Leinster P, Perry R, Young RJ. 1978. Ethylene dibromide in urban air. Atmos Environ 12:2383–2387.365190
Le Mesurier SM, Lykke AW J, Stewart BW. 1980. Reduced yield of pulmonary surfactant: Patterns of response following administration of chemicals to rats by inhalation. Toxicol Lett 5:89–94.6892858
* Le Mesurier SM, Stewart BW, O’Connell PJ, 1979. Pulmonary responses to atmospheric pollutants: II. Effect of petrol vapor inhalation on secretion of pulmonary surfactant. Pathology 11:81–87.581905
Lenner M, Lindqvist 0, Rosen A. 1983. The NO,/NO, ratio in emissions from gasoline-powered cars: High NO, percentage in idle engine measurements. Atmos Environ 17: 1395–1398.
Leseman WG. 1986. Water contamination caused by gasoline permeating a polybutylene pipe. JAWWA 39–43.
Lin AW M, Wu L, Yu J. 1990. Gasoline exposure assessment for oil refinery workers. Cincinnati, OH: American Industrial Hygiene Association, American Conference of Governmental Industrial Hygiene.
* Litton Bionetics. 1978. Teratology study in rats: Unleaded gasoline. Final report submitted to American Petroleum Institute, Washington, DC. Litton Bionetics, Inc., Kensington, MD.
* Litton Bionetics. 1980. Mutagenicity evaluation of gasoline, API PS-6 fuel in the mouse dominant lethal assay. Final report submitted to American Petroleum Institute, Washington, DC. Litton Bionetics, Inc., Kensington, MD.
Lock EA. 1990. Chronic nephrotoxicity of 2,2,4-trimethylpentane and other branched-chain hydrocarbons. Toxico1 Lett 53:75–80.
* Lock EA, Charbonneau M, Strasser J, 1987. 2,2,4-Trimethylpentane-induced nephrotoxicity: II. The reversible binding of a TMP metabolite to a renal protein fraction containing a2y-globulin. Toxicol Appl Pharmacol 91: 182– 192.2445051
Loury DJ, Butter-worth BE. 1986. Kidney-specific DNA repair assay: An evaluation of unleaded gasoline. Chemical Industry Institute of Toxicology 6: l-8.
* Loury DJ, Smith-Oliver T, Butterworth BE. 1987. Assessment of unscheduled and replicative DNA synthesis in rat kidney cells exposed in vitro or in viva to unleaded gasoline. Toxicol Appl Pharmacol 87:127–140.3798449
* Loury DJ, Smith-Oliver T, Strom S, 1986. Assessment of unscheduled and replicative DNA synthesis in hepatocytes treated in vivo and in vitro with unleaded gasoline or 2,2,4-trimethylpentane. Toxico1 Appl Pharmacol 85: 1 l-23.
Lucas C. 1985. Health hazard evaluation. Report no. HETA-83–136-1398. Social Security Administration, New Brunswick, NJ. NTIS/PB85–181246, issue 14.
Lykke AW, Stewart BW. 1978. Fibrosing alveolitis (pulmonary interstitial fibrosis) evoked by experimental inhalation of gasoline vapours. Experientia 34:498.639948
* Lykke AWJ, Stewart BW, O’Connell PJ, 1979. Pulmonary responses to atmospheric pollutants: I. An ultrastructural study of fibrosing alveolitis evoked by gasoline vapour. Pathology 11:71–80.431981
MacFarland HN. 1983. Chronic gasoline toxicity. Proceedings of the 1st Symposium on the Toxicology of petroleum hydrocarbons, Washington, DC, May 1982. Washington, DC: American Petroleum Institute. 78–86.
MacFarland HN, Path FR C. 1984. Xenobiotic induced kidney lesions: Hydrocarbons: The go-day and 2-year gasoline studies. In: Mehlman MA, Hemstreet GP II I, Thorpe JJ, , eds. Advances in modem environmental toxicology. Vol. 7: Renal effects of petroleum hydrocarbons. Princeton, NJ: Princeton Scientific Publishers, Inc., 51–56.
* MacFarland HN, Ulrich CE, Holdsworth CE, 1984. A chronic inhalation study with unleaded gasoline vapor. Journal of the American College of Toxicology 3:231–248.
* MacGregor JA, Richter WR, Magaw RI. 1993. Uterine changes in female mice following lifetime inhalation of wholly vaporized unleaded gasoline: A possible relationship to observed liver tumors? Journal of the American College of Toxicology 12(2): 119–126.
Machle W. 1941. Gasoline intoxication. JAMA 117:1965–1971.
Mackay D, Leinonen PJ. 1975. Rate of evaporation of low solubility contaminants from water bodies to atmosphere. Environ Sci Technol 9:1178–1180.
Mackay D, Patterson S. 1981. Calculating fugacity. Environ Sci Technol 15:1006–1014.22284102
Mackay D, Patterson S. 1982. Fugacity revisited. Environ Sci Technol 16:654–660.
* Magaw RI, Richter WR, Macgregor JA. 1993. A reexamination of liver tumors in mice exposed to wholly vaporized unleaded gasoline. Journal of the American College of Toxicology 12(2):195–199.
* Mann DC, Gresham WR. 1990. Microbial degradation of gasoline in soil. J Forensic Sci 35:913–923.
* Manton WI, Cook JD. 1984. High-accuracy (stable isotope dilution) measurements of lead in serum and cerebrospinal fluid. Br J Ind Med 41: 313–319.6378251
Marklund S, Andersson R, Tysklind M, 1990. Emissions of PCDDs and PCDFs in gasoline and diesel fueled cars. Chemosphere 20:553–561.
Mason JT II I. 1986. Public records reveal location of old gasoline storage tanks. J Teen Acad Sci 61:90–91.
* Matsubara K, Akane A, Takahashi S, 1988. Gas chromatographic determination for forensic purposes of petroleum fuel inhaled just before fatal burning. J Chromatogr 424:49–59.3366838
Matsumoto T, Koga M, Sata T, 1992. The changes of gasoline compounds in blood in a case of gasoline intoxication. Journal of Toxicology. Clinical Toxicology 30(4):653–662.1433434
Mayo DW, Page DS, Cooley J, 1978. Weathering characteristics of petroleum hydrocarbons deposited in fine clay marine sediments, Searsport, Maine. J Fish Res Board of Canada 35:552–562.
*McDermott HJ, Killiany Jr. 1978. Quest for a gasoline TLV. Am Ind Hyg Assoc J 39:110–117.637015
*McDermott HJ, Vos GA. 1979. Service station attendants’ exposure to benzene and gasoline vapors. Am Ind Hyg Assoc J 40:315–321 474416
McHugh MJ. 1987. The abuse of volatile substances. Pediatr Clin North Am 34:333–340.3550655
McLaren P. 1985. Behavior of diesel fuel on a high energy beach. Maine Pollution Bulletin 16:191–196.
* McKee JE, Laverty FB, Hertel RM. 1972. Gasoline in groundwater. J Water Polut Control Fed 441293–302.
* McLaughlin JK, Blot WJ, Mehl ES, 1985. Petroleum-related employment and renal cell cancer. J Occup Med 27:672–674.4045578
Mehlman MA. 1988. Recent laboratory studies in chemical carcinogenesis: Gasoline. Ann NY Acad Sci 543:408–411.
* Mehlman MA. 1990. Dangerous properties of petroleum-refining products: Carcinogenicity of motor fuels (gasoline). Teratogenesis Carcinog Mutagen 10:399–408.1981951
Mihelcic JR. 1990. Modeling the potential effect of additives on enhancing the solubility of aromatic solutes contained in gasoline. Groundwater Monitoring Review 10: 132–137.
Milne TA, Evans RJ, Nagle N. 1990. Catalytic conversion of microalgae and vegetable oils to premium gasoline, with shape-selective zeolites. Biomass 21:219–232.
Mommsen S, Aagard J. 1984. Occupational exposures as risk indicator of male bladder carcinoma in a predominantly rural area. Acta Radio1 [Oncol] 23:147–152.
Mommsen S, Aagaard J, Sell A. 1982. An epidemiological case-control study of bladder cancer in males from a predominantly rural district. Eur J Cancer Clin Oncol 18: 1205–1210.6897634
* Moore PJ, Pridmore SA, Gill GF. 1976. Total blood lead levels in petrol vendors. Med J Aust 1:438–440.1272138
Morris WE. 1985. Gasoline composition in no-lead era. Oil Gas J 83:99–100, 102–103, 106.
* Moss MA, Cooper PJ. 1986. Gasoline sniffing and lead poisoning. Acta Pharmacol Toxicol 7:48–51.
Murray DA J, Lockhart WL, Webster GR B. 1984. Analysis of the water-soluble fraction of crude oils and petroleum products by gas chromatography 2:39–46.
* Murty CVR, Olson MJ, Garg BD, 1988. Hydrocarbon-induced hyaline droplet nephropathy in male rats during senescence. Toxico1 Appl Pharmacol 96:380–392.
* Nakajima T, Okuyama S, Yonekura I, 1985. Effects of ethanol and phenobarbital administration on the metabolism and toxicity of benzene. Chem-Biol Interact 55:22–38.
* NAS/NRC. 1989. Biologic markers in reproductive toxicology. National Academy of Sciences/National Research Council. Washington, DC: National Academy Press, 15–35.
* NATICH. 1991. Database report on state, local, and EPA air toxics activities. National Air Toxics Information Clearinghouse. U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards. Washington, DC. August 13, 1991.
Nelson NA, Robins TG, Port FK. 1990. Solvent nephrotoxicity in humans and experimental animals. Am J Nephrology 10:10–20.
* NESCAUM. 1989. Evaluation of the health effects from exposure to gasoline and gasoline vapors. Final report. Northeast States for Coordinated Air Use Management.
Nettesheim P, Szakal AK. 1972. The response of the lower respiratory tract of mice and hamsters to chronic inhalation of ozonized gasoline fumes: A light microscopic and electron microscopical study. Ann Occup Hyg 15:263–269.4648239
* NFPA. 1978. Fire protection guide on hazardous materials. 7th ed. Boston, MA: National Fire Protection Association, 325M-11, 49–308.
NFPA. 1986. Manual for classification of gases, vapors, and dusts for electrical equipment in hazardous (classified) locations. Quincy, MA: National Fire Protection Association, NFPA publication no. 497M.
* Ng RC, Darwish H, Stewart DA. 1974. Emergency treatment of petroleum distillate and turpentine ingestion. Can Med Assoc J 111:537–538.4153346
* Niazi GA, Fleming AF, Siziya S. 1989. Blood dyscrasia in unofficial vendors of petrol and heavy oil and motor mechanics in Nigeria. Trop Doct 19:55–58.2734836
* NIOSH. 1974. Criteria for a recommended standard...Occupational exposure to benzene. Washington, DC: U.S. Department of Health, Education, and Welfare, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health. NIOSH-74–137.
* NIOSH. 1977. Manual of analytical methods. 2nd ed, vol. 1. Method no. P&CAM 200. Cincinnati, OH: U.S. Department of Health, Education, and Welfare, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health, 200-l to 200–8.
* NIOSH. 1984a. Manual of analytical methods. 3rd ed, vol. 1. Eller PM, ed. Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health, 8300-l to 8300–3.
* NIOSH. 1984b. Manual of analytical methods. 3rd ed, vol. 1. Eller PM, ed. Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health, 8301-l to 8301–4.
* NIOSH. 1984c. Manual of analytical methods. 3rd ed, vol. 2. Eller PM, ed. Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health, 1500-l to 1501–7.
* NIOSH. 1987. Manual of analytical methods. 3rd ed, vol. 1. Eller PM, ed. Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health, 3700-l to 3700–3, 4000-l to 4000–4.
* NIOSH. 1988. NIOSH testimony in OSHA PEL hearing, Washington, DC. July 1988. Washington, DC: National Institute for Occupational Safety and Health.
* NOES. 1991. National Occupational Exposure Survey (198l- 1983). Cincinnati, OH: U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health. September 11, 1991.
* Nylander PO, Olofsson H, Rasmuson B, 1978. Mutagenic effects of petrol in Drosophila melanogaster: I. Effects of benzene and 1,2-dichloroethane. Mutat Res 57:163–167.96337
* Ogata M, Taguchi T. 1987. Quantitation of urinary metabolites of toluene, xylene, styrene, ethylbenzene, benzene and phenol by automated high performance liquid chromatography. Int Arch Occup Environ Health 59:263–272.3570490
* OHM/TADS. 1991. Oil and Hazardous Materials/Technical Assistance Data System. Baltimore, MD: Chemical Information Systems, Inc. September, 1986.
Ohnishi Y, Kachi K, Sato K, 1980. Detection of mutagenic activity in automobile exhaust. Mutat Res 77:229–240.6155611
* Olson MJ, Garg Bb, Murty CVR, 1987a. Accumulation of alpha-2µglobulin in the renal proximal tubules of male rats exposed to unleaded gasoline. Toxico1 Appl Pharmacol 90:43–5 1.
Olson MJ, Garg BD, Sarkar FH, 1987b. Hyaline droplet and alpha-2µ-globulin accumulation in the kidneys of male rats after gasoline administration. Toxicology 47:233.
* Olson MJ, Johnson JT, Reidy CA. 1990. A comparison of male-rat and human urinary protein-simplications for human resistance to hyaline droplet nephropathy. Toxico1 Appl Pharmacol 102524–536.
* Olson MJ, Mancini MA, Garg BD, 1988. Leupeptin-mediated alteration of renal phagolysosomes: Similarity to hyaline droplet nephropathy of male rats exposed to unleaded gasoline. Toxico1 Lett 41:245–254.
Olteanu B. 1990. Trends in crude processing: II. Revamping of plants and processes for gasoline, aromatic-hydrocarbons and distillation products manufacturing. Revista de Chimie 41:414–420.
* O’Regan S, Turgeon C. 1986. Lack of antiglomerular basement membrane antibody binding to alveolar membranes after hydrocarbon exposure in rats. J Clin Lab Immunol 20:147–149.3746881
* OSHA. 1989a. Air contaminants. U.S. Department of Labor, Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000.
* OSHA. 1989b. Air contaminants. U.S. Department of Labor, Occupational Safety and Health Administration. Federal Register 54:2920–2960.
Ostendorf DW, Kampbell DH. 1991. Biodegradation of hydrocarbon vapors in the unsaturated zone. Water Resources Research 27:453–462.
Ostendorf DW, Leach LE, Hinlein ES, 1991. Field sampling of residual aviation gasoline in sandy soil. Ground Water Monit Rev 11: 107–120.
* Owens J, Soles L, Conove J, 1985. Gasoline sniffing and lead toxicity among siblings Virginia. MMWR 449–450, 455.
Page NP, Mehlman M. 1989. Health effects of gasoline refueling vapors and measured exposures at service stations. Toxicol Ind Health 5:869–890.2683228
* Pandya KP, Rao GS, Dhasmana A, 1975. Short communication: Occupational exposure of petrol pump workers. Ann Occup Hyg 18:363–364.1231599
Parker SP, ed. 1989. McGraw-Hill dictionary of scientific and technical terms. 4th ed. New York, NY: McGraw-Hill Book Company, 1592.
* Partanen T, Heikkila PK, Hernberg S, 1991. Renal cell cancer and occupational exposure to chemical agents. Stand J Work Environ Health 17:231–239.
* Phillips CF, Jones RK. 1978. Gasoline vapor exposure during bulk handling operations. Am Ing Hyg Assoc J 39:118–128.
Phillips RD, Cockrell BY. 1984. Effect of certain light hydrocarbons on kidney function and structure in male rats. In: Mehlman MA, Hemstreet AP, Thorpe JJ, , eds. Advances in modern environmental toxicology. Vol. VII: Renal effects of petroleum hydrocarbons. Princeton, NJ: Princeton Scientific Publishers, Inc., 89–105.
* Poklis A. 1976. Death resulting from gasoline “sniffing”: A case report. J Forensic Sci Sot 16:43–46.
* Poklis A, Burkett CD. 1977. Gasoline sniffing: A review. Clin Toxicol 11:35–41.872539
* Poole C, Dreyer NA, Satterfield MH, 1993. Kidney cancer and hydrocarbon exposure among petroleum refinery workers. Environmental Health Perspectives Supplements lOl(Supp1. 6):53–62.
Prockop L. 1979. Neurotoxic volatile substances. Neurology 29:862–865.572008
Provenzano G. 1978. Motor vehicle lead emissions in the United States: An analysis of important determinants, geographic patterns and future trends. J Air Pollut Control Assoc 28:1193-l 199.
* Przybylowski J. 1971. [Effects of experimental acute gasoline vapor intoxication (ethylene 78) on the circulatory system in rabbits.] At-h Hig Rada Toksikol 327–346. (Polish)
* Rao GS, Dhasmana A, Pandya KP. 1977. Hot summer occupational exposure of petrol pump workers. Proceedings on the 1st International Symposium on Environmental Pollution and Human Health 212–224.
Reible DD, Malhiet ME, Illangasekare TH. 1989. Modeling gasoline fate and transport in the unsaturated zone. J Hazard Mater 22:359–376.
Remington G, Hoffman BF. 1984. Gas sniffing as a form of substance abuse. Can J Psychiatry 29:31–35.6704883
* Richardson KA, Wilmer JL, Smith-Simpson D, 1986. Assessment of the genotoxic potential of unleaded gasoline and 2,2,4-trimethylpentane in human lymphoblasts in vitro. Toxicol Appl Pharmacol 82:3 16-322.
* Rischbieth RH, Thompson GN, Hamilton-Bruce A, 1987. Acute encephalopathy following petrol sniffing in two aboriginal patients. Clin Exp Neurol 23: 191–194.3665169
Robbins GA, Deyo BG, Temple MR, 1990. Soil-gas surveying for subsurface gasoline contamination using total organic vapor detection instruments: Part II. Field experimentation. Ground Water Monit Rev 10:110-l 17.
Robinson R. 1986. Cleaning up toxics. Civil Engineering 56:46–49.
* Robinson RO. 1978. Tetraethyl lead poisoning from gasoline sniffing. JAMA 240: 1373–1374.682329
* Roe VD, Lacy MJ, Stuart JD, 1989. Manual headspace method to analyze for the volatile aromatics of gasoline in groundwater and soil samples. Anal Chem 61:2584–2585.
Ross CA. 1982. Gasoline sniffing and lead encephalopathy. Can Med Assoc J 127: 1195–1197.7139470
* RTECS. 1990. Registry of Toxic Effects of Chemical Substances. U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health, Washington, DC. November 1, 1990.
* Runion HE. 1988. Occupational exposures to potentially hazardous agents in the petroleum industry. Occupational Medicine: State of the Art Reviews 3:431–444.
* Rushton L. 1993. 39-Year follow-up of the U.K. oil refinery and distribution center studies: Results for kidney cancer and leukemia. Environmental Health Perspectives Supplements 101(Supp1. 6):77–84.
* Russo PJ, Florky GR, Agopsowicz DE. 1987. Performance evaluation of a gasoline vapor sampling method. Am Ind Hyg Assoc J 48:528–53 1.3618465
* Saenz G, Pingitore NE. 1991. Characterization of hydrocarbon contaminated areas by multivariate statistical analysis: Case studies. Environmental Monitor Assessment 17(2–3):281–302.
Saito K. 1972. Electroencephalographical studies on the effect of commercially available leaded and nonleaded gasoline on rats. Hokkaido Igaku Zasshi 47:472–480.
Saito K. 1973. Electroencephalographic studies on petrol intoxication: Comparison between nonleaded and leaded white petrol. Br J Ind Med 30:352–358.4753718
Saito K, Inai H, Takakuwa E. 1973. [Studies on gasoline intoxication: Part 1. Electroencephalographical changes and lead content in organs or rats administered lead-free and l leadcontaining brands of gasoline.] Sangyo Igaku 14:9–20. (Japanese)
Saito K, Kamita N, Takakuwa E. 1974. Averaged auditory evoked response (AER) in rat intoxicated with gasoline. Ind Health 12:97–103.
Saldiva PH N, Massad E, Caldeira MP R, 1985. Pulmonary function of rats exposed to ethanol and gasoline fumes. Braz J Med Biol Res 18:573–577.2425877
Sanders WN, Maynard JB. 1968. Capillary gas chromatographic method for determining the C_3_-C hydrocarbons in full-range motor gasolines. Anal Chem 40:527–535.
* SANSS. 1987. Chemical Information System (CIS). Structure and Nomenclature Search System, Baltimore, MD. December 1986.
Sarojini R, Khan AK, Nagabhushanam R. 1989. Effect of petroleum hydrocarbons (petrol and diesel) on the physiology of the crab, Barytelphusa cunicularis: I-oxygen consumption. J Environ Biol 10:363–365.
* Sax NI, Lewis RJ, eds. 1989. Dangerous properties of industrial materials. 7th ed. New York, NY: Van Nostrand Reinhold, 1795–1796.
* Sax NI, Lewis RJ, eds. 1987. Hawley’s condensed chemical dictionary. 11th ed. New York, NY: Van Nostrand Reinhold, 554.
Sayers RR, Fieldner AC, Yant WP, 1927. Experimental studies on the effect of ethyl gasoline and its combustion products. U.S. Bureau of Mines.
Scala RA. 1988. Motor gasoline toxicity. Fundam Appl Toxico1 10:533–562.
Schafer LD, Hartnett JA, Hampton JA, 1990. Induction of cell proliferation in rat and mouse hepatic and renal tissue following treatment with gasoline. Society of Toxicology 29th Annual Meeting, Miami FL, February 12–16, 1990. Washington, DC: Society of Toxicology.
Scherz RG. 1974. The management of accidental childhood poisoning. Pediatrics 54:323–324.4416349
Schnatter AR, Katz AM, Nicolich MJ, 1993. A retrospective mortality study among Canadian petroleum marketing and distribution workers. Environmental Health Perspectives Supplements 101(Supp1. 6):85–99.
* Schnatter AR, Theriault G, Karz AM, 1992. A retrospective mortality study within operating segments of a petroleum company. American Journal of Industrial Medicine 22(2):209–229.1415287
Schreiner CA. 1983. Petroleum and petroleum products: A brief review of studies to evaluate reproductive effects. Adv Mod Environ Toxico1 3:29–45.
Schreiner CA, Mackerer CR. 1982. Mutagenesis testing of gasoline engine oils. Polynuclear Aromatic Hydrocarbons: Physiology Biology Chemistry International Symposium 6th, 705–7 12.
* Schwartz E. 1987. Proportionate mortality ratio analysis of automobile mechanics and gasoline service station workers in New Hampshire. Am J Ind Med 12:91–99.3618603
Seeber A, Kiesswetter E, Neidhart B, 1990. Neurobehavioral effects of a long-term exposure to tetraalkyllead. Neurotoxicol Teratol 12:653–655.2255310
Senychenkova II. 1991. [Embryotoxic effects of industrial environment pollutants: formaldehyde and gasoline.] Gigiena I Sanitariia Sep(9):35–38. (Russian)
* Seshia SS, Rajani KR, Boeckx RL, 1978. The neurological manifestations of chronic inhalation of leaded gasoline. Dev Med Child Neurol 20:323–334.97111
* Shamsky S, Samimi B. 1987. Organic vapors at underground gasoline tank removal sites. Appl Ind Hyg 2:242–245.
Shaner R, ed. 1982. How non-detection can cost you: The tank leak mess. National Petroleum News 74:36–40.
* Shankles B, Weinberg SB, Dal Cortivo LA. 1982. Detection and identification of gasoline in tissues by capillary GC using pattern recognition techniques. J Anal Toxico1 6:241–243.
* Shapiro LE, Sachchidananda J. 1982. Regulation of proteins by thyroid hormone and glucocorticoid: The responses of hepatic α2u-globulin and pituitary growth hormone differ in adult male hypothyroid rats. Endocrinology 8:653–660.
* Shiller JW. 1987. Gasoline vapor exposure parameters during refueling operations. Proceedings of the 80th Annual Meeting of the Association Dedicated to Air Pollution Control and Hazardous Waste Management, New York, NY, June 21–26. 80(2):1–16.
Short BG. 1989. Effects of unleaded gasoline on renal tubular cell kinetics and tumor promotion in rats. Diss Abstr Int B 50:801.
* Short BG, Burnett VL, Cox MG, 1987. Site-specific renal cytotoxicity and cell proliferation in male rats exposed to petroleum hydrocarbons. Lab Invest 57:564–577.3682766
* Short BG, Burnett VL, Swenberg JA. 1989a. Elevated proliferation of proximal tubule cells and localization of accumulated alpha-2u-globulin in Fischer-344 rats during chronic exposure to unleaded gasoline or 2,2,4-trimethylpentane. Toxico1 Appl Pharmacol 10 1:4 14-431.
* Short BG, Steinhagen WH, Swenberg JA. 1989b. Promoting effects of unleaded gasoline and 2,2,4-trimethylpentane on the development of atypical cell foci and renal tubular cell tumors in rats exposed to N-ethyl-N-hydroxyethylnitrosamine. Cancer Res 49:6369–6378.2804983
Shy CM. 1990. Lead in petrol: The mistake of the XXth century. World Health Statistics Quarterly 43:168–176.
* Siemiatycki J, Dewar R, Nadon L, 1987. Associations between several sites of cancer and twelve petroleum-derived liquids: Results from a case-referent study in Montreal. Scan J Work Environ Health 13:493–504.
* Simpson LA, Cruse CW. 1981. Gasoline immersion injury. Plastic Reconstructive Surgery 67:54–57.7443860
* Smith TJ, Hammon SK, Wong 0. 1993. Health effects of gasoline exposure. I. Exposure assessment for U.S. distribution workers. Environmental Health Perspectives Supplements l0l(Supp1. 6):13–21.
Snider EH, Manning FS. 1982. A survey of pollutant emission levels in wastewaters and residuals from petroleum refining industry. Environment International 7:237–258.
Spencer PS. 1984. Experimental evaluation of selected petrochemicals for subchronic neurotoxic properties. In: MacFarland HN, Holdsworth CE, MacGregor JA, , eds. Advances in modem environmental toxicology. Vol. VI: Applied toxicology of petroleum hydrocarbon. Princeton, NJ: Princeton Scientific Publishers, Inc., 199–211.
SRC. 1985. Monograph on human exposure to chemicals in the workplace: Gasoline. Syracuse Research Corporation. PB86– 1434 19.
* Standeven AM, Goldsworthy TL. 1993. Promotion of neoplastic lesions and induction of CYP2B induced by unleaded gasoline vapors in female B6C3F_l_ mouse liver. Carcinogenesis 14:2137–2141.8222067
* Standeven AM, Blazer DG III, Goldsworthy TL. 1994a. Investigation of antiestrogenic properties of unleaded gasoline in female mice. Toxicology and Applied Pharmacology 127:233–240.8048066
* Standeven AM, Wolf DC, and Goldsworthy TL. 1994b. Interactive effects of unleaded gasoline and estrogen on liver tumor promotion in female B6C3F_1_ mice. Cancer Research 54(5):1193–1204.
* Stephens ER. 1973. Hydrocarbons in polluted air: Summary report. Project CAPA-5–68. Riverside, CA: University of California, Statewide Air Pollution Research Center.
* Stock JK, Priestly BG. 1986. Urinary thioether output as an index of occupational chemical exposure in petroleum retailers. Br J Ind Med 43:718–720.3778843
Stump FD, Knapp KT, Ray WD. 1990. Seasonal impact of blending oxygenated organics with gasoline on motor vehicle tailpipe and evaporative emissions. J Air Waste Manage Assoc 40:872–880.1695102
Sturaro A, Doretti L, Parvoli G. 1990. Investigation of used synthetic lubricants by computerized gas chromatography/mass spectrometry. Sci Total Environ 99:53–60.2270471
*Stutz PR, Janusz SJ, eds. 1988. Hazardous materials injuries. Beltsville, MD: Bradford Communications Corp., 360–361.
* Svoma J, Houzim V. 1984. Protection of groundwater from oil pollution in the vicinity of airports. Environ Geol Water 6:21–30.
* Swenberg JA, Short B, Borghoff S, 1989. The comparative pathobiology of a2p-globulin nephropathy. Toxic.01 Appl Pharmacol 97:35–46.
Swinyard EA. 1975. Noxious gases and vapors: Carbon monoxide, hydrocyanic acid, benzene, gasoline, kerosene, carbon tetrachloride, and miscellaneous organic solvents. Pharmacol Basis Ther 5th 900–9 11.
Sykes RA, Mani MM, Hiebert JM. 1986. Chemical bums: Retrospective review. J Bum Care Rehabil 71343–347.
Tagavov IT, Sumanov VT, Khadzhiev SN. 1990. Formation of the octane number of alkylation gasoline. Chemistry and Technology of Fuels and Oils 25:276–278.
* Tangley L. 1984. Groundwater contamination: Local problems become national issue. Bio Science 34:142–148.
Tau LM, Fort AW, Bao S, 1990. Methanol to gasoline: ^14^C tracer studies of the conversion of methanol/higher alcohol mixtures over ZSM-5. Fuel Processing Technology 26:209–219.
* Thomas JM, Gordy VR, Fiorenza S, 1990. Biodegradation of BTEX in subsurface materials contaminated with gasoline: Granger, Indiana. Water Sci Technol 22:53–62.
* Tilbury L, Butterworth BE, Moss O, 1993. Hepatocyte cell proliferation in mice after inhalation exposure to unleaded gasoline vapor. Journal of Toxicology and Environmental Health 38(3):293–307.8450558
Tiimqvist M, Kautiainen A, Gatz RN, 1988. Hemoglobin adducts in animals exposed to gasoline and diesel exhausts: 1. Alkenes. J Appl Toxico1 8:159–170.
* Travis CC, Fox MT, Simmons WM, 1992. Co-exposure to gasoline vapor decreases benzene metabolism in Fisher-344 rats. Toxicology Letters (AMST) 62(2–3):231–240.
* TRI88. 1990. Toxic Chemical Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
Trump BF, Lipsky MM, Jones TW, 1984. An evaluation of the significance of experimental hydrocarbon toxicity to man. Adv Mod Environ Toxico1 7:273–288.
* Turlakiewicz Z, Chmielnicka J. 1985. Diethyllead as a specific indicator of occupational exposure to tetraethyllead. Br J Ind Med 42:682–685.4041386
* Uchrin CG, Katz J. 1991. Transport of a BTX mixture in a groundwater aquifer material. Bull Environ Contam Toxicol 46(4):534–541.1854997
* Valpey R, Sumi SM, Copass MK, 1978. Acute and chronic progressive encephalopathy due to gasoline sniffing. Neurology 28:507–510.565491
Van der Linden-AC, Thijsse GJ E. 1965. The mechanisms of microbial oxidations of petroleum hydrocarbons. In: Nord FF, ed. Advances in enzymology and related subjects of biochemistry. Volume XXVII. New York, NY: Interscience Publishers, 469–546.
* Van Doren G, Mertens B, Heyns W, 1983. Different forms of a2yglobulin in male and female rat urine. Eur J Biochem 134:175–181.6190651
* Van Gelder-Ottway. 1976. Some physical and biologic effects of oil films floating on water. In: Baker JM, ed. Marine ecology and oil pollution. New York, NY: John Wiley and Sons, 255–268.
* Vemot EH, Drew RT, Kane ML. 1990. Acute toxicologic evaluation of unleaded motor gasoline. [Abstract] Acute Toxic Data 1:28.
* Vyskocil, Tusl M, Obrsal J, 1988. A subchronic inhalation study with unleaded petrol in rats. J Appl Toxico1 8:239–242.
Walker JD, Colwell RR, Petrakis L. 1975a. A study of the biodegradation of a South Louisiana crude oil employing computerized mass spectrometry. San Francisco, CA: Joint Conference on the Prevention and Control of Oil Pollution, 601–605.
* Walker JD, Petrakis L, Colwell RP. 1975b. Comparison of the biodegradability of crude and fuel oils. Can J Microbial 22:598–602.
Wallingford ED, DiGiano FA, Miller CT. 1988. Evaluation of a carbon adsorption method for sampling gasoline vapors in the subsurface. Groundwater Monit Rev 8:85–92.
* Wang CC, Irons GV. 1961. Acute gasoline intoxication. Arch Environ Health 2:114–116.
Weaver NK. 1971. Toxicologic implications of motor gasoline and auto emissions. Ind Med Sur 40:31–34.
Weaver NK. 1988. Gasoline toxicology: Implications for human health. Ann NY Acad Sci 534:441–451.3291713
* Weiss G., ed. 1986. Hazardous chemicals databook. 2nd ed. Park Ridge, NJ: Noyes Data Corporation, 542.
* Wen CP, Tsai SP, Moffitt KB, 1984. Epidemiologic studies of the role of gasoline (hydrocarbon) exposure in kidney cancer risk. Adv Mod Environ Toxicol 7:245–257.
Williams K, Lewtas J. 1985. Metabolic activation of organic extracts from diesel, coke oven, roofing tar, and cigarette smoke emissions in the Ames assay. Environ Mutat 7:489–500.
* Wilson J, McNabb J. 1983. Biological transformation of organic pollutants in groundwater. EOS 64(33):505–507.
*Wong O, Raabe G-K. 1989. Critical review of cancer epidemiology in petroleum industry employees, with a quantitative meta-analysis by cancer site. Am J Ind Med 15:283–310.2929617
Wong O, Harris F, Smith TJ. 1993. Health effects of gasoline exposure. II. Mortality patterns of distribution workers in the United States. Environmental Health Perspectives Supplements lOl(Supp1. 6):63–76.
Worhneh F. 1983. inhalation of petrol (gasoline, benzene) in Ethiopia. Ethiopian Med J 21:19–26.
* Yamamoto T, Wilson CB. 1987. Binding of anti-basement membrane antibody to alveolar basement membrane after intratracheal gasoline instillation in rabbits. Am J Patho1 126:497–505.
* Yaniga PM. 1984. Groundwater abatement techniques for removal of refined hydrocarbons. Houston, TX: National Conference and Exhibition on Hazardous Wastes and Environmental Emergencies, March 12–14, 1984, 374–383.
Yoshimura H. 1982. [The influence of air pollution on the development of pulmonary cancer, with special reference to gasoline engine.] Jpn H Hyg 37:848–865. (Japanese)
* Young RS, Grzyb SE, Crismon L. 1977. Recurrent cerebellar dysfunction as related to chronic gasoline sniffing in an adolescent girl: Lead poisoning from “leaded” gasoline as an attendant complication. Clin Pediatr 16:706–708.
Zepp RG, Baughman GL, Schlotzhauer PF. 1981. Comparison of photochemical behavior of various humic substances in water: I. Sunlight induced reactions of aquatic pollutants photosensitized by humic substances. Chemosphere 10: 109–117.
Ziircher F, Thtier M. 1978. Rapid weathering processes of fuel oil in natural waters: Analysis and interpretations. Environ Sci Technol 12:838–843.
Zweidinger RB. 1982. Emission factors from diesel and gasoline powered vehicles: Correlation with the Ames test. Dev Toxicol Environ Sci 10:83–96.6176437
Zweidinger RA, Cooper SD, Harris BSH II I, 1980. Measurement of benzene body-burden for populations potentially exposed to benzene in the environment. U.S. Environmental Protection Agency, Office of Pesticides and Toxic Substances, Washington, DC. EPA 560/13–80-028, 194.