# 7 REGULATIONS AND ADVISORIES

The international, national, and state regulations and guidelines regarding gasoline in air, water, and other media are summarized in Table 7-1. Regulations and guidelines pertaining specifically to gasoline emissions are not included in Table 7-1. Regulations and guidelines for which it has not been explicitly stated if they apply to gasoline vapor and/or emissions have been included in Table 7-1. There is no EPA reference dose (RfD) or reference concentration (RfC) for gasoline. EPA has established many regulations on gasoline to control air pollution (EPA 1990a, 1990b, 1990c). Many states have adopted additional, more stringent regulations (CELDS 1991). Under the Hazardous Material Transportation Act, gasoline is designated as a hazardous substance subject to special requirements for packaging, labeling, and transportation (DOT 1989a, 1989b).

TABLE 7-1 Regulations and Guidelines Applicable to Gasoline

Agency | Description | Information | References
[underlined: NATIONAL]
Regulations:
a. Air
EPA OAQPS | Backing of lead usage right allowed in connection with regulations significantly reducing allowable gasoline lead content | Yes | EPA 1985a (40 CFR 80); EPA 1985b
| Lead content limit in gasoline | 0.10 grams/gallon | EPA 1985a (40 CFR 80): EPA 1985c
OSHA | PEL TWA | 900 mg/m^3^ (300 ppm) | OSHA 1989a (29 CFR 1910.1000): OSHA 1989B
| STEL (15-minute average) | 1,500 mg/m^3^ (550 ppm) | OSHA 1989a (29 CFR 1910.1000): OSHA 1989b
b. Other
DOT | Hazardous Material Transportation Act: Designated as a hazardous substance subject to requirement for packaging, labeling, and transportation | Yes | DOT 1989a (49 CFR 172.101. Appendix A): DOT 1989b
Guidelines:
a. Air:
ACGIH | TLV TWA | 890 mg/m^3^ (300 ppm) | ACGIH 1990
| STEL (15-minute average) | 1,480 mg/m^3^ (500 ppm) | ACGIH 1990
NIOSH | Carcinogen: lowest feasible concentration | | NIOSH 1988
[underlined: STATE]
Regulations and Guidelines:
a. Air | Acceptable Ambient Air Concentration | | NATICH 1991
Connecticut | (8 hours) | 1.8 ug/m^4^
Florida-Fort Lauderdale | (8 hours) | 9.0 ug/m^3^
Florida-Pinellas | (8 hours) | 9.0 ug/m^3^
Florida-Pinellas | (24 hours) | 2.16 ug/m^3^
Kansas | (1 year) | 1.33 ug/m^3^
Kansas-Kansas City | (Annual) | 1.33 ug/m^3^
Maryland | | 0.00
Nevada | (8 hours) | 2.14×10^1^ mg/m^3^
North Dakota | (1 hour) | 1.48×10^1^ mg/m^3^
North Dakota | (8 hours) | 8.90 mg/m^3^
Oklahoma | (24 hours) | 8.90×10^4^ μg/m^3^
Texas | (30 minutes) | 8.9×10^3^ μg/m^3^
| In addition to federal regulations many states has adopted additional rules and regulations on gasoline. These regulations vary from state to state. | | CELDS 1991
Alabama | Emissions from leaks from gasoline terminals, gasoline dispensing facilities, and petroleum refinery sources | Yes
| Emissions from leaks from gasoline tank trucks and vapor collection systems | Yes
| Organic emissions | Yes
Arizona | VOC emissions from petroleum storage and petroleum refineries | Yes
California | Leaking underground fuel tanks | Yes
Colorado | Hazardous transportation | Yes
Connecticut | Visible emissions | Yes
Florida | Ozone emission standards for existing petroleum liquid storage, bulk gasoline plants and terminals, and gasoline service stations | Yes
Illinois | Gasoline distribution | Yes
Kansas | Leaks from gasoline delivery vessels and vapor collection systems | Yes
| VOC emissions from gasoline dispensing facilities | Yes
Kentucky | VOC emissions from service stations | Yes
| Hydrocarbon emissions from bulk gasoline plants and new terminal loading facilities | Yes
Louisiana | Bulk gasoline terminals | Yes
Maine | Open burning | Yes
| VOC emission from bulk gasoline terminals and transfer operations | Yes
| Special wastes
Maryland | VOC emissions from large storage tanks | Yes
| Gasoline leaks from tank trucks and vapor control | Yes
| Transportation of hazardous materials | Yes
Massachusetts | Transportation of hazardous liquids | Yes
| Motor vehicle fuel tank trucks, vapor recovery | Yes
| Vehicle exhaust emissions | Yes
Michigan | VOC emissions at loading and dispensing facilities | Yes
Missouri | Petroleum liquid storage, loading and transfer | Yes
New Jersey | Air pollution from toxic substances | Yes
New York | Petroleum liquid storage facilities | Yes
North Carolina | Bulk gasoline plants and terminals, gasoline service stations | Yes
North Dakota | Performance from bulk gasoline terminals
Ohio | VOC emissions from bulk gasoline terminals and gasoline tank trucks | Yes
Pennsylvania | VOC emissions from bulk gasoline terminals and storage tanks during transfer operations | Yes
Rhode Island | Oil pollution | Yes
South Carolina | Bulk gasoline terminals and vapor collection | Yes
Tennessee | Bulk gasoline terminals
Texas | Reports required for gasoline | Yes
| VOC emissions from loading and unloading facilities | Yes
| Gasoline storage vessels | Yes
Washington, DC | Organic compounds | Yes
Wisconsin | VOC emissions in transfer operations | Yes
| Performance of bulk gasoline terminals | Yes
Virginia | Emission standards for petroleum liquid and transfer operations

ACGIH = American Conference of Governmental Industrial Hygienists; DOT = Department of Transportation; EPA = Environmental Protection Agency; NIOSH = National Institute for Occupational Safety and Health; OAQPS = Office of Air Quality Planning and Standards; OSHA = Occupational Safety and Health Administration; PEL = Permissible Exposure Limit; STEL = Short Term Exposure Limit; TLV = Threshold Limit Value; TWA = Time-Weighted Average; VOC = Volatile Organic Compound