# 3 CHEMICAL AND PHYSICAL INFORMATION

## 3.1 CHEMICAL IDENTITY

Gasoline is a refined product of petroleum consisting of a mixture of hydrocarbons, additives, and blending agents. The composition of gasolines varies widely, depending on the crude oils used, the refinery processes available, the overall balance of product demand, and the product specifications. The typical composition of gasoline hydrocarbons (% volume) is as follows: 4-8% alkanes; 2-5% alkenes; 25-40% isoalkanes; 3-7% cycloalkanes; l-4% cycloalkenes; and 20-50% total aromatics (0.5-2.5% benzene) (IARC 1989). Additives and blending agents are added to the hydrocarbon mixture to improve the performance and stability of gasoline (IARC 1989; Lane 1980). These compounds include anti-knock agents, anti-oxidants, metal deactivators, lead scavengers, anti-rust agents, anti-icing agents, upper-cylinder lubricants, detergents, and dyes (IARC 1989; Lane 1980). At the end of the production process, finished gasoline typically contains more than 150 separate compounds although as many as 1,000 compounds have been identified in some blends (Domask 1984; Mehlman 1990). Information regarding the chemical identity of gasoline is located in Table 3-1.

## 3.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties for the gasoline mixture is located in Table 3-2. In cases where data are not available for gasoline, ranges are given to indicate the different values for the individual components.

TABLE 3-1 Chemical Identity of Gasoline

Characteristic | Information | Reference
Chemical name | Gasoline | RTECS 1990
Synonyms | Casing head gasoline; motor fuel; motor spirit; natural gasoline; petrol | HSDB 1993
Registered trade name(s) | No data^a^
Chemical formula | No data^a^
Chemical structure | No data^a^
Identification numbers:
CAS registry | 8006-61-9 | RTECS 1990; Sax and Lewis 1989
NIOSH RTECS | LX3300000 | RTECS 1990; SANSS 1986; Sax and Lewis 1989
EPA hazardous waste | No data
OHM/TADS | 7217073 | OHM/TADS 1991; SANSS 1986
DOT/UN/NA/IMCO shipping | UN1203, UN1257 | RTECS 1990
HSDB | No data
NCI | No data

a Gasoline is a mixed compound consisting of hydrocarbons, blending agents, and additives.

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemicals Substances; SANSS = Structure and Nomenclature Search System

TABLE 3-2 Physical and Chemical Properties of Gasoline

Property | Information | Reference
Molecular weight | 108^a^ | Anonymous 1989
Color | Colorless to pale brown or pink | Sax and Lewis 1989; Weiss 1986
Physical state | Liquid | Sax and Lewis 1989
Melting point | No data
Boiling point | Initially, 39°C | Budavari et al. 1989; OHM/TADS 1991; Sax and Lewis 1989
| After 10% distilled, 60°C | Budavari et al. 1989; OHM/TADS 1991; Sax and Lewis 1989
| After 50% distilled, 110°C | Budavari et al. 1989; OHM/TADS 1991; Sax and Lewis 1989
| After 90% distilled, 170°C
| Final boiling point, 204°C
Density | 0.7-0.8 g/cm^3,b^ | IARC 1989
Odor | Gasoline odor | Weiss 1986
Odor threshold | 0.025 ppm^c^ | Weiss 1986
Solubility:
Water at 20°C | Insoluble | OHM/TADS 1991; Sax and Lewis 1989
Organic solvent(s) | Absolute alcohol, ether, chloroform, benzene | Budavari et al. 1989; Sax and Lewis 1989
Partition coefficients:
Log K_ow_ | 2.13-4.87^d^ | Air Force 1989
Log K_oc_ | 1.81-4.56^d^ | Air Force 1989
Vapor pressure^e^ | | ASTM 1989
at 60°C | 465 mmHg
at 56°C | 518 mmHg
at 51°C | 593 mmHg
at 47°C | 698 mmHg
at 41°C | 773 mmHg
Henry’s law constant:
at 20°C | 4.8×10^−4^-3.3 m^3^/mol^d^ | Air Force 1989
Autoignition temperature
Autoignition temperature | 280-486°C | NEPA 1986; Sax and Lewis 1989; Weiss 1986
Flashpoint | −46°C | Sax and Lewis 1989
Flammability limits | 1.4-7.4% | Weiss 1986
Conversion factors | No data
Explosive limits | 1.3-6.0% | Budavari et al. 1989; Sax and Lewis 1989

a Average molecular weight

b Temperature not specified

c Not specified whether data for air or water

d Since data are not available for gasoline, ranges are given indicating different values for the individual components.

e The American Society for Testing and Materials (ASTM) has established guidelines on compositions of gasoline that will permit satisfactory performance under varying conditions. These guidelines define five volatility classes that vary by seasonal climatic changes. The values given for vapor pressure at the given temperatures are based on these volatility classes.

TABLE 3-3 Major Components of Gasoline^a^

Component | Percentage Composition^b^ | Component
n-alkanes | | [underlined: Other possible components]
C_5_ | 3.0 | octane enhancers
C_6_ | 11.6 | methyl t-butyl ether (MTBE)
C_7_ | 1.2 | t-butyl alcohol (TBA)
C_9_ | 0.7 | ethanol
C_10_-C_13_ | 0.8 | methanol
total of n-alkanes | 17.3 | antioxidants
| | N,N’-dialkylphenylenediamines
branched alkanes | | 2,6-dialkyl and 2,4,6-trialkylphenols
C_4_ | 2.2 | butylated methyl, ethyl and dimethyl phenols
C_5_ | 15.1 | triethylene tetramine di(monononylphenolate)
C_6_ | 8.0 | metal deactivators
C_7_ | 1.9 | N,N’-disalicylidene-1.2-ethanediamine
C_8_ | 1.8 | N,N’-disalicylidene-propanediamine
C_9_ | 2.1 | N,N’-disalicylidene-cyclohexanediamine
C_10_-C_13_ | 1.0 | disalicylidene-N-methyl-dipropylene-triamine
total of branched | 32.0 | ignition controllers
| | tri-o-cresylphosphate (TOCP)
cycloalkanes | | icing inhibitors
C_6_ | 3.0 | isopropyl alcohol
C_7_ | 1.4 | detergents/dispersants
C_8_ | 0.6 | alkylamine phosphates
total of cycloalkanes | 5.0 | poly-isobutene amines
| | long chain alkyl phenols
olefins | | long chain alcohols
C_6_ | 1.8 | long chain carboxylic acids
total of olefins | 1.8 | long chain amines
| | corrosion inhibitors
aromarics | | carboxylic acids
benzene | 3.2 | phosphoric acids
toluene | 4.8 | sulfonic acids
xylenes | 6.6
ethylbenzene | 1.4
C_3_-benzenes | 4.2
C_4_-benzenes | 7.6
others | 2.7
total aromatics | 30.5

a Adapted from Air Force 1989

b Percent by weight