# 9 REFERENCES

* Cited in text

*Abián J, Durand G, Barceló D. 1993. Analysis of chlorotriazines and their degradation products in environmental samples by selecting various operating modes in thermospray HPLC/MS/MS. J Agric Food Chem 41:1264–1273.
Abou-Waly H, Abou-Setta MM, Nigg HN, 1991. Dose-response relationship of Anabaena flosaquae and Selenastrum capricornutum to atrazine and hexazinone using chlorophyll (a) content and 14C uptake. Aquat Toxicol 20:195–204.
Abraham AD, Pop M. 1979. Apprentissage et modifications biochimioues du cerveau et des surrénales chez les rats blancs sous l'action de l'atrazine. Stud Univ Babes-Bolyai, Biol 24(2):32–35.
Abrams K, Hogan DJ, Maibach HI. 1991. Pesticide-related dermatoses in agricultural workers. Occup Med State Art Rev 6(3):463–490.
*ACGIH. 2000. Documentation of the threshold limit values and biological indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
ACGIH. 2001. Atrazine. Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, Ohio: American Conference of Government Industrial Hygienists.
Adams CD, Randtke SJ. 1992. Removal of atrazine from drinking water by ozonation. J Am Water Works Assoc 84(9):91–102.
*Adams N, Levi PE, Hodgson E. 1990. In vitro studies of the metabolism of atrazine, simazine, and terbutryn in several vertebrate species. J Agric Food Chem 38:1411–4117.
*Ademola JI, Sedik LE, Wester RC, 1993. In vitro percutaneous absorption and metabolism in man of 2-chloro-4-ethylamino-6-isopropylamine-s-triazine (atrazine). Arch Toxicol 67:85–91.8481106
*Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27:532–537.4029526
*Adler I-D. 1980. A review of the coordinated research effort on the comparison of test systems for the detection of mutagenic effects, sponsored by the E.E.C. Mutat Res 74:77–93.6769035
*Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
*Adrian NR, Suflita JM. 1994. Anaerobic biodegradation of halogenated and nonhalogenated N-, S-, and other O-heterocyclic compounds in aquifer slurries. Environ Toxicol Chem 13(10):1551–1557.
*Agency for Toxic Substances and Disease Registry. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Federal Register 54(174):37618–37634.
*Akkanen J, Penttinen S, Haitzer M, 2001. Bioavailability of atrazine, pyrene and benzo[a]pyrene in European river waters. Chemosphere 45(4–5):453–462.11680741
*Albanis TA, Hela DG, Sakellarides TM, 1998. Monitoring of pesticide residues and their metabolites in surface and underground waters of Imathia (N. Greece) by means of solid-phase extraction disks and gas chromatography. J Chromatogr 823:59–71.
*Altman PL, Dittmer DS. 1974. In: Biological handbooks: Biology data book. Vol. III. 2^nd^ ed. Bethesda, MD: Federation of American Societies for Experimental Biology, 1987–2008, 2041.
*Ames RA, Hoyle BL. 1999. Bioremediation and biodegradation: Biodegradation and mineralization of atrazine in shallow subsurface sediments from Illinois. J Environ Qual 28:1674–1681.
*Amistadi MK, Hall JK, Bogus ER, 1997. Comparison of gas chromatography and immunoassay methods for the detection of atrazine in water and soil. J Environ Sci Health B B 32(6):845–860.
Amorena M, Lucisano A, Damiano S, 1984. Experimental atrazine toxicity: Relation between morphofunctional indexes and the presence of residues in the parenchymal tissue of treated animals. Riv Tossicol Sper Clin 14(3):151–168.
*Andersen KJ, Leighty EG, Takahashi MT. 1972. Evaluation of herbicides for possible mutagenic properties. J Agric Food Chem 20(3):649–656.4561194
*Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York: Marcel Dekker, Inc., 9–25.
*Andersen ME, Clewell HJ II I, Gargas ML, 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharm 87:185–205.
Anderson TA, Coats JR. 1995. Screening rhizosphere soil samples for the ability to mineralize elevated concentrations of atrazine and metolachlor. J Environ Sci Health B 4:473–484.
*AOAC. 1993. Official methods of analysis. Pesticides in water: Liquid chromatographic method with ultraviolet detection 992.14. 15^th^ ed.
*Arbuckle TE, Zhiqiu L, Mery LS. 2001. An exploratory analysis of the effect of pesticide exposure on the risk of spontaneous abortion in an Ontario farm population. Environ Health Perspect 109(8):851–857.11564623
*Ashby J, Tinwell H, Stevens J, 2002. The effects of atrazine on the sexual maturation of female rats. Regul Toxicol Pharmacol 35:468–473.12202059
*Aso S, Anai N, Noda S, 2000. Twenty-eight-day repeated-dose toxicity studies for detection of weak endocrine disrupting effects of nonylphenol and atrazine in female rats. J Toxicol Pathol 13(1):13–20.
*Babic-Gojmerac T, Kniewald Z, Kniewald J. 1989. Testosterone metabolism in neuroendocrine organs in male rats under atrazine and deethylatrazine influence. J Steroid Biochem 33(1):141–146.2761262
*Bailey GW, White JL, Rothberg T. 1968. Adsorption of organic herbicides by montmorillonite: Role of pH and chemical character of adsorbate. Soil Sci Soc Amer Proc 32:222–234.
*Bainova A, Zaprianov Z, Kaloyanova-Simeonova F. 1979. Effect of pesticides on the activity of monoamine oxidase (MAO) in rats. Arh Hig Rada Toksikol 30(Suppl. 1):531–535.
*Bakke JE, Larson JD, Price CE. 1972. Metabolism of atrazine and 2-hydroxyatrazine by the rat. J Agric Food Chem 20(3):602–607.5072315
Balguer P, Joyeux A, Denison MS, 1996. Assessing the estrogenic and dioxin-like activities of chemicals and complex mixtures using in vitro recombinant receptor-reporter gene assays. Can J Physiol Pharmacol 74:216–222.8723035
Balinova AM, Mondesky M. 1999. Pesticide contamination of ground and surface water in Bulgarian Danube Plain. J Environ Sci Health B 34(1):33–46.10048204
*Balke NE, Price TP. 1988. Relationship of lipophilicity to influx and efflux of triazine herbicides in oat roots. Pest Biochem Physiol 30:228–237.
Ballantine LG, McFarland JE, Hackett DS. 1998a. Triazine herbicides: Risk assessment. ACS Symp Ser 683:432–447.
Ballantine LG, McFarland JE, Hackett DS. 1998b. Triazine herbicides: Risk assessment. ACS Symp Ser 683:399–413.
Baluch HU, Somasundaram L, Kanwar RS, 1993. Fate of major degradation products of atrazine in Iowa soils. J Environ Sci Health B 28(2):127–149.
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
Barrios E, Hoot S, Sera-Wattling C. 1997. Influence of compost addition to soil on the behaviour of herbicides. Pestic Sci 49:65–75.
*Bartsch H, Malaveille C, Camus AM, 1980. Validation and comparative studies on 180 chemicals with S. typhimurium strains and V79 Chinese hamster cells in the presence of various metabolizing systems. Mutat Res 76:1–50.6993936
*Bason CW, Colborn T. 1998. U.S. application and distribution of pesticides and industrial chemicals capable of disrupting endocrine and immune systems. J Clean Technol Environ Toxicol Occup Med 7:147–156.
*Battaglin WA, Goolsby DA. 1999. Are shifts in herbicide use reflected in concentration changes in Midwestern rivers? Environ Sci Technol 33:2917–2925.
*Battaglin WA, Furlong ET, Burkhardt MR, 2000. Occurrence of sulfonylurea, sulfonamide, imidazolinone, and other herbicides in rivers, reservoirs and ground water in the Midwestern United States, 1998. Sci Total Environ 248:123–133.10805233
*Baun A, Nyholm N. 1996. Monitoring pesticides in surface water using bioassays on XAD-2 preconcentrated samples. Water Sci Technol 33(6):339–347.
Beach ED, Fernandez-Carnage J, Huang W-Y, 1995. The potential risks of groundwater and surface water contamination by agricultural chemicals used in vegetable production. J Environ Sci Health Part A 30(6):1295–1325.
Belford AC, Van Drunken M, Been MA, 1998. Relative risks of transformation products of pesticides for aquatic ecosystems. Sci Total Environ 222:167–183.9851068
*Benfenati E, Tremolada P, Chiappetta L, 1990. Simultaneous analysis of 50 pesticides in water samples by solid-phase extraction and GC-MS. Chemosphere 21(12):1411–1421.
*Benigni R, Bignami M, Camoni I, 1979. A new in vitro method for testing plant metabolism in mutagenicity studies. J Toxicol Environ Health 5:809–819.513148
*Bennett ER, Moore MT, Cooper CM, 2000. Method for the simultaneous extraction and analysis of two current use pesticides, atrazine and lambda-cyhalothrin, in sediment and aquatic plants. Bull Environ Contam Toxicol 64:825–833.10856339
*Berger GS. 1994. Epidemiology of endometriosis. In: Berger GS, ed. Endometriosis: Advanced management and surgical techniques. New York, NY: Springer-Verlag.
*Best JA, Weber JB. 1974. Disappearance of s-triazines as affected by soil pH using a balance-sheet approach. Weed Sci 22:364–373.
*Bester K, Huhnerfuss H. 1993. Triazines in the Baltic and North Sea. Mar Pollut Bull 26(8):423–427.
Bester K, Huhnerfuss H, Neudorf B, 1995. Atmospheric deposition herbicides in Northern Germany and the German Bight (North Sea). Chemosphere 30(9):1639–1653.
*Biradar DP, Rayburn AL. 1995a. Chromosomal damage induced by herbicide contamination at concentrations observed in public water supplies. J Environ Qual 24:1222–1225.
*Biradar DP, Rayburn AL. 1995b. Flow cytogenetic analysis of whole cell clastogenicity of herbicides found in groundwater. Arch Environ Contam Toxicol 28:13–17.7717760
Blumhorst MR, Weber JB, Swain LR. 1990. Efficacy of selected herbicides as influenced by soil properties. Weed Technol 4:279–283.
*BNA. 2001. Environment and Safety Library on the Web States and Territories. Washington, DC: Bureau of National Affairs, Inc. http://www.esweb.bna.com. June 20, 2001.
Boecher M, Boeldick T, Sasse F. 1991. Cytotoxic effect of atrazine on murine B-lymphocytes in vitro. Sci Total Environ 132(2–3):429–433.
Bolan NS, Baskaran S. 1996. Characteristics of earthworm casts affecting herbicide sorption and movement. Biol Fertil Soils 22:367–372.
Börzsönyi M, Pintér A. 1979. Dagantkelto N-nitrozo vegyületek keletkezése in vivo és az emberi környezetben. Magy Onkol 23:171–179.
*Bouaid A, Martin-Esteban A, Fernandez P, 2000. Microwave-assisted extraction method for the determination of atrazine and four organophosphorus pesticides in oranges by gas chromatography (GC). Fresenius J Anal Chem 367:291–294.11227461
*Bradlow HL, Davis DL, Lin G, 1995. Effects of pesticides on the ratio of 16α/2-hydroxy estrone: A biologic marker of breast cancer risk. Environ Health Perspect 7:147–150.
*Bradlow HL, Davis D, Sepkovic DW, 1997. Role of the estrogen receptor in the action of organochlorine pesticides on estrogen metabolism in human breast cancer cell lines. Sci Total Environ 208:9–14.9496644
*Bradway DE, Moseman RF. 1982. Determination of urinary residue levels of the N-dealkyl metabolites of triazine herbicides. J Agric Food Chem 30:244–247.
*Brown DS, Flagg EW. 1981. Empirical prediction of organic pollutant sorption in natural sediments. J Environ Qual 10:382–336.
Brown GW, White JL, Rothberg T. 1968. Adsorption of organic herbicides by montmorillonite: Role of pH and chemical character of adsorbate. Soil Sci Soc Am Proc 32:222–234.
*Brown LM, Burmeister LF, Everett GD, 1993. Pesticide exposures and multiple myeloma in Iowa men. Cancer Causes and Control 4:153–156.8481493
*Brown MB, Blair A, Gibson R. 1990. Pesticide exposures and other agricultural risk factors for leukemia among men in Iowa and Minnesota. Cancer Res 50:6585–6591.2208120
*Brusick DJ. 1994. An assessment of the genetic toxicity of atrazine: Relevance to human health and environmental effects. Mutat Res 317:133–144.7511792
*Buchholz BA, Fultz E, Haack KW, 1999. HPLC-accelerator MS measurement of atrazine metabolites in human urine after dermal exposure. Anal Chem 71:3519–3525.10464479
*Burnmeister LF. 1990. Cancer in Iowa farmers: Recent results. Am J Ind Med 18:295–301.2220834
*Bushway RJ, Hurst HL, Perkins LB, 1992. Atrazine, alachlor, and carbofuran contamination of well water in Central Maine. Bull Environ Contam Toxicol 49:1–9.1392281
*Butler MA, Hoagland RE. 1989. Genotoxicity assessment of atrazine and some major metabolites in the Ames test. Bull Environ Contam Toxicol 43:797–804.2688762
*Cantemir C, Cozmei C, Scutaru B, 1997. Protein expression in peripheral lymphocytes from atrazine chronically intoxicated rats. Toxicol Lett 93:87–94.9486943
*Cantor KP, Blair A, Everett G, 1992. Pesticides and other agricultural risk factors for non-Hodgkin's lymphoma among men in Iowa and Minnesota. Cancer Res 52:2447–2455.1568215
Carabias-Martinez R, Rodriguez-Gonzalo E, Paniagua-Marcos PH, 2000. Analysis of pesticide residues in matrices with high lipid contents by membrane separation coupled on-line to a high-performance liquid chromatography system. J Chromatogr 869:427–439.
*Carr BR. 1992. Disorders of the ovary and female reproductive tract. In: Wilson JD, Foster DW, eds. Williams’ endocrinology. 8^th^ ed. New York: WB Saunders Co., 733–798.
*Castano P, Ferrario VF, Vizzotto L. 1982. Sciatic nerve fibers in albino rats after atrazine treatment: A morpho-quantitative study. Int J Tissue React 4:269–275.7169298
*Catenacci G, Barbieri F, Bersani M, 1993. Biological monitoring of human exposure to atrazine. Toxicol Lett 69:217–222.8212063
*Catenacci G, Maroni M, Cottica D, 1990. Assessment of human exposure to atrazine through the determination of free atrazine in urine. Bull Environ Contam Toxicol 44:1–7.2306524
Catenacci G, Tringali S, Imbriani M. 1995. Retrospective study of morbidity in a group professionally exposed to chlorotriazine herbicides. G Ital Med Lav 17:23–26.8991822
Catenacci G, Tringali S, Terzi R. 1997. Studio retrospettivo di morbilitB in gruppi di esposti professionalmente ad eerbicidi clorotriazinici. G Ital Med Lav Ergon 19(1):23–25.9377737
Chasseaud LF. 1974. The nature and distribution of enzymes catalyzing the conjunction of glutathione with foreign compounds. Huntingdon, England: Marcel Dekker, Inc., 185–220.
Chaturvedi AK. 1993. Biochemical and toxicological studies on the mixtures of three commonly-used herbicides in mice. Arch Environ Contam Toxicol 24:449–454.8507100
*Chevreuil M, Garmouma M, Teil MJ, 1996. Occurrence of organochlorines (PCBs, pesticides) and herbicides (triazines, phenylureas) in the atmosphere and in the fallout from urban and rural stations of the Paris area. Sci Total Environ 182:25–37.8854939
Chinoy NJ, Shukla S, Walimbe AS, 1997. Fluoride toxicity on rat testis and cauda epididymal tissue components and its reversal. Fluoride 30(1):41–50.
Chollet N, Degraeve N, Gilot-Delhalle J, 1982. The Belgian environmental mutagen society. Mutat Res 97:237–245.
*Clark GM, Goolsby DA, Battaglin WA. 1999. Seasonal and annual load of herbicides from the Mississippi River basin to the Gulf of Mexico. Environ Sci Technol 33(7):981–986.
Clay SA, Allmaras RR, Koskinen WC, 1988a. Desorption of atrazine and cyanazine from soil. J Environ Qual 17(4):719–723.
Clay SA, Koskinen WC, Allmaras RR, 1988b. Differences in herbicide adsorption on soil using several soil PH modification techniques. J Environ Sci Health B 23(6):559–573.
*Clements C, Ralph S, Petras M. 1997. Genotoxicity of select herbicides in Rana catesbeiana tadpoles using the alkaline single-cell gel DNA electrophoresis (comet) assay. Environ Molec Mutagen 29:277–288.9142171
*Clewell HJ III, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
*Connor K, Howell J, Chen I, 1996. Failure of chloro-s-triazine-derived compounds to induce estrogen receptor-mediated responses in vivo and in vitro. Fundam Appl Toxicol 30:93–101.8812239
*Cooper RL, Goldman JM, Stoker TE. 1999. Neuroendocrine and reproductive effects of contemporary-use pesticides. Toxicol Ind Health 15:26–36.10188189
Cooper RL, Stoker TE, Goldman JM, 1996a. Atrazine disrupts hypothalamic control of pituitary-ovarian function. Toxicologist 30:66.
*Cooper RL, Stoker TE, Goldman JM, 1996b. Effect of atrazine on ovarian function in the rat. Reprod Toxicol 10(4):257–264.8829248
*Cooper RL, Stoker TE, Tyrey L, 2000. Atrazine disrupts the hypothalamic control of pituitary-ovarian function. Toxicol Sci 53:297–307.10696778
Council on Scientific Affairs. 1998. Cancer risk of pesticides in agricultural workers. JAMA 260(7):959–966.
*Cova D, Nebuloni C, Arboldi A, 1996. N-nitrostation of triazines in human gastric juice. J Agric Food Chem 44:2852–2855.
Crain DA, Guillette LJ J, Rooney AA, 1997. Alterations in steroidogenesis in alligators (Alligator mississippiensis) exposed naturally and experimentally to environmental contaminants. Environ Health Perspect 105(5):528–533.9222139
Crain DA, Spiteri ID, Guillette LJ JR. 1999. The functional and structural observations of the neonatal reproductive system of alligators exposed in ovo to atrazine, 2,4-D, or estradiol. Toxicol Ind Health 15:180–185.10188200
*Crawford JJ, Sims GK, Mulvaney RL, 1998. Biodegradation of atrazine under denitrifying conditions. Appl Microbiol Biotechnol 49:618–623.9650260
*CRIS. 2002. CRIS Database. Current Research Information System. http://cristel.csrees.usda.gov/star/system.html. January 11, 2002.
*Croce CD, Morichetti E, Intorre L, 1996. Biochemical and genetic interactions of two commercial pesticides with the monooxygenase system and chlorophyllin. J Environ Pathol Toxicol Oncol 15(1):21–28.9037261
*Coupe RH, Manning MA, Foreman WT, 2000. Occurrence of pesticides in rain and air in urban and agricultural areas of Mississippi, April-September 1995. Sci Total Environ 248:227–240.10805242
Cummings AM, Rhodes BE, Cooper RL. 2000a. Atrazine effects on early pregnancy and implantation in the rat. Biol Reprod 62:183–184.
*Cummings AM, Rhodes BE, Cooper RL. 2000b. Effect of atrazine on the implantation and early pregnancy in 4 strains of rats. Toxicol Sci 58:135–143.11053550
*Curíc S, Gojmerac T, Zuric M. 1999. Morphological changes in the organs of gilts induced with low-dose atrazine. Vet Arh 69(3):135–148.
*Curran WS, Loux MM, Liebl RA, 1992. Photolysis of imidazolinone herbicides in aqueous solution and on soil. Weed Sci 40:143–148.
*Curtis KM, Savitz DA, Weinberg CR, 1999. The effect of pesticide exposure on time to pregnancy. Epidemiology 10:112–117.10069244
Dabeka RW, Mckenzie AD, Lacroix GM A. 1987. Dietary intakes of lead, cadmium, arsenic and fluoride by Canadian adults: A 24-hour duplicate diet study. Food Addit Contam 4(1):89–102.3556679
*Dalluge J, Hankemeier T, Vreuls RJ J, 1999. On-line coupling of immunoaffinity-based solid-phase extraction and gas chromatography for the determination of s-triazines in aqueous samples. J Chromatogr 830:377–386.
Dalton R. 2002. Frogs put in the gender blender by America's favourite herbicide. Nature 416(6882):665–666.11961511
*Dankwardt A, Pullen S, Rauchalles S, 1995. Atrazine residues in soil two years after the atrazine ban: A comparison of enzyme immunoassay with HPLC. Anal Lett 28(4):621–634.
Danzo BJ. 1997. Environmental xenobiotics may disrupt normal endocrine function by interfering with the binding of physiological ligands to steroid receptors and binding proteins. Environ Health Perspect 105(3):294–301.9171990
Das PC, McElroy WK, Cooper RL. 2000. Differential modulation of catecholamines by chlorotriazine herbicides in ohenchromocytoma (PC12) cells in vitro. Toxicol Sci 56:324–331.10910990
Das PC, McElroy WK, Cooper RL. 2001. Alteration of catecholamines in pheochromocytoma (PC12) cells in vitro by the metabolites of chlorotriazine herbicide. Toxicol Sci 59:127–137.11134552
Daxenberger A. 2002. Pollutants with androgen-disrupting potency. Eur J Lipid Sci Technol 104:124–130.
*de Almeida Azevedo D, Lacorte S, Vinhas T, 2000. Monitoring of priority pesticides and other organic pollutants in river water from Portugal by gas chromatography-mass spectrometry and liquid chromatography-atmospheric pressure chemical ionization mass spectrometry. J Chromatogr 879:13–26.
*de Bertoldi M 1980. Mutagenicity of pesticides evaluated by means of a gene-conversion in Saccharomyces cerevisiae and in Aspergillus nidulans. Environ Mutagen 2:359–370.7032901
De Ferrai M, Artuso M, Bonassi S, 1991. Cytogenetic biomonitoring of an Italian population exposed to pesticides: Chromosome aberration and sister-chromatid exchange analysis in peripheral blood lymphocytes. Mutat Res 260:105–113.2027334
De Laat J, Chramosta N, Doré M, 1994. Rate constants for reaction of hydroxyl radicals with some degradation by-products of atrazine by O_3_ or O_3_/H_2_O_2_. Environ Technol 15:419–428.
Della Morte R, Villani GR D, Di Martino E, 1994. Glutathione depletion induced in rat liver fractions by seven pesticides. J Biol Res- Boll Soc It Biol Sper 70(8–9):185–192.
*Denovan LA, Lu C, Hines CJ, 2000. Saliva biomonitoring of atrazine exposure among herbicide applicators. Int Arch Occup Environ Health 73:457–462.11057414
De Serres FJ. 1976. Prospects for a revolution in the methods of toxicological evaluation. Mutat Res 38:165–176.934169
*Desi I. 1983. Neurotoxicological investigation of pesticides in animal experiments. Neurobehav Toxicol Teratol 5:503–515.6664408
De Souza ML, Wackett LP, Boundy-Mills KL, 1995. Cloning, characterization, and expression of a gene region from Pseudomonas sp. strain ADP involved in the dechlorination of atrazine. Appl Environ Microbiol 61(9):3373–3378.7574646
*Detenbeck NE, Hermanutz R, Allen K, 1996. Fate and effects of the herbicide atrazine in flow-through wetland mesocosms. Environ Toxicol Chem 15(6):937–946.
Dewey SL. 1986. Effects of the herbicide atrazine on aquatic insect community structure and emergence. Ecology 67(1):148–162.
Dhanwada KR, Manske M, Makepeace J. 2002. Growth suppression induced by atrazine on human cells. Mol Biol Cell 12:386a 387a.
Donna A, Betta PG, Gagliardi F, 1981. Preliminary experimental contribution to the study of possible carcinogenic activity of two herbicides containing atrazine-simazine and trifuralin as active principles. Pathologica 73:707–721.7342028
*Donna A, Betta PG, Robutti F, 1984. Ovarian mesothelial tumors and herbicides: a case-control study. Carcinogenesis 5(7):941–942.6733855
*Donna A, Betta PG, Robutti F, 1986. Carcinogenicity testing of atrazine: Preliminary report on a 13-month study on male Swiss albino mice treated by intraperitoneal administration. G Ital Med Lav 8:119–121.3452555
*Donna A, Crosignani P, Robutti F, 1989. Triazine herbicides and ovarian epithelial neoplasms. Scand J Work Environ Health 15:47–53.
*Dorfler U, Feicht EA, Scheunert I. 1997. S-Triazine residues in groundwater. Chemosphere 35:99–106.9232000
*Dorsey L, Portier C. 2000. Atrazine: Hazard and dose-response assessment and characterization. FIFRA Scientific Advisory Panel meeting, SAP report no. 2000–05. http://www.epa.gov/scipoly/sap/2000/june27/finalatrazine.pdf. February 13, 2000.
Dosemeci M, Alavanja MC R, Rowland AS, 2002. A quantitative approach for estimating exposure to pesticides in the agricultural health study. Ann Occup Hyg 46(2):245–260.12074034
*Doussett S, Mouvet C, Schiavon M. 1994. Sorption of terbuthylazine and atrazine in relation to the physico-chemical properties of three soils. Chemosphere 28(3):467–476.
*Doussett S, Mouvet C, Schiavon M. 1997. Degradation of [^14^C]terbuthylazine and [^14^C]atrazine in laboratory soil microcosms. Pestic Sci 49(1):9–16.
*Dunkelberg H, Fuchs J, Hengstler JG, 1994. Genotoxic effects of the herbicides alachlor, atrazine, pendimethaline, and simazine in mammalian cells. Bull Environ Contam Toxicol 52:498–504.8167442
*Egaas E, Falls JG, Dauterman WC. 1995. A study of gender, strain and age differences in mouse liver glutathione-S-transferase. Comp Biochem Physiol 110C:35–40.
Ehling UH. 1980. Induction of gene mutations in germ cells of the mouse. Arch Toxicol 46:123–138.7235989
Eisler R. 1989. Atrazine hazards to fish, wildlife, and invertebrates: A synoptic review. Biol Rep 85(1.18):53.
*Eldridge JC, Fleenor-Heyser DG, Extrom PC, 1994a. Short-term effects of chlorotriazines on estrus in female Sprague-Dawley and Fischer 344 rats. J Toxicol Environ Health 43:155–167.7932846
Eldridge JC, Tennant MK, Wetzel LT, 1994b. Factors affecting mammary tumor incidence in chlorotriazine-treated female rats; hormonal properties, dosage, and animal strain. Environ Health Perspect 11:29–36.
Eldridge JC, Wetzel LT, Stevens JT, 1999b. The mammary tumor response in triazine-treated female rats: A threshold-mediated interaction with strain and species-specific reproductive senescence. Steroids 64:672–678.10503727
*Eldridge JC, Wetzel LT, Tyrey L. 1999a. Estrous cycle patterns of Sprague-Dawley rats during acute and chronic atrazine administration. Reprod Toxicol 13:491–499.10613397
Ellenhorn MJ, Barceloux DG. 1988. Medical toxicology: Diagnosis and treatment of human poisoning. New York, NY: Elsevier, 1078–1080.
*Ellenhorn MJ, Schonwald S, Ordog G, , eds. 1997. Medical toxicology: Diagnosis and treatment of human poisoning. 2^nd^ edition. Baltimore: Williams & Wilkins.
*Elling W, Huber SJ, Bankstahl B, 1987. Atmospheric transport of atrazine: A simple device for its detection. Environ Pollut 48:77–82.15092700
*Emnova EE, Merenyuk GV, Tsurkan LG. 1987. Study of the genetic activity of symmetrical triazine herbicides in Saccharomyces-cerevisiae strains. Tsitol Genet 21(2):127–131.3296366
*Entry JA, Emmingham WH. 1996. Influence of vegetation on microbial degradation of atrazine and 2,4-dichlorophenoxyacetic acid in riparian soils. Can J Soil Sci 76:101–106.
*EPA. 1983. Guidance for the reregistration of pesticide products containing atrazine as the active ingredient. Washington, DC: U.S. Environmental Protection Agency. PB84–149541.
EPA. 1984a. A supplement to a teratology study of atrazine technical Charles River rats. Washington, DC: U.S. Environmental Protection Agency. EPA MRID 405663–02. EPA Guidelines No. 83–8.
EPA. 1984b. A supplement to a teratology study of atrazine technical in New Zealand white rabbits. Washington, DC: U.S. Environmental Protection Agency. EPA MRID 405663–01. EPA Guidelines No. 83–3.
EPA. 1984c. A teratology study of atrazine technical in Charles River rats. Washington, DC: U.S. Environmental Protection Agency. EPA TRID 4542–010-19.
EPA. 1984d. Research and development: Health and environmental effects profile for atrazine. Cincinnati, OH: Office of Solid Waste and Emergency Response. U.S. Environmental Protection Agency. ECAO-CIN-PO98.
EPA. 1984e. Segment II teratology study in rabbits. Washington, DC: U.S. Environmental Protection Agency. EPA TRID 4542–010-17.
*EPA. 1984f. Twenty-four month combined chronic oral toxicity study of rats utilizing atrazine technical. Twelve month interim report for toxigenics study 410–1102. U.S. Environmental Protection Agency. EPA TRID 4426–010-19.
*EPA. 1986. Twenty-four month combined chronic oral toxicity study of rats utilizing atrazine technical. Final report for toxigenics study 410–1102. U.S. Environmental Protection Agency. EPA TRID 4701–920-30.
EPA. 1987a. Historical control data supplemental to oncogenicity study in mice. U.S. Environmental Protection Agency. EPA MRID 406293–01. EPA Guidelines No. 83–82.
*EPA. 1987b. Oncogenicity study in mice. U.S. Environmental Protection Agency. EPA MRID 404313–02. EPA Guidelines No. 83–2.
EPA. 1987c. Supplemental information for the two-generation study in rats. U.S. Environmental Protection Agency. EPA MRID 419868–01. EPA Guidelines No. 83–4.
*EPA. 1987d. Supplement to two-year chronic feeding/oncogenicity study in rats administered atrazine. U.S. Environmental Protection Agency. EPA MRID 406293–02. EPA Guidelines No. 83–5.
*EPA. 1987e. Two-generation reproduction study in rats. U.S. Environmental Protection Agency. EPA MRID 404313–03. EPA Guidelines No. 83–4.
*EPA. 1987f. Chronic toxicity study in dogs. U.S. Environmental Protection Agency. EPA MRID 404313–01. EPA Guidelines No. 83–1
EPA. 1990a. Interim methods for development of inhalation reference concentrations. Washington, DC: Office of Health and Environmental Assessment, Office of Research and Development, Environmental Criteria and Assessment Office, U.S. Environmental Protection Agency. EPA 600/8–90/066A.
EPA. 1990b. National pesticide survey: Summary results of EPA's national survey of pesticides in drinking water wells. Office of Water/Office of Pesticides and Toxic Substances, U.S. Environmental Protection Agency. http://www.epa.gov/cgi-bin/climage.html. April 9, 2001.
EPA. 1990c. Project summary: Analysis of solid waste- performance data for SW-846 methods 8270, 8081, and 8141. Las Vegas, NV: Environmental systems monitoring laboratory, U.S. Environmental Protection Agency. EPA/600/S4–90/015. http://www.epa.gov/cgi-bin/climage.html. April 20, 2001.
*EPA. 1996/1997. Pesticides industry sales and usage. Office of Prevention, Pesticides and Toxic Substances. U.S. Environmental Protection Agency. http://www.epa.gov/cgi-bin/climage.html. April 9, 2001.
*EPA. 1997. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. EPA/630/R-96/012.
*EPA. 2000a. Drinking water standards and health advisories. Washington, DC: Office of Water, U.S. Environmental Protection Agency. EPA 822-B-00–001.
EPA. 2000b. Preliminary risk assessment for atrazine. Permanent tolerances by pesticide: Aug 1996 TIS. Office of pesticide programs. U.S. Environmental Protection Agency. http://www.epa.gov/opfead1/cb/csbpage/updates/atrazine.html. April 16, 2000.
*EPA. 2001a. Atrazine registration eligibility decision: Product chemistry considerations, PC code 080803; Case number 0062. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/pesticides/reregistration/atrazine/chem_chap.pdf. April 16, 2001.
*EPA. 2001b. Interim status standards for owners and operators of hazardous waste treatment, storage, and disposal facilities. Compounds with Henry’s law constant less than 0.1 Y/X. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 265, Appendix VI. http://ecfr.access.gpo.gov/otcgi/cf. April 03, 2001.
*EPA. 2001c. National primary drinking water regulations. Maximum contaminant levels for organic contaminants. U.S. Environmental Protection Agency. 40 CFR 141.61. http://frwebgate.access.gpo.gov/cgi. April 03, 2001.
*EPA. 2001d. National primary drinking water regulations. Maximum contaminant level goals for organic contaminants. U.S. Environmental Protection Agency. 40 CFR 141.50. http://frwebgate.access.gpo.gov/cgi. April 03, 2001.
*EPA. 2001e. National primary drinking water regulations. Public notification. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.32 (e)(28). http://ecfr.access.gpo.gov/otcg. April 03, 2001.
EPA. 2001f. National primary drinking water regulation. Technical fact sheet on: Atrazine. U.S. Environmental Protection Agency. http://www.epa.gov/OGWDW/dwh/t-soc/atrazine.html. April 06, 2001.
*EPA. 2001g. Pesticide chemicals. Applicability; description of the organic pesticide chemicals manufacturing subcategory. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 455.20. http://ecfr.access.gpo.gov/otcg. April 03, 2001.
*EPA. 2001h. Tolerances and exemptions from tolerances for pesticide chemicals in food. Atrazine; tolerances for residues. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.220. http://ecfr.access.gpo.gov/otcgi. April 03, 2001.
*EPA. 2001i. Toxic chemical release reporting: Community right-to-know. Chemicals and chemical categories to which this part applies. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65. http://ecfr.access.gpo.gov/otcgi/cf. April 03, 2001.
EPA. 2001j. Toxicology disciplinary chapter for the registration eligibility decision document. Washington, DC: Office of Pesticide Programs. U.S. Environmental Protection Agency. PC code: 080803.
EPA. 2001k. Reregistration eligibility decision: Product chemistry considerations. Washington, DC: Office of Prevention, Pesticides and Toxic Substances. U.S. Environmental Protection Agency.
*EPA. 2002a. Revised human health risk assessment. Atrazine. Washington, DC: Office of Prevention, Pesticides and Toxic Substances. U.S. Environmental Protection Agency.
*EPA. 2002b. Announcement of the drinking water contaminant candidate list. Washington, DC: Office of Prevention, Pesticides and Toxic Substances. U.S. Environmental Protection Agency. http://www.epa.gov/OGWDW/ccl/ccl_fr.html.
EPA. 2002c. 2002 Edition of the drinking water standards and health advisories. Washington, DC: EPA Office of Prevention, Pesticides and Toxic Substances. U.S. Environmental Protection Agency. 822-R-02–038. http://www.epa.gov/waterscience.
EPA/OTS. 2002a. Initial submission: Letter containing a summary of a teratology study in rabbits on atrazine. Doc # 88–920000783 (full report previously submitted to USEPA under FIFRA: MRID 143006)
EPA/OTS. 2002b. Initial submission: Letter containing a summary of a teratology study in rats on atrazine. Doc #88–920000784 (full report previously submitted to USEPA under FIFRA: MRID 143008)
EPA/OTS. 2002c. Initial submission: Letter containing a summary of a teratology study in rats on atrazine. Doc #88–920000790 (Full report previously submitted to USEPA under FIFRA MRID 41065201)
*Extoxnet. 1996. Pesticide information profiles: Atrazine. Oregon: Extension Toxicology Network. http://ace.orst.edu/cgi-bin/mfs/01/pips/atrazine.html. April 16, 2001.
Farm Chemicals Handbook. 1997. Willoughby, OH: Meister Publishing Co., C32.
*Farm Chemicals Handbook. 2001. In: Meister RT, ed. Farm Chemicals Handbook. Meister Publishing Company, C33, C439, C447, D59, E102.
FDA. 1988. Residues in foods-1987. Pesticide program/monitoring program. U.S. Food and Drug Administration.
*FDA. 1993. Food and drug administration pesticide program residue monitoring. U.S. Food and Drug Administration - 1993.
*FDA. 1994. Pesticide analytical manual: Multiresidue methods. U.S. Department of Health and Human Services. Public Health Service. U.S. Food and Drug Administration.
FDA. 1995a. Food and Drug Administration pesticide program: Residue monitoring 1995. Food and Drug Administration. http://vm.cfsan.fda.gov/~acrobat/pes95res.html. April 12, 2001.
*FDA. 1995b. Pesticide program. Residue monitoring. U.S. Food and Drug Administration. http://vm.cfsan.fda.gov/~acrobat/pes95res.html.
FDA. 1995c. Table 2: Pesticides detectable by the methods used and pesticides found (*) in 1995 regulatory monitoring. Center for Food Safety and Applied Nutrition. U.S. Food and Drug Administration. http://vm.cfsan.fda.gov/~dms/pes95res.html.
*FDA. 1996. Table 3: Pesticides detectable and found (*) by methods used in 1996 regulatory monitoring. U.S. Food and Drug Administration.
*FDA. 1997. Table 4. Pesticides detectable and found (*) by methods used in 1997 regulatory monitoring. U.S. Food and Drug Administration.
*FDA. 1998. Table 4: Pesticides detectable and found (*) by methods used in 1998 regulatory monitoring. U.S. Food and Drug Administration.
*FDA. 1999. Table 3. Pesticides detectable and found (*) by methods used in 1999 regulatory monitoring. U.S. Food and Drug Administration.
*FDA. 2000a. Food additives permitted for direct addition to food for human consumption. Adjuvants for pesticide use dilutions. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 172.710. http://frwebgate.access.gpo.gov/cgi. March 27, 2001.
*FDA. 2000b. Requirements for specific standardized beverages. Bottled water. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 165.110. http://frwebgate.access.gpo.gov/cgi. March 27, 2001.
*Feakin SJ, Blackburn E, Burns RG. 1994. Biodegradation of s-triazine herbicides at low concentrations in surface waters. Water Res 28(11):2289–2296.
FEDRIP. 1993. Palo Alto, CA: Federal Research in Progress. Dialog Information Services, Inc.
*FEDRIP. 1998. Palo Alto, CA: Federal Research in Progress. Dialog Information Services, Inc.
FEDRIP. 2001. Palo Alto, CA: Federal Research in Progress. Dialog Information Services, Inc.
*FEDRIP. 2002. Palo Alto, CA: Federal Research in Progress. Dialog Information Services, Inc.
Felding G. 1992a. Leaching of atrazine and hexazinone from Abies nordmanniana (Steven) spach plantations. Pestic Sci 35:271–275.
Felding G. 1992b. Leaching of atrazine into ground water. Pestic Sci 35:39–43.
Fenton SE, Youngblood GL. 2000. Gestational exposure to atrazine induces prostatitis and epididymal fat. Biol Reprod 62(1):187–188.
Fenton SE, Greiner SN, Youngblood GL, 2002. Effects from gestational exposure to a mixture of atrazine and its biological metabolites in male Long-Evans rats. Biol Reprod 66:199–200.11751283
*Ferrari R, Nilsson T, Arena R, 1998. Inter-laboratory validation of solid-phase micro extraction for the determination of triazine herbicides and their degradation products at ng/1 level in water samples. J Chromatogr 795:371–376.
*Fishel F. 2000. Missouri restricted-use pesticide list. Agricultural MU Guide. Spring 2000.
*Fomon SJ. 1966. Body composition of the infant: Part I: The male “reference infant”. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
*Fomon SJ, Haschke F, Ziegler EE, 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35:1169–1175.7081099
Food and Drug Administration Pesticide Program. 1987. Residues in foods-1987. J Assoc Off Anal Chem 71(6):156A 174A.
Ford MM, Eldridge JC. 1999. Attenuation of gonadotropin release by high dose atrazine in rats: A pituitary mechanism of action [Abstract]. Abstr Soc Neurosci 25(1–2):1828.
*Foreman WT, Majewski MS, Goolsby DA, 2000. Pesticides in the atmosphere of the Mississippi River Valley, part II- air. Sci Total Environ 248:213–216.10805241
Foster S, Thomas T, Korth W. 1998. Laboratory-derived acute toxicity of selected pesticides to Ceriodaphnia dubia. Australas J Ecotoxicol 4:53–59.
*Foster TS, Khan SU. 1976. Metabolism of atrazine by the chicken. J Agric Food Chem 24(3):566–570.1270671
*Fournier M, Friborg J, Girard D, 1992. Limited immunotoxic potential of technical formulation of the herbicide atrazine (Aatrex) in mice. Toxicol Lett 60:263–274.1534425
Franekic J, Hulina G, Kniewald J, 1989. Atrazine and the genotoxicity of its metabolites [Abstract]. Environ Mol Mutagen 14(Suppl. 15):62.
Frank R, Logan L. 1988. Pesticide and industrial chemical residues at the mouth of the Grand Saugeen and Thames Rivers, Ontario, Canada, 1981–1985. Arch Environ Contam Toxicol 17:741–754.
*Frank R, Sirons GJ. 1985. Dissipation of atrazine residues from soils. Bull Environ Contam Toxicol 34:541–548.3986393
*Frank R, Braun HE, Van Hoveholddrinet M, 1982. Agriculture and water quality in the Canadian Great Lakes Basin: V. Pesticide use in 11 agricultural watersheds and presence in stream water, 1975–1977. J Environ Qual 11:497–505.
Frank R, Logan L, Clegg BS. 1991. Pesticide and polychlorinated biphenyl residues in waters at the mouth of the Grand, Saugeen, and Thames Rivers, Ontario, Canada, 1986–1990. Arch Environ Contam Toxicol 21:585–595.1759852
*Friedmann AS. 2002. Atrazine inhibition of testosterone production in rat males following peripubertal exposure. Reprod Toxicol 16:275–279.12128101
*Gaines TB, Linder RE. 1986. Acute toxicity of pesticides in adult and weaning rats. Fundam Appl Toxicol 7:299–308.3758548
*Gan J, Becker RL, Koskinen WC, 1996. Degradation of atrazine in two soils as a function of concentration. J Environ Qual 25:1064–1072.
Garaj-Vrhovac V, Zeljezic D. 2002. Assessment of genome damage in a population of Croatian workers employed in pesticide production by chromosomal aberration analysis, micronucleus assay and comet assay. J Appl Toxicol 22:249–255.12210542
Gaynor JD, MacTavish DC, Labaj AB. 1998. Atrazine and metolachlor residues in Brookston CL following conventional and conservation tillage culture. Chemosphere 36(15):3199–3210.9747519
*Gaynor JD, Tan CS, Drury CF, 1995. Atrazine in surface and subsurface runoff as affected by cultural practices. Water Qual Res J Can 30(3):513–531.
*Gebel T, Kevekordes S, Pav K, 1997. In vivo genotoxicity of selected herbicides in the mouse bone-marrow micronucleus test. Arch Toxicol 71:193–197.9049057
*George SE, Chadwick RW, Kohan MJ, 1995. Atrazine treatment potentiates excretion of mutagenic urine in 2,6-dinitrotoluene-treated Fischer 344 rats. Environ Mol Mutagen 26:178–184.7556115
*Ghiazza J, Zavarise G, Lanero M, 1984. SCE (sister chromatid exchange) induced by trifluralin, atrazine and simazine in human lymphocyte chromosomes. Boll Soc It Biol Sper 11:2145–2153 [Italian].
Gilman SD, Gee SJ, Hammock BD, 1998. Analytical performance of accelerator mass spectrometry and liquid scintillation counting for detection of ^14^C-labeled atrazine metabolites in human urine. Anal Chem 70:3463–3469.9726169
*Giwercman A, Carlsen E, Keiding N, 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl 101(2):65–71.
*Glotfelty DE, Leech MM, Jersey J, 1989. Volatilization and wind erosion of soil surface applied atrazine, simazine, alachor, and toxaphene. J Agric Food Chem 37:546–551.
*Glotfelty DE, Seiber JN, Liljedahl LA. 1987. Pesticides in fog. Nature 325:602–605.
*Gluth G, Freitag D, Hanke W, 1985. Accumulation of pollutants in fish. Comp Biochem Physiol 81C(2):273–277.
*Gojmerac T, Kniewald J. 1989. Atrazine biodegradation in rats-a model for mammalian metabolism. Bull Environ Contam Toxicol 43:199–206.2775886
*Gojmerac T, Kartal B, Curíc S, 1996. Serum biochemical changes associated with cystic ovarian degeneration in pigs after atrazine treatment. Toxicol Lett 85(1):9–15.8619262
*Gojmerac T, Kartal B, Zuric M, 1995. Serum biochemical and histopathological changes related to the hepatic function in pigs following atrazine treatment. J Appl Toxicol 15(3):233–236.7560745
*Gojmerac T, Uremovic M, Uremovic Z, 1999. Reproductive disturbance caused by an s-triazine herbicide in pigs. Acta Vet Hung 47(1):129–135.10213938
Goolsby DA, Thurman EM, Pomes ML, 1997. Herbicides and their metabolites in rainfall: Origin, transport, and deposition patterns across the Midwestern and Northeastern United States, 1990–1991. Environ Sci Technol 31:1325–1333.
Graber ER, Gerstl Z, Fischer E, 1995. Division S-1-soil physics: Enhanced transport of atrazine under irrigation with effluent. Soil Sci Soc Am J 59:1513–1519.
Graumann K, Briethofer A, Jungbauer A. 1999. Monitoring of estrogen mimics by recombinant yeast assay: Synergy between natural and synthetic compounds? Sci Total Environ 225:69–79.10028704
*Green RE, Schneider RC, Gavenda RT. 1993. Utility of sorption and degradation parameters from the literature for site-specific pesticide impact assessments. Soil Sci Soc Am J 32:209–225.
*Griffiths AJ F. 1979. Neurospora prototroph selection system for studying aneuploid production. Environ Health Perspect 31:75–80.387401
*Guzelian PS, Henry CJ, Olin SS, eds. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences Institute Press.
Haddad LM, Winchester JF. 1990. Clinical management of poisoning and drug overdose. 2^nd^ ed. Philadelphia, PA: W.B. Sanders Company, 1084–1085.
*Haddad LM, Shannon MW, Winchester JF, eds. 1998. Clinical management of poisoning and grug overdose. Third edition. Philadelphia, PA: W.B. Sanders Company, 413–425.
Haith DA. 1980. A mathematical model for estimating pesticide losses in runoff. J Environ Qual 9(3):428–433.
Hall JC, VanDeynze TD, Struger J, 1993. Enzyme immunoassay based survey of precipitation and surface water for the presence of atrazine, metolachlor and 2,4-D. J Environ Sci Health B 28(5):577–598.8409233
*Hall LL, Fisher HL, Sumler MR, , eds. 1988. Dose response of skin absorption in young and adult rats. Philadelphia, PA: American Society for Testing and Materials (ASTM), 177–194.
*Hanioka N, Jinno H, Kitazawa K, 1998a. In vitro biotransformation of atrazine by rat liver microsomal cytochrome P450 enzymes. Chem Biol Interact 116:181–198.9920461
Hanioka N, Jinno H, Tanaka-Kagawa T, 1998b. Changes in rat liver cytochrome P450 enzymes by atrazine and simazine treatment. Xenobiotica 28(7):683–698.9711812
*Hanioka N, Jinno H, Tanaka-Kagawa T, 1999. In vitro metabolism of simazine, atrazine and propazine by hepatic cytochrome P450 enzymes of rat, mouse and guinea pig, and oestrogenic activity of chlorotriazines and their main metabolites. Xenobiotica 29(12):1213–1226.10647908
*Hansch C, Leo A, Hoekman D. 1995. Exploring QSAR - hydrophobic, electronic, and steric constants. Washington, DC: Amer Chem Soc, 48.
Harrison GW, Weber JB, Baird JV. 1976. Herbicide phytotoxicity as affected by selected properties of North Carolina soils. Weed Sci 24:120–126.
*Hasegawa R, Ito N. 1992. Liver medium-term bioassay in rats for screening of carcinogens and modifying factors in hepatocarcinogenesis. Food Chem Toxicol 30(11):979–992.1473791
Haskovcova I, Trojanova M, Mourek J. 1991. Zhemy v organismu laboratorního potkana za vyvoje po parenterálnním podání herbicidu zeazin S-40. Sb Lek 93(5–6):180–185.1798916
*HazDat. 2003. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA. http://www.atsdr.cdc.gov/gsl/getsite.
Heindel JJ, Chapin RE, Gulati DK, 1994. Assessment of the reproductive and developmental toxicity of pesticide/fertilizer mixtures based on confirmed pesticide contamination in California and in Iowa groundwater. Fundam Appl Toxicol 22:605–621.8056207
Hemminki K, Reunanen A, Kahn H. 1990. Use of DNA adducts in the assessment of occupational and environmental exposure to carcinogens. Eur J Cancer 27(3):284–289.
*Hernandez F, Beltran J, Lopez FJ, 2000. Use of solid-phase microextraction for the quantitative determination of herbicides in soil and water samples. Anal Chem 72:2313–2322.10845380
Hiendel JJ, Price CJ, George JD, 1992. Developmental toxicity evaluation in rats of a pesticide/fertilizer mixture selected to mimic environmental exposure [Abstract]. Teratology 45(5):500.
Hill EF, Heath RG, Spann JW, 1975. Lethal dietary toxicities of environmental pollutants to birds. U S Fish Wildl Serv Spec Sci Rep: Wildl 191:1–61.
*Hoar Sk, Blair A Holmes FF, 1985. Herbicides and colon cancer. Lancet 1:1277–1278.
*Hoar SK, Blair A, Holmes FF, 1986. Agricultural herbicide use and risk of lymphoma and soft-tissue sarcoma. JAMA 256:1141–1146.3801091
*Hoel DG, Davis DL, Miller AB, 1992. Trends in cancer mortality in 15 industrialized countries, 1969–1986. J Natl Cancer Inst 84(5):313–320.1738181
*Hogenboom AC, Speksnijder P, Vreeken RJ, 1997. Rapid target analysis of microcontaminants in water by on-line single-short-column liquid chromatography combined with atmospheric pressure chemical ionization tandem mass spectrometry. J Chromatogr A 777:81–90.9297841
Hooghe RJ, Devos S, Hooghe-Peters EL. 2000. Effects of selected herbicides on cytokine production in vitro. Life Sci 66(26):2519–2525.10883730
*Hopenhayn-Rich C, Stump ML, Browning SR. 2002. Regional assessment of atrazine exposure and incidence of breast and ovarian cancers in Kentucky. Arch Environ Contam Toxicol 42:127–136.11706377
*Howard PH. 1991. Handbook of environmental fate and exposure data for organic chemicals. Chelsea, MI, ed.: Lewis Publishers, Inc.
*HSDB. 2001. Hazardous Substance Data Bank. National Library of Medicine, National Toxicology Information Program, Bethesda MD. http://toxnet.nlm.nih.gov/cgi-bin/sis/htmlgen?HSBD. December, 2002.
*HSDB. 2002. Hazardous Substance Data Bank. National Library of Medicine, National Toxicology Information Program, Bethesda MD. http://toxnet.nlm.nih.gov/cgi-bin/sis/htmlgen?HSBD. April 6, 2001.
Huber W. 1993. Ecotoxicological relevance of atrazine in aquatic systems. Environ Toxicol Chem 12:1865–1881.
*Humburg NE, ed. 1989. Herbicide handbook of the weed science society of America. 6^th^ ed. Champaign, IL: Weed Sci Soc Amer, 17.
*Hurbankova M, Kaiglova A, Piotrovskij VK, 1996. Some bronchoalveolar lavage and blood parameters in response to intratracheal instillation of atrazine in rats. Biologia (Bratislava) 51(6):729–734.
*IARC. 1999. IARC monographs on the evaluation of carcinogenic risks to humans: Some chemicals that cause tumours (SIC) of the kidney or urinary bladder in rodents and some other substances. Vol. 73. Lyon, France: World Health Agency: International Agency for Research on Cancer.
*IARC. 2001. Atrazine (Group 3). Summary of data reported and evaluation. International Agency for Research on Cancer. http://193.51.164.11/htdocs/Monographs/Vol73/73-03.html. April 06, 2001.
*Ikonen R, Kangas J, Savolainen H. 1988. Urinary atrazine metabolites as indicators for rat and human exposure to atrazine. Toxicol Lett 44:109–112.3188067
*Infurna R, Levy B, Meng C, 1988. Teratological evaluations of atrazine technical, atrazine herbicide, in rats and rabbits. J Toxicol Environ Health 24:307–319.3398074
*Innes JR M, Ulland BM, Valerio MG, 1969. Bioassay of pesticides and industrial chemicals for tumorigenicity in mice: A preliminary study. J Natl Cancer Inst 42(16):1101–1114.5793189
IRIS. 2001. Atrazine. Integrated Risk Information System, U.S. Environmental Protection Agency. http://www.epa.gov/IRIS/subst/0209.html. April 06, 2001.
*IRIS. 2002. Atrazine. Integrated Risk Information System, U.S. Environmental Protection Agency. http://www.epa.gov/IRIS/subst/0209.html. December, 2002.
*Ishidate M, Harnois MC, Sofuni T. 1988. A comparative analysis of data on the clastogenicity of 951 chemical substances tested in mammalian cell cultures. Mutat Res 195:151–213.3277036
*Islam MO, Hara M, Miyake J. 2002. Induction of P-glycoprotein, glutathion-S-transferase and cytochrome P450 in rat liver by atrazine. Environ Toxicol Pharmacol 12:1–6.21782617
*Jaeger LL, Jones AD, Hammock BD. 1998. Development of an enzyme-linked immunosorbent assay for atrazine mercapturic acid in human urine. Chem Res Toxicol 11:342–352.9548805
Jakominic M, Jelicic A, Simic B, 2000. Effects of atrazine on 5alpha-dihydrotestosterone on regulated mechanisms in rat prostate nuclei. Biomedicine 1:51–59.
Jarzynka W, Put A. 1985. Effect of some herbicides on the parotid glands and oral mucosa in rats. Czas Stomatol 38(3):198–204.3867435
Jarzynka W, Put A. 1988. [The influence of long-term utilization of some herbicides on oral cavity tissues of white rats]. Czas Stomat 41(11):680–686. (Polish)
Jayachandran K, Steinheimer TR, Somasundaram L, 1994. Occurrence of atrazine and degradates as contaminants of subsurface drainage and shallow groundwater. J Environ Qual 23:311–319.
*Johanson CE. 1980. Permeability and vascularity of the developing brain: Cerebellum vs cerebral cortex. Brain Res 190:3–16.6769537
*Johnson AE, Van Kampen KR, Binns W. 1972. Effects on cattle and sheep of eating hay treated with the triazine herbicides, atrazine and prometone. Am J Vet Res 33:1433–1438.5039515
*Johnson B, Fishel F, Kendig A. 1996. Atrazine: Best management practices and alternatives in Missouri. University of Missouri-Columbia Extension office. http://www.muextension.missouri.edu/xplor/agguides/crops/g04851.htm#getpdf. February 13, 1996.
*Jowett PL H, Nicohlson SS, Gamble GA. 1986. Tissue levels of atrazine in a case of bovine poisoning. Vet Hum Toxicol 28(6):539–540.3788036
*Kappas A. 1988. On the mutagenic and recombinogenic activity of certain herbicides in Salmonella typhimurium and in Aspergillus nidulans. Mutat Res 204:615–621.3280995
Kearney PC, Oliver JE, Helling CS, 1977. Distribution, movement, persistence, and metabolism of N-nitrosoatrazine in soils and a model aquatic ecosystem. J Agric Food Chem 25(5):1177–1181.893846
*Kettles MA, Browning SR, Prince TS, 1997. Triazine herbicide exposure and breast cancer incidence: An ecologic study of Kentucky counties. Environ Health Perspect 105(11):1222–1227.9370519
*Kligerman AD, Doerr CL, Tennant AH, 2000a. Cytogenetic studies of three triazine herbicides. I. In vitro studies. Mutat Res 465:53–59.10708969
*Kligerman AD, Doerr CL, Tennant AH, 2000b. Cytogenic studies of three triazine herbicides. II. In vivo micronucleus studies in mouse bone marrow. Mutat Res 471:107–112.11080666
*Klint M, Arvin E, Jensen BK. 1993. Degradation of the pesticides mecoprop and atrazine in unpolluted sandy aquifers. J Environ Qual 22:262–266.
*Kniewald J, Jakominic M, Tomljenovic A, 2000. Disorders of male rat reproductive tract under the influence of atrazine. J Appl Toxicol 20:61–68.10641017
Kniewald J, Mildner P, Kniewald Z. 1979. Effects of s-triazine herbicides on hormone-receptor complex formation, 5α-reductase and 3α-hydroxysteroid dehydrogenase activity at the anterior pituitary level. J Steroid Biochem 11:833–838.491646
*Kniewald J, Osredecki V, Gojmerac T, 1995. Effect of S-triazine compounds on testosterone metabolism in the rat prostate. J Appl Toxicol 15(3):215–218.7560742
Kniewald J, Peruzovic M, Gojmerac T, 1987. Indirect influence of s-triazines on rat gonadotropic mechanism at early postnatal period. J Steroid Biochem 27(4–6):1095–1100.3695505
Kniewald J, Simíc B, Jakominic M, 2001. Atrazine induced a fall of sperm numbers and epididymal sperm motility in the rat: Study of neuroendocrine mechanisms [Abstract]. Biol Reprod 64:351–352.
Kniewald J, Simíc B, Jakominic M, 2002. Multigeneration toxicity test of atrazine on reproductive capability of male rats [Abstract]. Toxicol Lett 123:75.
*Kolpin DW, Kalkhoff SJ. 1993. Atrazine degradation in a small stream in Iowa. Environ Sci Technol 27:134–139.
*Kolpin DW, Barbash JE, Gilliom RJ. 2000. Pesticides in ground water of the United States, 1992–1996. Ground Water 38(6):858–863.
*Kolpin DW, Kalkhoff SJ, Goolsby DA, 1997a. Occurrence of selected herbicides and herbicide degradation products in Iowa’s ground water. Ground Water 35:679–688.
*Kolpin DW, Sneck-Fahrer D, Hallberg GR, 1997b. Temporal trends of selected agricultural chemicals in Iowa's groundwater, 1982–1995: Are things getting better? J Environ Qual 26:1007–1017.
Komeil AA, Abdalla MA, Younis HM, 1988. Teratology of three different insecticides in pregnant mice [Abstract]. Teratology 38(2):21A.
*Komori M, Nishio K, Kitada M, 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29:4430–4433.2350547
*Konda LN, Pasztor Z. 2001. Environmental distribution of acetochlor, atrazine, chlorpyrifos, and propisochlor under field conditions. J Agric Food Chem 49(8):3859–3863.11513679
*Kornilovskaya IN, Gorelaya MV, Usenko VS, 1996. Histological studies of atrazine toxicity on the thyroid gland in rats. Biomed Environ Sci 9:60–66.8721629
*Koskinen WC, Clay SA. 1997. Factors affecting atrazine fate in North Central US soils. Rev Environ Contam Toxicol 151:117–165.9216258
*Koskinen WC, Rochette EA. 1996. Atrazine sorption-desorption in filed-moist soils. Int J Environ Anal Chem 65:223–230.
*Kottler BD, White JC, Kelsey JW. 2001. Influence of soil moisture on the sequestration of organic compounds in soil. Chemosphere 42:893–898.11272911
*Krishnan K, Andersen ME, Clewell HJ II I, 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RS H, ed. Toxicology of chemical mixtures: Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
*Kroschwitz JI, Howe-Grant M. 1995. Kirk-Othmer encyclopedia of chemical technology. 4th edition. New York, NY: John Wiley and Sons, 13:73.
*Kruger EL, Rice PJ, Anhalt JC, 1997. Comparative fates of atrazine and deethylatrazine in sterile and nonsterile soils. J Environ Qual 26:95–101.
Landrigan PJ, Claudio L, Markowitz SB, 1999. Pesticides and inner-city children: Exposures, risks, and prevention. Environ Health Perspect Suppl 107 (3):431–437.
*Lang D, Crigee D, Grothusen A, 1996. In vitro metabolism of atrazine, terbuthylazine, ametryne, and terbutryne in rats, pigs, and humans. Drug Metab Dispos 24(8):859–865.8869820
*Lang DH, Rettie AE, Bocker RH. 1997. Identification of enzymes involved in the metabolism of atrazine, terbuthylazine, ametryne, and terbutryne in human liver microsomes. Chem Res Toxicol 10(9):1037–1044.9305587
*Larsen GL, Bakke JE. 1975. Metabolism of 2-chloro-4-cyclopropylamino-6-isopropylamino-s-triazine (Cyprazine) in the rat. J Agric Food Chem 23(3):388–392.1150981
Larsen SB, Joffe M, Bonde JP, 1998. Time to pregnancy and exposure to pesticides in Danish farmers. Occup Environ Med 55:278–283.9624283
*Laws SC, Ferrel JM, Stoker T, 2000. The effects of atrazine on female wistar rats: An evaluation of the protocol for assessing pubertal development and thyroid function. Toxicol Sci 58:366–376.11099648
Le Clorirec C 1983. Concentation and analysis of numerous nitrogenous organic substances in natural waters. Int J Environ Anal Chem 14:127–145.
*Leeder JS, Kearns GL. 1997. Pharmcogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
Leistra M, Boesten JJTI. 1989. Pesticide contamination of groundwater in Western Europe. Agric Ecosyst Environ 26:369–389.
Lerch RN, Blanchard PE, Thurman EM. 1998. Contribution of hydroxylated atrazine degradation products to the total atrazine load in Midwestern states. Environ Sci Technol 32:40–48.
*Leung H-W. 1993. Physiologically-based pharmacokinetic modeling. In: Ballentine B, Marro T, Turner P, eds. General and applied toxicology. Vol. 1. New York, NY: Stockton Press, 153–164.
*L’Haridon JL, Fernandez M, Ferrier V, 1993. Evaluation of the genotoxicity of N-nitrosoatrazine, N-nitrosodiethanolamine and their precursors in vivo using the newt micronucleus test. Water Res 27(5):855–862.
*Lioi MB, Scarfi MR, Santoro A, 1998. Cytogenetic damage and induction of pro-oxidant state in human lymphocytes exposed in vitro to gliphosate, vinclozolin, atrazine, and DPX-E9636. Environ Mol Mutagen 32:39–46.9707097
*Lioy PJ, Edwards RD, Freeman N, 2000. House dust levels of selected insecticides and a herbicide measured by the EL and LWW samplers and comparisons to hand rinses and urine metabolites. J Expo Anal Environ Epidemiol 10:327–340.10981727
*Liskova A, Wagnerova J, Tulinska J, 2000. Effect of the herbicide atrazine on some immune parameters in mice. J Trace Microprobe Tech 18(2):235–240.
Liu S, Yen ST, Kolpin DW. 1996. Atrazine concentrations in near-surface aquifers: A censored regression approach. J Environ Qual 25:992–999.
*Livingston AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4:301–324.351201
Loosli R. 1995. Epidemiology of atrazine. Rev Environ Contam Toxicol 143:47–57.7501866
*Lopez-Avila V, Benedicto J, Baldin E. 1992. Analysis of classes of compounds of environmental concern: III. Organochlorine pesticides. J High Resolut Chromatogr 15:319–328.
*Lorberau CD, Pride JL. 2000. A laboratory comparison of two media for use in the assessment of dermal exposure to pesticides. Appl Occup Environ Hyg 15(12):946–950.11141607
*Lu C, Anderson LC, Fenske RA. 1997a. Determination of atrazine levels in whole saliva and plasma in rats: Potential of salivary monitoring for occupational exposure. J Toxicol Environ Health 50:101–111.9048955
*Lu C, Anderson LC, Morgan MS, 1997b. Correspondence of salivary and plasma concentrations of atrazine in rats under variable salivary flow rate and plasma concentration. J Toxicol Environ Health 52:317–329.9354177
*Lu C, Anderson LC, Morgan MS, 1998. Salivary concentrations of atrazine reflect free atrazine plasma levels in rats. J Toxicol Environ Health 53:283–292.
*Lucas AD, Jones AD, Goodrow MH, 1993. Determination of atrazine metabolites in human urine: Development of a biomarker of exposure. Chem Res Toxicol 6:107–116.8448340
*Lunchick C, Selman F. 1998. The assessment of worker exposure to atrazine and simazine: A tiered approach. ACS Symp Ser 683:141–155.
*Lusby AF, Simmons Z, McGuire PM. 1979. Variation in mutagenicity of s-triazine compounds tested on four Salmonella strains. Environ Mutagen 1:287–290.399912
Ma L, Selim HM. 1996. Atrazine retention and transport in soils. Rev Environ Contam Toxicol 145:129–173.7494909
*MacIntosh DL, Needham LL, Hammerstrom KA, 1999. A longitudinal investigation of selected pesticide metabolites in urine. J Expo Anal Environ Epidemiol 9:494–501.10554151
Madar I, Giurgea R. 1981. The effect of atrazine and prometryne on the glucose consumption and the insulin-sensitivity of diaphragms of white rats. Stud Cercet Biol Ser Biol Anim 33(2):121–126.
*Madsen L, Lindhardt B, Rosenberg P, 2000. Pesticide sorption by low organic carbon sediments: A screening for seven herbicides. J Environ Qual 29:1488–1500.
Magnelli L, Fibbi G, Caldini R, 1989. Inhibition of spontaneous growth and induced differentiation of murine erythroleukaemia cells by paraquat and atrazine. Food Chem Toxicol 27(2):125–128.2714717
*Majewski MS, Foreman WT, Goolsby DA. 2000. Pesticides in the atmosphere of the Mississippi River Valley, part I-rain. Sci Total Environ 248:201–212.10805240
Malkomes VH P, Behr U. 1987. [Influence of the mode of application of chlortoluron and its combination with atrazine on microbial activities in soil.] Nachrichtenbl Pflanzenschutz DDR 39:183–188. (German)
Manciulea S, Abraham AD, Wittenberger C. 1980. Atrazine and prometryn activity on the hepatic biosynthesis of white rats. Stud Cercet Biol Ser Biol Anim 32(1):51–53.
*Mandelbaum RT, Wackett LP, Allan DL. 1993. Mineralization of the s-triazine ring of atrazine by stable bacterial mixed cultures. Appl Environ Microbiol 59(6):1695–1701.8328795
Mantovani A. 1993. Reproductive risks from contaminants in drinking water. Ann Ist Super Sanita 29(2):317–326.8279723
*Marcé RM, Prosen H, Crespo C, 1995. On-line trace enrichment of polar pesticides in environmental waters by reversed-phase liquid chromatography-diode array detection-particle beam mass spectrometry. J Chromatogr A 696:63–74.
Maria CS, Vilas MG, Muriana FG, 1986. Subacute atrazine treatment effects on rat renal functions. Bull Environ Contam Toxicol 36:325–331.3955241
Martens DA, Bremner JM. 1993. Influence of herbicides on transformations of urea nitrogen in soil. J Environ Sci Health B B 28(4):377–395.
Mathew R, Kacew S, Khan SU. 1998. Bioavailability in rats of bound pesticide residues from tolerant or susceptible varieties of soybean and canola treated with metribuzin or atrazine. Chemosphere 36(3):589–596.9451811
*Mathias M, Gilot D J, Moutschen J. 1989. Mutagenicity of atrazine in Schizosaccharomyces pombe lindner with and without metabolic activation by maize. Environ Exp Bot 29(2):237–240.
*Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74:135–149.1387742
McDougal A, Safe S. 1998. Induction of 16α-/2-hydroxyestrone metabolite ratios in MCF-7 cells by pesticides, carcinogens, and antiestrogens does not predict mammary carcinogens. Environ Health Perspect 106(4):203–206.
*McDougal A, Wilson C, Safe S. 1997. Induction of estradiol 2-hydroxylase activity in MCF-7 human breast cancer cells by pesticides and carcinogens. Environ Toxicol Chem 3:195–199.
*McLaughlin RA, Johnson BS. 1997. Optimizing recoveries of two chlorotriazine herbicide metabolites and 11 pesticides from aqueous samples using solid-phase extraction and gas chromatography-mass spectrometry. J Chromatogr A 790:161–167.9435119
*Meakins NC, Bubb JM, Lester JN. 1995. The mobility, partitioning and degradation of atrazine and simazine in the salt marsh environment. Mar Pollut Bull 30(12):812–819.
*Means JC, Plewa MJ, Gentile JM. 1988. Assessment of the mutagenicity of fractions from s-triazine-treated Zea mays. Mutat Res 197:325–336.3123924
*Meisner LF, Belluck DA, Roloff BD. 1992. Cytogenetic effects of alachlor and/or atrazine in vivo and in vitro. Environ Mol Mutagen 19:77–82.1732107
*Meisner LF, Roloff BD, Belluck DA. 1993. In vitro effects of n-nitrosoatrazine on chromosome breakage. Arch Environ Contam Toxicol 24:108–112.8466288
*Meli G, Bagnati R, Fanelli R, 1992. Metabolic profile of atrazine and N-nitrosoatrazine in rat urine. Bull Environ Contam Toxicol 48:701–708.1504516
*Mencoboni M, Lerza R, Bogliolo G, 1992. Effect of atrazine on hemopoietic system. In Vivo 6:41–44.1627741
Messaad IA, Peters EJ, Young L. 2000. Thermal tolerance of red shiner (Cyprinella lutrensis) after exposure to atrazine, terbufos, and their mixtures. Bull Environ Contam Toxicol 64:748–754.10857461
Meulenberg EP. 2002. A new test to identify endocrine disruptors using sex hormone-binding globulins from human serum. Eur J Lipid Sci Technol 104:131–136.
Meydani M, Hathcock JN. 1984. Effect of dietary methionine on methyl mercury and atrazine toxicity. Drug Nutr Interact 2:217–233.
*Meylan WM, Howard PH. 1993. Computer estimation of the atmospheric gas-phase reaction rate of organic compounds with hydroxyl radicals and ozone. Chemosphere 26:2293–2299.
*Miles CJ, Pfeuffer RJ. 1997. Pesticides in canals of South Florida. Arch Environ Contam Toxicol 32:337–345.9175497
*Miller SM, Sweet CW, Depinto JV, 2000. Atrazine and nutrients in precipitation: Results from the Lake Michigan mass balance study. Environ Sci Technol 34:55–61.
*Mills PK. 1998. Correlation analysis of pesticide use data and cancer incidence rates in California Counties. Arch Environ Health 53(6):410–413.9886160
*Mohammed KB, Ma TH. 1999. Tradescantia-micronucleus and -stamen hair mutation assays on genotoxicity of the gaseous and liquid forms of pesticides. Mutat Res 426:193–199.10350597
*Mojasevic M, Helling CS, Gish TJ, 1996. Persistence of seven pesticides as influenced by soil moisture. J Environ Sci Health B B 31(3):469–476.
Moorhouse KG, Casida JE. 1992. Pesticides as activators of mouse liver microsomal glutathione S-transferase. Pestic Biochem Physiol 44:83–90.
Morgan MS. 1997. The biological exposure indices: A key component in protecting workers from toxic chemicals. Environ Health Perspect 105:105–115.9114280
*Morichetti E, Croce CD, Rosellini D, 1992. Genetic and biochemical studies on a commercial preparation of atrazine. Toxicol Environ Chem 37:35–41.
*Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokin 5:485–527.
*Muller SR, Berg M, Ulrich MM, 1997. Atrazine and its primary metabolites in Swiss Lakes: Input characteristics and long-term behavior in the water column. Environ Sci Tech 31:2104–2113.
*Munger R, Isacson P, Hu S, 1997. Intrauterine growth retardation in Iowa communities with herbicide-contaminated drinking water supplies. Environ Health Perspect 105(3):308–314. [Erratum. Environ Health Perspect 105(6):570.]9171992
Munger RG, Isacson P, Kramer M, 1992a. Birth defects and pesticide-contaminated water supplies in Iowa. Am J Epidemiol 136(8):959.
*Munger RG, Hanson J, Isacson P, 1992b. Excess of birth defects in Iowa communities with herbicide-contaminated drinking water supplies. Department of Preventive Medicine and Environmental Health. University of Iowa College of Medicine 2–21 [unpublished manuscript].
*Murnik MR, Nash CL. 1977. Mutagenicity of the triazine herbicides atrazine, cyanazine, and simazine in Drosophila melanogaster. J Toxicol Environ Health 3:691–697.412980
Nadar I, Giurgea R. 1981. The effect of atrazine and prometryne on the glucose consumption and the insulin-sensitivity of diaphragms of white rats. 33(2):121–126.
Namera A, Yashiki M, Nagasawa N, 1997. Rapid analysis of malathion in blood using head space-solid phase micro extraction and selected ion monitoring. Forensic Sci Int 88:125–131.9251231
*Narotsky MG, Best DS, Guidici DL, 2001. Strain comparisons of atrazine-induced pregnancy loss in the rat. Reprod Toxicol 15:61–69.11137379
*NAS/NRC. 1989. Report of the oversight committee. In: Biologic markers in reproductive toxicology. 15–35.
Naydenova Z, Krauss G-J, Golovinsky E, 1999. Effect of s-triazine and phenoxyalkanoic acid herbicides on UDP-glucuronosyltransferase in rat liver microsomes. Pestic Sci 55:825–830.
*NCFAP. 2000. Trends in crop pesticide use: Comparing 1992 and 1997. Washington, DC: National Center for Food and Agricultural Policy.
*Needham LL, Blount B, Rogers S, 2000. Levels of selected nonpersistant endocrine disrupters in humans. In: Keith LH, Jones-Lepp TL, Needham LL, eds. Analysis of environmental endocrine disruptors. Washington, DC: American Chemical Society, 147–157.
Neskovic NK, Ibrahim E, Karan V, 1993. Acute and subacute toxicity of atrazine to carp (Cyprinus carpio L). Ecotoxicol Environ Saf 25:173–182.7682501
Neuberger JS. 1996. Atrazine and/or triazine herbicides exposure and cancer: An epidemiologic review. J Agromed 3(2):9–30.
Nezefi TA. 1971. Morphological changes in white rats during the prolonged action of atrazine. Zdravookhr Turkm 15(3):9–12.
Nezefi TA. 1974. Morphological changes in white rat organs under the influences of some herbicides. Zdravookhr Turkm 18(3):24–25.
*NIOSH. 1989. National Occupational Exposure Survey. National Institute for Occupational Safety and Health.
*NIOSH. 1994. Pocket guide to chemical hazards. DHHS (NIOSH) Publication No. 94–116. Washington, DC: U.S. Government Printing Office, National Institute for Occupational Safety and Health. June 1994.
*NIOSH. 1998a. NIOSH manual for analytical methods: Chlorinated and organonitrogen herbicides (air sampling). 4^th^ ed. DHHS (NIOSH) Publication 94–113. National Institute for Occupational Safety and Health.
*NIOSH. 1998b. NIOSH manual of analytical methods: chlorinated and organonitrogen herbicides (hand wash). National Institute for Occupational Safety and Health. DHHS (NIOSH) Publication 94–113.
*NIOSH. 2001. NIOSH pocket guide to chemical hazards. Atrazine. National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/npg/npgd0043.html. April 06, 2001.
Nitschke L, Schussler W. 1998. Surface water pollution by herbicides from effluents of waste water treatment plants. Chemosphere 36(1):35–41.9450325
Novak JM. 1999. Soil factors influencing atrazine sorption: Implications on fate. Environ Toxicol Chem 18(8):1663–1667.
*Novak JM, Watts DW. 1996. Solid-phase extraction and GC analyses of select agricultural pesticides and metabolites in stream water. J Environ Sci Health B 31(6):1171–1187.
Novak JM, Moorman TB, Karlen DL. 1994. Influence of soil aggregate size on atrazine sorption kinetics. J Agric Food Chem 42:1809–1812.
Novartis Corporation. 2001. Key global brands. http://www.cp.novartis.com/en/customer/key.asp. April 16, 2001.
*NRC. 1993. National Research Council. Pesticides in the diets of infants and children. Washington, DC: National Academy Press.
*Nsabimana E, Bohatier J, Belan A, 1996. Effects of the herbicide atrazine on the activated sludge process: Microbiology and functional views. Chemosphere 33(3):479–494.
*OSHA. 2001. Air contaminants. VI. Health effects discussion and determination of final PEL. Occupational Safety and Health Administration. http://www.oshaslc.gov/Preamble/AirCont_data/AIRCON6.html. April 06, 2001.
Osterloh J, Letz G, Pond S, 1983b. An assessment of the potential testicular toxicity of 10 pesticides using the mouse-sperm morphology assay. Mutat Res 116:407–415.6835254
Ouellet M, Bonin J, Rodrigue J, 1997. Hindlimb deformities (ectromelia, ectrodactyly) in free-living anurans from agricultural habitats. J Wildl Dis 33(1):95–104.9027696
Overton EB, Mascarella SW, McFall JA, 1980. Organics in the water column and air-water interface samples of Mississippi river water. Chemosphere 9:629–633.
*Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
*Pang L, Close ME. 1999. Attenuation and transport of atrazine and picloram in an alluvial gravel aquifer: A tracer test and batch study. N Z J Mar Freshwater Res 33:279–291.
Pape-Lindstrom PA, Lydy MJ. 1997. Synergistic toxicity of atrazine and organophosphate insecticides contravenes the response addition mixture model. Environ Toxicol Chem 16(11):2415–2420.
Paton DL, Walker JS. 1988. Pyrethrin poisoning from commercial-strength flea and tick spray. Am J Emerg Med 6:232–235.3370098
*Pelizzetti E, Maurino V, Minero C, 1990. Photocatalytic degradation of atrazine and other s-triazine herbicides. Environ Sci Technol 24:1559–1565.
*Pensabene JW, Fiddler W, Donoghue DJ. 2000. Supercritical fluid extraction of atrazine and other triazine herbicides from fortified and incurred eggs. J Agric Food Chem 48:1668–1672.10820076
*Penuela GA, Barcelo D. 2000. Comparative photodegradation study of atrazine and deethylatrazine in water samples containing titanium dioxide/hydrogen peroxide and ferric chloride/hydrogen peroxide. J AOAC Int 83(1):53–60.10693004
Perkovich BS, Anderson TA, Kruger EL, 1996. Enhanced mineralization of [^14^C]atrazine in Kochia scoparia rhizospheric soil from a pesticide-contaminated site. Pestic Sci 46:391–396.
Perry MJ, Christini DC, Mathew J, 2000. Urinalysis of atrazine exposure in farm pesticide applicators. Toxicol Ind Health 16:285–290.11693946
*Peruzovic M, Kniewald J, Capkun V, 1995. Effect of atrazine ingested prior to mating on rat females and their offspring. Acta Physiol Hung 83(1):79–89.7660840
*Peters JW, Cook RM. 1973. Effects of atrazine on reproduction in rats. Bull Environ Contam Toxicol 9(5):301–304.4780735
*Pino A, Maura A, Grillo P. 1988. DNA damage in stomach, kidney, liver and lung of rats treated with atrazine. Mutat Res 209:145–147.3193977
*Pintér A, Torok G, Borzsonyi M, 1990. Long-term carcinogenicity bioassay of the herbicide atrazine in F344 rats. Neoplasma 37(5):533–544.2234215
Pinter J, Thomas P. 1997. The ovarian progestogen receptor in the spotted sea trout, Cynoscion nebulosus, demonstrates steroid specificity different from progesterone receptors in other vertebrates. J Steroid Biochem Mol Biol 60(1–2):113–119.9182865
Plewa MJ. 1978. Activation of chemicals into mutagens by green plants: A preliminary discussion. Environ Health Perspect 27:45–50.367774
*Plewa MJ, Gentile JM. 1976. Mutagenicity of atrazine: A maize-microbe bioassay. Mutat Res 38:287–292.781535
*Podda MV, Deriu F, Solinas A, 1997. Effect of atrazine on spontaneous and evoked cerebellar activity in the rat. Pharmacol Res 36(3):199–202.9367664
*Pommery J, Mathieu M, Mathieu D, 1993. Atrazine in plasma and tissue following atrazine-aminotriazole-ethylene glycol-formaldehyde poisoning. Clin Toxicol 31(2):323–331.
Purcell M, Neault JF, Malonga H, 2001. Interactions of atrazine and 2,4-D with human serum albumin studied by gel and capillary electophoresis, and FTIR spectroscopy. Biochem Biophys Res Commun 1548:129–138.
*Qiao X, Ma L, Hummel HE. 1996. Persistence of atrazine and occurrence of its (SIC) primary metabolites in three soils. J Agric Food Chem 44:2846–2848.
*Quackenboss JJ, Pellizzari ED, Shubat P, 2000. Design strategy for assessing multi-pathway exposure for children: The Minnesota Children's Pesticide Exposure Study (MNCPES). J Expo Anal Environ Epidemiol 10:145–158.10791596
*Radosevich M, Traina SJ, Hao Y-L, 1995. Degradation and mineralization of atrazine by a soil bacterial isolate. Appl Environ Microbiol 61(1):297–302.7887609
*Radosevich M, Traina SJ, Tuovinen OH. 1996. Biodegradation of atrazine in surface soils and subsurface sediments collected from an agricultural research farm. Biodegradation 7:137–149.8882806
*Radovcic M, Straus B, Stankovic V. 1978. Effects of atrazine on glucose-6-phosphate dehydrogenase and aldolase in rat organs. Acta Pharm Jugosl 28:127–130.
*Ratenasavanh D, Beaune P, Morel F, 1991. Intralobular distribution and quantitation of cytochrome P-450 enzymes in human liver as a function of age. Hepatology 13(6):1142–1151.1904834
Ravindran M. 1977. Amyotrophic lateral sclerosis and toxic hydrocarbons. Arch Neurol 34:721.
Rayburn AL, Bouma J, Northcott CA. 2001. Comparing the clastogenic potential of atrazine with caffeine using Chinese hamster ovary (CHO) cells. AAOHN J 121:69–78.
*Redondo MJ, Ruiz MJ, Font G, 1997. Dissipation and distribution of atrazine, simazine, chlorpyrifos, and tetradifon residues in citrus orchard soil. Arch Environ Contam Toxicol 32:346–352.9175498
Reeder AL, Foley GL, Nichols DK, 1998. Forms and prevalence of intersexuality and effects of environmental contaminants on sexuality in cricket frogs (Acris crepitans). Environ Health Perspect 106(5):261–266.9647894
*Ribas G, Frenzilli G, Barale R, 1995. Herbicide-induced DNA damage in human lymphocytes evaluated by the single-cell gel electrophoresis (SCGE) assay. Mutat Res 344:41–54.7565891
*Ribas G, Surralles J, Carbonell E, 1998. Lack of genotoxicity of the herbicide atrazine in cultured human lymphocytes. Mutat Res 416:93–99.9725995
*Ribaudo MO, Bouzaher A. 1994. Atrazine: Environmental characteristics and economics of management. AER-699, USDA Agricultural Economic Report Number 699.
*Rice CP, Nochetto CB, Zara P. 2002. Volatilization of trifluralin, atrazine, metolachor, chlorpyrifos, alpha-endosulfan, and beta-endosulfan from freshly tilled soil. J Agric Food Chem 50(14):4009–4017.12083875
Richards RP, Baker DB. 1993. Pesticide concentration patterns in agricultural drainage networks in the Lake Erie Basin. Environ Toxicol Chem 12:13–16.
Richards RP, Baker DB. 1998. Triazines in waters of the Midwest: Exposure patterns. Am Chem Soc Abstr Pap 683:336–346.
Richards RP, Baker DB, Creamer NL, 1996. Well water quality, well vulnerability, and agricultural contamination in the Midwestern United States. J Environ Qual 25:389–402.
Ridgway RL, Tinney JC, MacGregor JT, 1978. Pesticide use in agriculture. Environ Health Perspect 27:103–112.104870
*Riederer M. 1990. Estimating partitioning and transport of organic chemicals in the foliage/atmosphere system: Discussion of a fugacity-based model. Environ Sci Technol 24:829–837.
Rivera J, Caixach J, De Torres M, 1986. Fate of atrazine and trifluralin from an industrial waste dumping at the Llobregat River. Presence in fish, raw and finished water. Int J Environ Anal Chem 24:183–191.3710679
*Rodriguez CJ, Harkin JM. 1997. Degradation of atrazine in subsoils, and groundwater mixed with aquifer sediments. Bull Environ Contam Toxicol 59:728–735.9323221
*Roloff BD, Belluck DA, Meisner LF. 1992. Cytogenetic studies of herbicide interactions in vitro and in vivo using atrazine and linuron. Arch Environ Contam Toxicol 22:267–271.1616310
Roses N, Poquet M, Munoz I. 1999. Behavioral and histological effects of atrazine on freshwater molluscs (Physa Acuta drap. and ancylus fluviatilis mull. gastropoda). J Appl Toxicol 19:351–356.10513681
*Ruiz MJ, Marzin D. 1997. Genotoxicity of six pesticides by Salmonella mutagenicity test and SOS chromotest. Mutat Res 390:245–255.9186574
*Sabik H, Jeannot R. 1998. Determination of organonitrogen pesticides in large volumes of surface water by liquid-liquid and solid-phase extraction using gas chromatography with nitrogen-phosphorus detection and liquid chromatography with atmospheric pressure chemical ionization mass spectrometry. J Chromatogr 818:197–207.
Saglio P, Trijasse S. 1998. Behavioral responses to atrazine and diuron in goldfish. Arch Environ Contam Toxicol 35:484–491.9732481
*Sanderson JT, Heneweer M, Seinen W, 1999. Chloro-s-triazine herbicides and certain metabolites induce aromatase (CYP19) activity in H295R human adrenocortical carcinoma cells. Organohalogen Compounds 42:5–8.
*Sanderson JT, Letcher RJ, Henewer M, 2001. Effects of chloro-s-triazine herbicides and metabolites on armoatase activity in various human cell lines and on vitellogenin in male carp hepatocytes. Environ Health Perspect 109(10):1027–1031.11675267
*Sanderson JT, Seinen W, Giesy JP, 2000. 2-Chloro-s-triazine herbicides induce aromatase (CYP19) activity in H295R human adrenocortical carcinoma cells: A novel mechanism for estrogenicity? Toxicol Sci 54:121–127.10746939
*Santa Maria C, Monero J, Lopez-Campos JL. 1987. Hepatotoxicity induced by the herbicide atrazine in the rat. J Anal Toxicol 7(6):373–378.
*Santa Maria C, Vilas MG, Muriana FG, 1986. Subacute atrazine treatment effects on rat renal functions. Bull Environ Contam Toxicol 36:325–331.3955241
Sathiakumar N, Delzell E. 1997. A review of epidemiologic studies of triazine herbicides and cancer. Crit Rev Toxicol 27(6):599–613.9408733
*Sathiakumar N, Delzell E, Cole P. 1996. Mortality among workers at two triazine herbicide manufacturing plants. Am J Ind Med 29:143–151.8821357
*Savitz DA, Arbuckle T, Kaczor D, 1997. Male pesticide exposure and pregnancy outcome. Am J Epidemiol 146(12):1025–1036.9420527
*Schlicher JE, Beat VB. 1972. Dermatitis resulting from herbicide use- a case study. J Iowa Med Soc 62:419–420.5044769
*Scutaru B, Giersch T, Cozmei C, 1998. Immunenzmatic determination of atrazine in rat tissue samples. Toxicology 127:11–16.9699789
*SDI. 1999. Water quality testing product profile: Atrazine rapid assay. Newark, Delaware: Strategic Diagnostics Inc. http://www.sdix.com/productpesticides.html. April 23, 2001.
*Seiler JP. 1973. A survey on the mutagenicity of various pesticides. Experientia 15(5):622–623.
Senseman SA, Ketchersid ML. 2000. Evaluation of co-solvents with supercritical fluid extraction of atrazine from soil. Arch Environ Contam Toxicol 38:263–267.10667922
*Setchell BP, Waites GM H. 1975. The blood-testis barrier. In: Creep RO, Astwood EB, Geiger SR, eds. Handbook of physiology: Endocrinology V. Washington, DC: American Physiological Society.
Setzler JV. 1980. Atrazine Residues in Northern Ohio Streams -- 1980. Technical Report. Tiffin, OH: Water Quality Lab/Heidelberg College.
*Seybold CA, Mersie W, McName C, 1999. Release of atrazine (^14^C) from two undistributed submerged sediments over a two-year period. J Agric Food Chem 47:2156–2162.10552512
*Seybold CA, Mersie W, McNamee C. 2001. Anaerobic degradation of atrazine and metolachlor and metabolite formation in wetland soil and water microsomes. J Environ Qual 30(4):1271–1277.11476505
*Shafer TJ, Ward TR, Meacham CA, 1999. Effects of the chlorotriazine herbicide, cyanazine, on GABA_A_ receptors in cortical tissue from rat brain. Toxicology 142:57–68.10647918
Shah PV, Fisher HL, Sumler MR, 1987. Comparison of the penetration of 14 pesticides through the skin of young and adult rats. J Toxicol Environ Health 21:353–366.3586065
*Shyr SW, Crowley WR, Grosvenor CE. 1986. Effect of neonatal prolactin deficiency on prepubertal tuberinfundibular and tuberohypophyseal dopaminergic neuronal activity. Endocrinology 119(3):1217–1221.3732163
*Siebers J, Gottschild D, Nolting H-G. 1994. Pesticides in precipitation in Northern Germany. Chemosphere 28(8):1559–1570.
*Šimić B, Jakominic M, Romac P, 2001. Effect of atrazine on sperm parameters in rats. Environment 2:195–202.
*Šimić B, Kniewald J, Kniewald Z. 1994. Effects of atrazine on reproductive performance in the rat. J Appl Toxicol 14(6):401–404.7884143
Šimić B, Kniewald Z, Davies JE, 1991. Reversibility of the inhibitory effect of atrazine and lindane on cytosol 5α-dihydrotestosterone receptor complex formation in rat prostate. Bull Environ Contam Toxicol 46:92–99.1705844
*Sinclair JL, Lee TR. 1992. Biodegradation of atrazine in subsurface environments. Environmental Research Brief. EPA/600/S-92/001.
Singh I, Lusby AF, McGuire PM. 1982. Mutagenicity of HPLC fractions from extracts of Aatrex-treated corn. Environ Mutagen 4:45–53.6175511
*Solomon KR, Baker DB, Richards RP, 1996. Ecological risk assessment of atrazine in North American surface waters. Environ Toxicol Chem 15(1):31–76.
*Sonnier M, Cresteil T. 1998. Delayed ontogenesis of CYP1A2 in the human liver. Eur J Biochem 251:893–898.9490065
*Southwick LM, Willis GH, Johnson DC, 1995. Leaching of nitrate, atrazine, and metribuzin from sugarcane in Southern Louisiana. J Environ Qual 24:684–690.
*Spalding RF, Junk GA, Richard JJ. 1980. Water: Pesticides in ground water beneath irrigated farmland in Nebraska, August 1978. Pestic Monit J 14(2):70–73.7232106
*Sprague LA, Herman JS, Hornberger GM, 2000. Atrazine adsorption and colloid-facilitated transport through the unsaturated zone. J Environ Qual 29:1632–1641
*Stafford CJ, Greer ES, Burns AW. 1992. Manual for chemical methods for pesticides and devices. 2nd ed. U.S. EPA: AOAC International, Arlington, VA.
*Starr JL, Glotfelty DE. 1990. Atrazine and bromide movement through a silt loam soil. J Environ Qual 19:552–558.
Steen RJCA, Leonards PEG, Brinkman UAT, 1999. Ecological risk assessment of agrochemicals in European estuaries. Environ Toxicol Chem 18(7):1574–1581.
*Steichen J, Koelliker J, Grosh D, 1988. Contamination of farmstead wells by pesticides, volatile organics, and inorganic chemicals in Kansas. Ground Water Monit Rev 8(3):153–160.
*Stevens JT, Breckenridge CB, Wetzel LT, 1994. Hypothesis for mammary tumorigenesis in Sprague-Dawley rats exposed to certain triazine herbicides. J Toxicol Environ Health 43:139–153.7932845
*Stevens JT, Breckenridge CB, Wetzel L, 1999. A risk characterization for atrazine: Oncogenicity profile. J Toxicol Environ Health 56:69–109.
*Stoker TE, Laws SC, Guidici DL, 2000. The effect of atrazine on puberty in male Wistar rats: An evaluation in the protocol for the assessment of pubertal development and thyroid function. Toxicol Sci 58:50–59.11053540
*Stoker TE, Robinette CL, Cooper RL. 1999. Maternal exposure to atrazine during lactation suppresses suckling-induced prolactin release and results in prostatitis in the adult offspring. Toxicol Sci 52:68–79.10568700
Stolze K, Nohl H. 1994. Effect of xenobiotics on the respiratory activity of rat heart mitochondria and the concomitant formation of superoxide radicals. Environ Toxicol Chem 13(3):499–502.
*Struthers JK, Jayachandran K, Moorman TB. 1998. Biodegradation of atrazine by Agrobacterium radiobacter J14a and use of this strain in bioremediation of contaminated soil. Appl Environ Microbiol 64(9):3368–3375.9726884
*Sumner DD, Cassidy JE, Szolics IM, 1984. Evaluation of the mutagenic potential of corn (zea mays L.) grown in untreated and atrazine (AATREX^®^) treated soil in the field. Drug Chem Toxicol 7(3):243–257.6376059
*Surrallés J, Xamena N, Creus A, 1995. The suitability of the micronucleus assay in human lymphocytes as a new biomarker of excision repair. Mutat Res 342:43–59.7885393
*Suschetet M, Leclerc J, Lhuissier M, 1974. Toxicite et effets nutriotionnels chez le rat, de deux herbicides: Le piclorame (acide amino-4 trichloro-3,5,6 picolinique) et l'atrazine (chloro-2 ethylamino-4 isopropylamino-6-S-traizine). Ann Nutr Aliment 28:29–47.4462415
*Syngenta. 2000. Key marketed products. Syngenta Key Global Brands. http://www.cp.novartis.com/en/customer/key.asp. April 13, 2000.
*Taets C, Aref S, Rayburn AL. 1998. The clastogenic potential of triazine herbicide combinations found in potable water supplies. Environ Health Perspect 106(4):197–201.9487108
*Tanfani F, Ambrosini A, Albertini G, 1990. Interaction of the herbicide atrazine with model membranes. I: Physico-chemical studies on dipalmitoyl phosphatidylcholine liposomes. Chem Phys Lipids 55:179–189.2090359
*Tangbanluekal L, Robinette CL. 1993. Prolactin mediates estradiol-induced inflammation in the lateral prostate of wistar rats. Endocrinology 132(6):2407–2416.8504745
Taningher M, Perrotta A, Malacarne D, 2002. Lack of significant promoting activity by benzene in the rat liver model of carcinogenesis. J Toxicol Environ Health 45(4):481–488.
*Tasli S, Ravanel P, Tissut M, 1996. Atrazine movement and dissipation in a sandy loam soil under irrigation: An immunoenzymatic study. Bull Environ Contam Toxicol 56:359–366.8825956
Tchounwou PB, Wilson BA, Ishaque AB, 2001. Atrazine potentiation of arsenic trioxide-induced cytotoxicity and gene expression in human liver carcinoma cells (HepG2). Mol Cell Biochem 222:49–59.11678611
*Telang NT, Suto A, Wong GY, 1992. Induction by estrogen metabolite 16α-hydroxyestrone of genotoxic damage and aberrant proliferation in mouse mammary epithelial cells. J Natl Cancer Inst 84(8):634–636.1556774
*Tennant AH, Peng B, Kligerman AD. 2001. Genotoxicity studies of three triazine herbicides: in vivo studies using the alkaline single cell gel (SCG) assay. Mutat Res 493:1–10.11516710
Tennant MK, Hill DS, Eldridge JC, 1994a. Chloro-s-triazine antagonism of estrogen action: Limited interaction with estrogen receptor binding. J Toxicol Environ Health 43:197–211.7932849
*Tennant MK, Hill DS, Eldridge JC, 1994b. Possible antiestrogenic properties of chloro-s-triazines in rat uterus. J Toxicol Environ Health 43:183–196.7932848
Tessier DM, Matsumura F. 2001. Increased ErB-2 tyrosine activity, MAPK phosphorylation, and cell proliferation in the prostate cancer cell line LNCaP following treatment by select pesticides. Toxicol Sci 60:38–43.11222871
Tezak Z, Simíc B, Kniewald J. 1992. Effect of pesticides on oestradiol-receptor complex formation in rat uterus cytosol. Food Chem Toxicol 30(10):879–885.1385282
*Thakur AK, Wetzel LT, Voelker RW, 1998. Results of a two-year oncogenicity study in Fischer 344 rats with atrazine. In: Ballantine LG, McFarland JE, Hackett DS, eds. Traizine herbicides: Risk assessment. ACS Symposium Series No. 683. Washington DC: American chemical Society, 384–398.
*Thurman EM, Cromwell AE. 2000. Atmospheric transport, deposition, and fate of triazine herbicides and their metabolites in pristine areas at Isle Royale National Park. Environ Sci Technol 34:3079–3085.
*Thurman EM, Goolsby DA, Meyer MT, 1991. Herbicides in surface waters of the Midwestern United States: The effect of spring flush. Environ Sci Technol 25:1794–1796.
*Thurman EM, Goolsby DA, Meyer MT, 1995. Evidence of long-range atmospheric transport and degradation of atrazine and deethylatrazine. Reprints of papers presented at the 2009th ACS National Meeting, Anaheim, CA. April 2–7, 1995, 286–287.
*Tierney DP, Nelson PA, Christensen BR, 1999. Predicted atrazine concentrations in the Great Lakes: Implications for biological effects. J Great Lakes Res 25(3):455–467.
*Timchalk C, Dryzga MD, Langvardt PW, 1990. Determination of the effect of tridiphane on the pharmacokinetics of [^14^C]-atrazine following oral administration to male Fischer 344 rats. Toxicology 61:27–40.2315949
*Tomlin CD S. 1997. The pesticide manual - world compendium: 11^th^ ed. Surrey, England: British Crop Protection Council, 55.
*Torres C, Ribas G, Xamena N, 1992. Genotoxicity of four herbicides in the drosophilia wing spot test. Mutat Res 280:291–295.1382231
Tran DQ, Kow KY, McLachlan JA, 1996. The inhibition of estrogen receptor-mediated responses by chloro-s-triazine-derived compounds is dependent on estradiol concentration in yeast. Biochem Biophys Res Commun 227:140–146.8858116
Travis CC, Arms AD. 1988. Bioconcentration of organics in beef, milk, and vegetation. Environ Sci Technol 22:271–274.22288859
*Trentacoste SV, Friedman AS, Youker RT, 2001. Atrazine effects on testosterone levels and androgen-dependent reproductive organs in peripubertal male rats. J Androl 22(1):142–148.11191080
*Trevisan M, Montepiani C, Ragozza L, 1993. Pesticides in rainfall and air in Italy. Environ Pollut 80:31–39.15091869
TRI83. 1984. Toxic Chemical Release Inventory. Bethesda, MD: National Library of Medicine, National Toxicology Information Program.
TRI98. 2001. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access. Offices of Environmental Information. U.S. Environmental Protection Agency. Toxic Release Inventory. http://www.epa.gov/triexplorer/. January 27, 2001.
*TRI01. 2003. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access. Offices of Environmental Information. U.S. Environmental Protection Agency. Toxic Release Inventory. http://www.epa.gov/triexplorer/. July 09, 2002.
*Tripathy NK, Broutray PK, Sahu GP, 1993. Atrazine, a triazine herbicide, is genotoxic in the Drosophila somatic and germ line cells. Biologisches Zenralblatt 112(3):312–318.
*Trochimowicz HJ, Kennedy GL, Krivanek ND. 2001. Alkyl pyridines and miscellaneous organic nitrogen compounds. In: Patty’s toxicology, 5^th^ ed. Vol. 4. Bingham E, Cohrssen B, Powell CH, eds. York New: John Wiley and Sons, 1193–1372.
Trojanova M, Mourek J. 1990. Acute changes in the organism of the laboratory rat during development after parenteral application of the herbicide zeazin S-40. Sb Lek 92(2–3):92–96.2349447
*Turiel E, Fernandez P, Perez-Conde C, 1999. Oriented antibody immobilzation for atrazine determination by a flow-through fluoroimmunosensor. Fresenius J Anal Chem 365:658–662.
*UDC. 1977. Industrial process profiles for environmental use: Pesticide industry. Austin, Texas: U.S. Department of Commerce: National Technical Information Service. Chapter 8: 71. PB-266 255.
*Ugazio G, Bosio A, Burdino E, 1991a. Lethality, hexobarbital narcosis and behavior in rats exposed to atrazine, bentazon or molinate. Res Commun Chem Pathol Pharmacol 74(3):349–361.1775725
*Ugazio G, Bosio A, Nebbia C, 1991b. Age- and sex-related effects on hepatic drug metabolism in rats chronically exposed to dietary atrazine. Res Commun Chem Pathol Pharmacol 73(2):231–243.1784837
*Ugazio G, Burdino E, Dacasto M, 1993. Induction of hepatic drug metabolizing enzymes and interaction with carbone tetrachloride in rats after a single oral exposure to atrazine. Toxicol Lett 69:279–288.8212068
*USDA. 1993. Pesticide data program: annual summary calendar year 1998. Marketing Service Science and Technology. United States Department of Agriculture.
*USDA. 1998. Pesticide data program: annual summary calendar year 1998. Marketing Service Science and Technology. United States Department of Agriculture.
*USDA. 1999. Pesticide data program: annual summary calendar year 1999. Agricultural marketing service science & technology. United States Department of Agriculture.
USDA. 2000. Mechanistic investigations of atrazine photolysis and hydroxy radical reactions. Influence of dissolved organic carbon. United States Department of Agriculture.
*USGS. 2000. Water-quantity and water-quality aspects of a 500-year flood-Nishnabotna River, Southwest Iowa, June 1998. United States Geological Survey.
*Van Leeuwen JA, Waltner-Toews D, Abernathy T, 1999. Associations between stomach cancer incidence and drinking water contamination with atrazine and nitrate in Ontario (Canada) agroecosystems, 1987–1991. Int J Epidemiol 28(8):836–840.10597979
*Venkatesh K, Levi PE, Inman AO, 1992. Enzymatic and immunohistochemical studies on the role of cytochrome P450 and the flavin-containing monooxygenase of mouse skin in the metabolism of pesticides and other xenobiotics. Pestic Biochem Physiol 43:53–66.
*Verschueren K. 2001. Handbook of environmental data on organic chemicals, 4^th^ ed. Vol. 1. New York: John Wiley and Sons, 231–235.
*Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238:476–483.8681961
Vonier PM, Crain DA, McLachlan JA, 1996. Interaction of environmental chemicals with the estrogen and progesterone receptors from the oviduct of the American Alligator. Environ Health Perspect 104(12):1318–1322.9118873
*Vos JG, Krajnc EI. 1983a. Immunotoxicty of pesticides. Dev Sci Pract Toxicol 11:229–240.
*Vos JG, Krajnc EI, Beekhof PK, 1983b. Methods for testing immune effects of toxic chemicals: Evaluation of the immunotoxicity of various pesticides in the rat. Pest Chem; Proc Int Congr, 5^th^ ed., 3:497–504.
Walker EM J, Gale GR, Atkins LM, 1979. Some effects of atrazine on ehrlich ascites tumor cells in vitro and in vivo. Bull Environ Contam Toxicol 22:95–102.465795
*Walker MJ, Porter KS. 1990. Assessment of pesticides in Upstate New York ground water: Results of a 1985–1987 sampling survey [Abstract]. Ground Water Monit Remed 10(1):116–126.
*Wang Y-S, Duh J-R, Chen Y-L. 1996. Movement of three s-triazine herbicides atrazine, simazine, and ametryn in subtropical soils. Bull Environ Contam Toxicol 57:743–750.8791549
*Ward TM, Weber JB. 1968. Aqueous solubility of alkyl amino-s-triazine as a function of pH and molecular structure. J Agr Food Chem 16:959–961.
*Weber JB. 1991. Fate and behaviour of herbicides in soils. Appl Plant Sci 5:29–41.
*Weisenburger DD. 1990. Environmental epidemiology of non-Hodgkin's lymphoma in Eastern Nebraska. Am J Ind Med 18:303–305.2220835
Weisenburger DD, Hickman TJ, Patil KD, 1990. Carcinogenesis tests of atrazine and N-nitrosoatrazine-compounds of special interest to the midwest [Abstract]. Proc Am Assoc Cancer Res 31:102.
*Wenk M, Baumgartner T, Dobovsek J, 1998. Rapid atrazine mineralization in soil slurry and moist soil by inoculation of an atrazine-degrading Pseudomonas sp. strain. Appl Microbiol Biotechnol 49:624–630.9650261
*West JR, Smith HW, Chases H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
*Wetzel LT, Luempert LG, Breckenridge CB, 1994. Chronic effects of atrazine on estrus and mammary tumor formation in female Sprague-Dawley and Fischer-344 rats. J Toxicol Environ Health 43:169–182.7932847
*WHO. 2001. Guidelines for drinking-water quality. World Health Organization. http://www.who.int/water_sanitation_health/GDWQ/Chemicals/atrazinesum/html. April 06, 2001.
*Widdowson EM, Dickerson JW T. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise. Volume II: The elements Part A. New York: Academic Press.
*Widmer SK, Olson JM, Koskinen WC. 1993. Kinetics of atrazine hydrolysis in water. J Environ Sci Health B 28(1):19–28.
Wiegand C, Pflugmacher S, Giese M, 2000. Uptake, toxicity, and effects on detoxication enzymes of atrazine and trifluoroacetate in embryos of zebrafish. Ecotoxicol Environ Saf 45:122–131.10648131
*Wienhold BJ, Gish TJ. 1994. Effect of formulation and tillage practice on volatilization of atrazine and alachlor. J Environ Qual 23:292–298.
*Wietersen RC, Daniel TC, Fermanich KJ, 1993. Atrazine, alachlor, and metolachlor mobility through two sandy Wisconsin soils. J Environ Qual 22:811–818.
Wigfield YY, Grant R. 1993. Analysis for atrazine in fortified cornmeal and corns using a commercially available enzyme immunoassay microtiter plate. Bull Environ Contam Toxicol 51:171–177.8353379
*Wittmann C, Bilitewski U, Giersch T, 1996. Development and evaluation of a dipstick immunoassay format for the determination of atrazine residues on-site. Analyst 121:863–869.8763210
Wu TL. 1980. Dissipation of the herbicides atrazine and alachlor in a Maryland corn field. J Environ Qual 9(3):459–465.
*Wu TL. 1981. Atrazine residues in estuarine water and the aerial deposition of atrazine into Rhode River, Maryland. Water Air Soil Pollut 15:173–184.
*Wurth G, Straus B, Stankovic V. 1982. Effects of atrazine on ceruloplasmin and acid phosphatase in rat liver, kidney, and spleen. Acta Pharm Jugosl 32:53–57.
Yoder J, Watson M, Benson WW. 1973. Lymphocyte chromosome analysis of agricultural workers during extensive occupational exposure to pesticides. Mutat Res 21:335–340.4779319
*Zahm SH, Weisenburger DD, Babbit PA, 1990. A case-control study of non-Hodgkin's lymphoma and the herbicide 2,4-dichlorophenoxyacetic acid (2,4-D) in eastern Nebraska. Epidemiology 1:349–356.2078610
*Zahm SH, Weisenburger DD, Cantor KP, 1993a. Role of the herbicide atrazine in the development of non-Hodgkin's lymphoma. Scand J Work Environ Health 19:108–114.
*Zahm SH, Weisenburger DD, Saal RC, 1993b. The role of agricultural pesticide use in the development of non-Hogkin's lymphoma in women. Arch Environ Health 48(5):353–358.8215601
Zapardiel A, Bermejo E, Perez JA, 2000. Determination of s-triazines with copper and glassy carbon electrodes. Flow injection analysis of aziprotryne in water samples. Fresenius J Anal Chem 367:461–466.11227477
*Zeiger E, Anderson B, Haworth S, 1988. Salmonella mutagenicity tests: IV. Results from the testing of 300 chemicals. Environ Mol Mutagen 11(Suppl. 12):1–158.
*Ziegler EE, Edwards BB, Jensen RL, 1978. Absorption and retention of lead by infants. Pediatr Res 12:29–34.643372
Zolese G, Ambrosini A, Bertoli E, 1990. Interaction of the herbicide atrazine with model membranes. II: Effect of atrazine on fusion of phospholipid vesicles. Chem Phys Lipids 56:101–110.2095988