# PEER REVIEW

A peer review panel was assembled for atrazine. The panel consisted of the following members:

1. James E. Klaunig, Ph.D., Professor of Pharmacology and Toxicology, Director, Division of Toxicology, Indiana University School of Medicine, 135 Bennington Drive, Zionsville, Indiana 46077;
2. Kannan Krishnan, Ph.D., Associate Professor, Department of Occupational and Environmental Health, University of Montreal School of Medicine, 2375 Chemin de la Cote Ste-Catherine, Montreal, Quebec H3T 1A8; and
3. Frederick Oehme, D.V.M, Ph.D., Professor of Toxicology, Pathobiology, Medicine, and Physiology, Director, Comparative Toxicology Laboratories, Department of Diagnostic Medicine/Pathobiology, Kansas State University, 1800 Dennison Avenue, Mosier Hall, Manhattan, Kansas 66506-5606.

These experts collectively have knowledge of atrazine's physical and chemical properties, toxicokinetics, key health end points, mechanisms of action, human and animal exposure, and quantification of risk to humans. All reviewers were selected in conformity with the conditions for peer review specified in Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

Scientists from the Agency for Toxic Substances and Disease Registry (ATSDR) have reviewed the peer reviewers' comments and determined which comments will be included in the profile. A listing of the peer reviewers' comments not incorporated in the profile, with a brief explanation of the rationale for their exclusion, exists as part of the administrative record for this compound. A list of databases reviewed and a list of unpublished documents cited are also included in the administrative record.

The citation of the peer review panel should not be understood to imply its approval of the profile's final content. The responsibility for the content of this profile lies with the ATSDR.