# UPDATE STATEMENT

A Toxicological Profile for atrazine, Draft for Public Comment was released in September, 2001. This edition supersedes any previously released draft or final profile.

Toxicological profiles are revised and republished as necessary, but no less than once every three years. For information regarding the update status of previously released profiles, contact ATSDR at:

- Agency for Toxic Substances and Disease Registry
  Division of Toxicology/Toxicology Information Branch
  1600 Clifton Road NE,
  Mailstop E-29
  Atlanta, Georgia 30333