# 8 REGULATIONS AND ADVISORIES

International, national, and state regulations and advisories regarding atrazine in air, water, and other media are summarized in Table 8-1. These values have been established because of the potential for atrazine to cause adverse health effects in exposed people.

The EPA (IRIS 2002) has calculated a chronic oral Reference Dose (RfD) for atrazine of 3.5×10^−2^ mg/kg/day based on a NOAEL of 3.5 mg/kg/day for decreased body weight gain in rats exposed for their lifetimes to 70 ppm atrazine in the diet. The NOAEL of 3.5 mg/kg/day atrazine was divided by uncertainty factors of 10 for extrapolation from animals to humans and 10 for human variability in sensitivity. EPA has not derived a Reference Concentration (RfC) for chronic inhalation or done a carcinogenicity assessment for lifetime exposure.

No inhalation MRLs have been derived for atrazine due to lack of data. An MRL of 0.01 mg/kg/day has been derived for acute-duration oral exposure (14 days or less) to atrazine based on a NOAEL of 1 mg/kg/day for decreased body weight gain in pregnant rabbits exposed to atrazine on gestational days 7–19 (Infurna et al. 1988) and an uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

An MRL of 0.003 mg/kg/day has been derived for intermediate-duration oral exposure (15–365 days) to atrazine based on a LOAEL from a 19-day study in which pigs that were administered 1 mg/kg/day atrazine in the diet had decreased levels of estradiol-17β (E_2_), resulting in delayed onset of estrus (Gojmerac et al. 1999). The MRL of 0.003 mg/kg/day was calculated by dividing the LOAEL of 1 mg/kg/day by an uncertainty factor of 300 (10 to account for the use of a LOAEL for delayed onset of estrus, 10 for extrapolation from animals to humans, and 3 for human variability). An uncertainty factor of 3 for human variability was used instead of 10 because the critical effect was identified in a sensitive population (young, developing female pigs). The existing database on the chronic-duration oral toxicity of atrazine was considered inadequate for MRL derivation.

Table 8-1 Regulations and Guidelines Applicable to Atrazine

Agency | Description | Information | Reference
[underlined: INTERNATIONAL]
Guidelines:
IARC | Carcinogenicity classification | Group 3^a^ | IARC 2001
WHO | Drinking water guideline | 2 μg/L | WHO 2001
[underlined: NATIONAL]
Regulations and Guidelines:
a. Air:
ACGIH | TLV–TWA | 5 mg/m^3^ | ACGIH 2000
NIOSH | REL (TWA) | 5 mg/m^3^ | NIOSH 2001
OSHA | PEL (8-hour TWA) | 5 mg/m^3^ | OSHA 2001
b. Water
EPA | Drinking water standards | 3 μg/L | EPA 2001e; 40CFR141.32; (e)(28)
| Drinking water standards DWEL | 1.0 mg/L | EPA 2002b
| MCLG | 3 μg/L | EPA 2001d; 40CFR141.50
| MCL | 3 μg/L | EPA 2001c; 40CFR141.61
c. Food
EPA | Tolerances for residues (ppm) | | EPA 2001h
| Cattle-fat, meat byproducts, and meat | 0.02 | 40CFR180.220
| Corn, fodder–field, pop, and sweet | 15.0
| Corn, forage–field, pop, and sweet | 15.0
| Corn–fresh and grain | 0.25
| Eggs | 0.02
| Goats-fat, meat byproducts, and meat | 0.02
| Guava | 0.05
| Hogs–fat, meat byproducts, and meat | 0.02
| Horses–fat, meat byproducts, and meat | 0.02
| Macadamia nuts | 0.25
| Milk | 0.02
| Poultry–fat, meat byproducts, and meat | 0.02
| Rye grass, perennial | 15.0
| Sheep–fat, meat byproducts, and meat | 0.02
| Sorghum-fodder and forage | 15.0
| Sorghum-grain | 0.25
EPA | Tolerances for residues (ppm) | | EPA 2001h
| Sugarcane-fodder and forage | 0.25 | 40CFR180.220
| Wheat-fodder and straw | 5.0
| Wheat, grain | 0.25
| Tolerances for combined residues of atrazine and its metabolites (ppm)
| Grass, range | 4.0
FDA | Bottled water | 3 μg/L | FDA 2000b; 21CFR165.110
| Food additives permitted for direct addition to food for human consumption—diethanolamide condensate based on a mixture of saturated and unsaturated soybean oil fatty acids (or stripped coconut fatty acids) as a surfactant in emulsifier blends | Added to the herbicide atrazine for application to corn | FDA 2000a; 21CFR172.710
d. Other
ACGIH | Carcinogenicity classification | A4^b^ | ACGIH 2000
| RfD | 3.5×10^−2^ mg/kg/day | IRIS 2001
| Effluent limitations for BOD5 and TSS | | EPA 2001g; 40CFR455.20
EPA | Toxic chemical release reporting; Community Right-to-Know; effective date of reporting | 01/01/95 | EPA 2001i; 40CFR372.65
| Standards for hazardous waste TSD facilities—Henry’s law constant less than 0.1 atm m^3^/mol | | EPA 2001b; 40CFR265; Appendix VI
NRC | Acceptable daily intakes | 2.15×10^−2^ mg/kg/day | HSDB 2001
[underlined: STATE]
a. Air
Alaska | Air contaminant standard | 5 mg/m^3^ | BNA 2001
Connecticut | HAP | | BNA 2001
| 8 Hours | 100 μg/m^3^
| 30 Minutes | 500 μg/m^3^
Hawaii | Air contaminant | 5 mg/m^3^ | BNA 2001
Kentucky | Air quality | | BNA 2001
| TAL (8 hours) | 20 mg/m^3^
| Significant levels | 1.276×10^−3^ pounds/hour
Louisiana | Hazardous waste; air emission standards—compounds with Henry’s law constant less than 0.1 atm m^3^/mol (at 25 °C) | | BNA 2001
Michigan | PEL (TWA) | 5 mg/m^3^ | BNA 2001
Nebraska | Hazardous waste; organic air emission standards for tanks and containers—compounds with Henry’s law constant less than 0.1 atm m^3^/mol | | BNA 2001
New Hampshire | Toxic air pollutant | | BNA 2001
| OEL | 5 mg/m^3^
| 24-Hour AAL | 18 μg/m^3^
| Annual AAL | 12 μg/m^3^
| 24-Hour de minimus | 1.67×10^−3^ pounds/hour
| Annual de minimus | 3.91×10^1^ pounds/year
New Mexico | Toxic air pollutant | | BNA 2001
| OEL | 5 mg/m^3^
| Emissions | 0.333 pounds/hour
New York | PEL (TWA) | 5 mg/m^3^ | BNA 2001
North Carolina | PEL (TWA) | 5 mg/m^3^ | BNA 2001
Washington | PEL (TWA) | 5 mg/m^3^ | BNA 2001
| Toxic air pollutants | | BNA 2001
| ASIL (24-hour average) | 17 μg/m^3^
Wisconsin | Emission rate with emission point | | BNA 2001
| <25 feet | 4.176×10^−1^ pounds/hour
| Emission rate with emission point
| >25 feet | 1.752 pounds/hour
b. Water
Alabama | MCL | 3 μg/L | BNA 2001
Alaska | MCL | 3 μg/L | BNA 2001
Arizona | Drinking water guideline | 3 μg/L | HSDB 2001
| Groundwater protection list | | BNA 2001
| Safe drinking water—reporting limit | 0.1 μg/L | BNA 2001
California | Drinking water standard | 3 μg/L | HSDB 2001
| Pesticide contamination prevention—groundwater protection list | | BNA 2001
Colorado | Groundwater quality standards | 3 μg/L | BNA 2001
| MCL | 3 μg/L | BNA 2001
Connecticut | Standards for quality of public drinking water—MCL | 3 μg/L | BNA 2001
Delaware | MCL | 3 μg/L | BNA 2001
Florida | Contaminant cleanup target level | | BNA 2001
| Freshwater surface water criteria | 1.8 μg/L (human health)
| Marine surface water criteria | 1.8 μg/L (human health)
Georgia | MCL for drinking water | 3 μg/L | BNA 2001
Hawaii | MCL | 3 μg/L | BNA 2001
Idaho | Groundwater quality standards | 3 μg/L | BNA 2001
Illinois | MCL | 3 μg/L | BNA 2001
Kansas | Surface water quality criteria | | BNA 2001
| Aquatic life
| Acute | 170 μg/L
| Chronic | 3 μg/L
| Domestic water supply | 3 μg/L
Kentucky | MCL | 3 μg/L | BNA 2001
Maine | Drinking water guideline | 3 μg/L | HSDB 2001
| Private water systems | | BNA 2001
| Maximum exposure guideline | 4.3×10^−2^ mg/L
| Action level | 2.1×10^−2^ mg/L
Maryland | Drinking water | 3 μg/L | BNA 2001
Michigan | MCL | 3 μg/L | BNA 2001
| Effective date | 07/30/92
Minnesota | Drinking water guideline | 20 μg/L | HSDB 2001
Mississippi | Groundwater standards | 3 μg/L | BNA 2001
Missouri | MCL | 3 μg/L | BNA 2001
Nebraska | Aquatic criteria^d^ | | BNA 2001
| Acute | 330 μg/L
| Chronic | 12 μg/L
| MCL | 3 μg/L | BNA 2001
New Jersey | Groundwater quality criteria | 3 μg/L | BNA 2001
| PQL | 1 μg/L
New Mexico | MCL | 3 μg/L | BNA 2001
New York | Groundwater effluent limitations—maximum allowable concentration | 7.5 μg/L | BNA 2001
| MCL | 3 μg/L | BNA 2001
North Dakota | MCL | 3 μg/L | BNA 2001
Ohio | MCL | 3 μg/L | BNA 2001
Oklahoma | MCL | 3 μg/L | BNA 2001
Rhode Island | Groundwater quality standard | 3 μg/L | BNA 2001
| Preventive action limit | 1.5 μg/L
Rhode Island | MCLG | 3 μg/L | BNA 2001
| MCL | 3 μg/L
South Carolina | MCL | 3 μg/L | BNA 2001
South Dakota | Groundwater quality standards | 3 μg/L | BNA 2001
Tennessee | MCL | 3 μg/L | BNA 2001
Texas | MCL | 3 μg/L | BNA 2001
Utah | Groundwater quality standards | 3 μg/L | BNA 2001
| MCL | 3 μg/L | BNA 2001
Vermont | Groundwater quality standards | | BNA 2001
| Enforcement standard | 3 μg/L
| Preventive action level | 1.5 μg/L
| MCL | 3 μg/L | BNA 2001
Virginia | MCLG MCL | 3 μg/L 3 μg/L | BNA 2001
Washington | MCLG | 3 μg/L | BNA 2001
| MCL | 3 μg/L
West Virginia | Groundwater standards | Not to exceed 3 μg/L | BNA 2001
Wisconsin | Groundwater quality standards (total chlorinated residues) | | BNA 2001
| Enforcement standard^e^ | 3 μg/L
| Preventive action limit^e^ | 0.3 μg/L
| MCLG^f^ | 3 μg/L | BNA 2001
| MCL | 3 μg/L
Wyoming | Groundwater standards—MCL | 3 μg/L | BNA 2001
c. Food | | No data
d. Other
Arizona | Soil remediation levels | | BNA 2001
| Residential | 20.0 mg/kg
| Non-residential | 86.0 mg/kg
Arkansas | Hazardous waste management—compounds with Henry’s law constant less than 0.1 atm m^3^/mol (at 25 °C) | | BNA 2001
California | Hazardous substance list | | BNA 2001
California | Pesticide registration—active ingredient that have the most significant data gaps, widespread use, and suspected to be hazardous to people | | BNA 2001
| Restricted pesticide —agricultural, outdoor institutional, and outdoor industrial uses of pesticides containing atrazine are prohibited in the Pesticide Management Zones | | BNA 2001
Colorado | Hazardous waste—compounds with Henry’s law constant less than 0.1 atm m^3^/mol (at 25 °C) | | BNA 2001
Delaware | Hazardous waste—compounds with Henry’s law constant less than 0.1 atm m^3^/mol | | BNA 2001
Florida | Toxic substances in the workplace—substance list | | BNA 2001
Iowa | Restrictions on distribution and use of pesticides | | BNA 2001
Massachusetts | Containers adequately labeled pursuant to federal law | | BNA 2001
| Oil and hazardous material list | | BNA 2001
Minnesota | Hazardous substance | | BNA 2001
| RfD | 3.5×10^−2^ mg/kg/day | BNA 2001
| Health risk limit | 20 μg/L
| Toxic end point | Cardiovascular system | BNA 2001
New Jersey | Hazardous substance | | BNA 2001
South Carolina | Hazardous waste—compounds with Henry’s law constant less than 0.1 atm m^3^/mol | | BNA 2001
Tennessee | Hazardous substance site remediation goals | 3×10^−3^ ppm | BNA 2001
Washington | Pesticide regulation | Restricted use pesticide | BNA 2001
Wisconsin | Hazardous waste—compounds with Henry’s law constant less than 0.1 atm m^3^/mol (at 25 °C) Pesticide product restrictions | | BNA 2001

a Group 3: not classifiable as to its carcinogenicity to humans

b A4: not classifiable as a human carcinogen

c Group C: possible human carcinogen

d Human health criteria at 10–5 risk level for carcinogens based on the consumption of fish and other aquatic organisms.

e Total chlorinated atrazine residues includes parent compound and the following metabolites of health concern: 2-chloro-4-amino-6 isopropylamino-s-triazine (formerly deethylatrazine), 2-chloro-4-amino-6-ethylamino-s-triazine (formerly deisopropylatrazine), and 2-chloro-4,6-diamino-s-triazine (formerly diaminoatrazine).

f Atrazine, total chlorinated residue includes atrazine and its metabolites, diaminoatrazine, diethylatrazine, and deisopropylatrazine.

ACGIH = American Conference of Governmental Industrial Hygienists; AAL = ambient air limits; ASIL = acceptable source impact levels; BOD = biological oxygen demand; BNA = Bureau of National Affairs; CFR = Code of Federal Regulations; DWEL = drinking water equivalent level; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; HAL = health advisory level; HAP = hazardous air pollutant; HSDB = Hazardous Substances Data Bank; IARC = International Agency for Research on Cancer; IRIS = Integrated Risk Information System; MCL = maximum contaminant level; MCLG = maximum contaminant level goal; NIOSH = National Institute for Occupational Safety and Health; OEL = occupational exposure limit; OSHA = Occupational Safety and Health Administration; PEL = permissible exposure limit; PQL = practical quantitation level; REL = recommended exposure limit; RfD = reference dose; TAL = threshold ambient limit; TLV = threshold limit values; TSD = treatment, storage, and disposal; TSS = total suspended solids; TWA = time-weighted average; WHO = World Health Organization