# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity of atrazine is located in Table 4-1.

Atrazine is produced commercially in the United States as a technical-grade chemical with a purity of 92–97% (IARC 1999) to 99.9% (EPA 1983) active ingredient. Impurities in the former formulation included dichlorotriazines, hydroxytriazines, and tris(alkyl)aminotriazines.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of atrazine is located in Table 4-2.

Table 4-1 Chemical Identity of Atrazine

Characteristic | Information | Reference
Chemical name: | Atrazine | EPA 1983; Howard 1991
Synonyms: | 6-Chloro-n-ethyl-n’-(1-methylethyl)-triazine-2,4-diamine; 2-Chloro-4-ethylamino-6-iso-propylamine-s-triazine; 2-Chloro-4-(ethyl-amino)-6-(isopropylamino)-s-triazine; 2-Chloro-4-(ethylamino)-6-(isopropylamino)-triazine; Chloro-4-(propylamino)-6-ethyl-amino-s-triazine; Chloro-3-ethylamino-5-iso-propylamino-2,4,6-triazine; Butyl-n-(acetyl)-aminopropionic acid
Registered trade names: | Aatrex®, Aatram®, Atratol®, Gesaprim® | EPA 1983; Syngenta 2000
Chemical structure:
| [image]
Identification numbers:
CAS registry | 1912-24-9 | HSDB 2002
NIOSH RTECS | XY5600000 | HSDB 2002
DOT/UN/NA/IMO | UN 2763 | HSDB 2002
| UN 2997 | HSDB 2002
| UN 2764 | HSDB 2002
| UN 2998 | HSDB 2002
| IMO 6.1 | HSDB 2002
| IMO 3.2 | HSDB 2002
HSDB | 413 | HSDB 2002
Experimental code number | G-30027 (Ciba-Geigy) | Farm Chem Handbook 2001

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NIOSH = National Institute for Occupational Safety and Health; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of Atrazine

Property | Information | Reference
Molecular weight | 215.69 | HSDB 2002
Color | White colorless | HSDB 2002
Physical state | Colorless powder | IARC 1999
| Colorless crystals | Verschueren 2001
Melting point | 173–175 °C | HSDB 2002
Density | 1.23 g/cm^3^ (22 °C) | HSDB 2002
Odor | Odorless | NIOSH 1994
Solubility:
at 22 °C | Soluble in water (34.7 mg/L) | Ward and Weber 1968
at 25 °C | Soluble in ethylacetate (24 g/L), acetone (31 g/L), dichloromethane (28 g/L), ethanol (15 g/L), toluene (4 g/L), n-hexane (0.11 g/L), and n-octanol (8.7 g/L) | Tomlin 1997
at 27 °C | Soluble in n-pentane (360 mg/L), diethyl ether (12,000 mg/L), methanol (18,000 mg/L), ethyl acetate (28,000 mg/L), chloroform (52,000 mg/L), and dimethyl sulfoxide (183,000 mg/L) | Humburg 1989
Partition coefficients:
Log K_ow_ | 2.60 | Hansch et al. 1995
| 2.71 | Brown and Flagg 1981
Log K_oc_ | 1.96 | Dousset et al. 1994
| 1.97 | Green et al. 1993
| 2.98 | Koskinen and Rochette 1996
| 3.38 | Koskinen and Rochette 1996
| 2.18 | Meakins et al. 1995
| 2.53 | Meakins et al. 1995
| 2.33 | Weber 1991
Vapor pressure at 25 °C | 2.89×10^−7^mmHg | Tomlin 1997
Henry’s Law constant at 25 °C | 2.96×10^−9^ atm-m^3^/mol | Riederer 1990
pK_a_ | 1.68 | Bailey et al. 1968
Hydrolysis rate constant at 25 °C | 2.735×10^−11^ cm^3^/molecule-second (estimated) | Meylan and Howard 1993
Autoignition temperature | No data
Flashpoint | Not applicable | EPA 1983
Flammability limits | Not applicable | EPA 1983
Conversion factors^a^ | mg/m^3^=8.82×ppm | HSDB 2002; rIARC 1999
Explosive limits | Not applicable | EPA 1983

a In air, atrazine is both present in the gas phase and associated with particulates (HSDB 2002). Conversion factors are only applicable for those compounds that exist entirely in the vapor phase. Therefore, while this conversion factor has been reported in the literature, its use is not recommended, as it will not provide an accurate reflection of ambient air atrazine concentrations.